# Summary and Discussion

In this chapter, we describe the limitations of our review and meta-analysis and then present our conclusions. We also discuss the implications of our findings for future research.

## Limitations

### Publication Bias

Our literature search procedures were extensive and included canvassing experts from academia and industry regarding studies we may have missed. However, our test for possible publication bias indicates that there is unexplained heterogeneity, one reason for which could be publication bias. Furthermore, when we reviewed the recent meta-analysis assessing death and the use of these drugs in persons with dementia, we learned of the existence of some manufacturer-supported trials, the published results of which we searched for and were not able to find, despite extensive computerized searches and requests to the manufacturers (we have since learned the results were not published). It is possible that other such unpublished trial results exist for the other conditions included in our report. We assume that publication bias may occur for all conditions, resulting in an overestimation of the efficacy of these drugs for all conditions.

### Study Quality

An important limitation common to systematic reviews is the quality of the original studies. Recent attempts to define elements of study design and execution that are related to bias have shown that in many cases, such efforts are not reproducible and do not distinguish studies based on result bias. Therefore, the current approach is to avoid rejecting studies or using quality criteria to adjust the meta-analysis results. However, we did use as a measure of quality the Jadad scale, which is the only validated set of quality criteria for trials. As there is a lack of empirical evidence regarding other study characteristics and their relationship to bias, we did not attempt to use other criteria. However, other aspects of the design and execution of a trial may be related to bias, but we do not yet have good measures of these elements. Even given this limitation, our sensitivity analysis on the relationship between trial quality (as measured using Jadad’s scale) and result leads us to conclude that the better quality trials report an effect size 25 percent smaller than do lower quality trials. This finding increases the likelihood that a synthesis of results of all studies - whether narrative or quantitative - is producing inflated estimates of efficacy.

### Heterogeneity

In our meta-analysis, we observed evidence of heterogeneity. In an attempt to incorporate any heterogeneity, we used a random effects approach. There were too few trials to perform sensitivity analyses using variables that might account for heterogeneity other than quality (completeness of follow-up, dose, etc.). Further, we are unable to explain most of the heterogeneity. Thus, our pooled results should be interpreted in light of the observed heterogeneity.

### Applicability of Findings

Green & Glasgow125 provide a framework for evaluating the relevance, generalization, and applicability of research. Their framework includes assessing the participation rate, the intended target population, representativeness of the setting, representativeness of the individuals, along with information about implementation and assessment of outcomes. As these data are reported rarely in the studies we reviewed, conclusions about applicability are necessarily weak. In many cases, enrollment criteria for these trials were highly selective (for example, requiring an open-label run in). Such highly selective criteria many increase the likelihood of benefit and decrease the likelihood of adverse events in such patients. At best we judge these results to be only modestly applicable to the patients seen in typical office-based care.

## Conclusions

With the above limitations in mind, we reached the conclusions displayed in the table below.

Table 11

Summary of evidence- efficacy

Condition | Strength of Evidence | Conclusion
Behavioral Problems in Dementia | Moderate for risperidone, olanzapine, and quetiapine; low for aripipipazole. | - A recent meta-analysis of 15 placebo-controlled trials found a small but statistically significant benefit for risperidone and aripiprazole on agitation and psychosis outcomes.; - Evidence from this meta-analysis shows a trend toward effectiveness of olanzapine for psychosis; results did not reach statistical significance. The authors found three studies of quetiapine; they were too dissimilar in their design and outcomes to pool.; - A large head-to-head placebo controlled trial (Clinical Antipsychotic Trials of Intervention Effectiveness – Alzheimer’s Disease; CATIE-AD) concluded there were no differences in time to discontinuation of medication between risperidone, olanzapine, quetiapine and placebo. Efficacy outcomes favored risperidone and olanzapine, and tolerability outcomes favored quetiapine and placebo.; - We found no studies of ziprasidone for agitation and behavioral disorders in elderly persons with dementia.
Specific Categories of Depression: a. Inadequate Response to SRI b. with psychotic features c. with bipolar disorder | Moderate that olanzapine whether used as monotherapy or to augment therapy does not improve outcomes at 8 weeks in SRI resistant depression; low for all atypical antipsychotics for other depression indications, due to small studies, inconsistent findings or lack of comparisons to usual treaments. | - For serotonin reuptake inhibitor (SRI)-resistant patients with major depressive disorder, combination therapy with an atypical antipsychotic plus an SRI antidepressant is not more effective than an SRI alone, at 8 weeks.; - In two trials enrolling patients with major depressive disorder with psychotic features, olanzapine and olanzapine plus fluoxentine were compared with placebo for 8 weeks. Neither trial indicated a benefit for olanzapine alone. In one trial, the combination group had significantly better outcomes than placebo or olanzapine alone, but the contribution of olanzapine cannot be determined as the trial lacked a fluoxetine-only comparison arm.; - For bipolar depression, olanzapine and quetiapine were superior to placebo in one study for each drug, but data are conflicting in two other studies which compared atypical antipsychotics to conventional therapy.; - We found no studies of aripiprazole for depression.
Obsessive-Compulsive Disorder | Moderate for risperidone and quetiapine; low for olanzapine due to sparse and inconsistent results. | - We identified 12 trials of risperidone, olanzapine, and quetiapine used as augmentation therapy in patients with OCD who were resistant to standard treatment.; - A moderate amount of evidence from nine trials shows that these drugs have a clinically important beneficial effect when used as augmentation therapy for patients who failed to adequately respond to SRI therapy.; - We found no trials of ziprasidone or aripiprazole for obsessive-compulsive disorder.
Post-traumatic Stress Disorder | Low for risperidone for combat-related PTSD due to sparse data; very low for risperidone and olanzapine for treating PTSD due to causes other than combat. | - We found four risperidone and two olanzapine trials of over six weeks for PTSD.; - There were 3 trials enrolling men with combat-related PTSD; these showed a benefit in sleep quality, depression, anxiety and overall symptoms when risperidone or olanzapine was used to augment therapy with antidepressants or other psychotropic medication.; - We found 3 trials of olanzapine or risperidone as monotherapy for women with PTSD; the evidence was inconclusive regarding efficacy.; - We found no studies of quetiapine, ziprasidone, or aripiprazole for PTSD.
Personality Disorders | Very low due to small effects, small size of studies, and limitations of trial quality. | - Four RCTs, each with no more than 60 subjects, provide evidence that olanzapine is more effective than placebo and may be more effective than fluoxetine in treating borderline personality disorder.; - The benefit of adding olanzapine to dialectical therapy for borderline personality disorder was small.; - Olanzapine caused significant weight gain in all studies.; - Risperidone was more effective than placebo for the treatment of schizotypal personality disorder in one small 9- week trial.; - Aripiprazole was more effective than placebo for the treatment of borderline personality in one small 8-week trial.
Tourette’s Syndrome in Children/Adolescents | Low for risperidone; very low for ziprasidone. | - We found four trials of risperidone and one of ziprasidone for this condition.; - The little evidence available is inconclusive about the efficacy of either drug.; - We found no studies of aripiprazole, quetiapine, or olanzapine for Tourette’s symptoms.
Autism in Children/Adolescents | Low for risperidone due to sparse data. | - Just before this report was published, the FDA approved risperidone for use in autism; - Two trials of eight weeks duration support the superiority of risperidone over placebo in improving serious behavioral problems in children with autism.; - We found no trials of olanzapine, quetiapine, ziprasidone or aripiprazole for autism.

Table 12

Summary of adverse event and safety findings for which there is moderate or strong evidence

Side effect | Head to head trials | Active control trials | Placebo controlled trials
Mortality (dementia patients only) | Insufficient evidence of difference. | Insufficient evidence of difference. | Small but significant increased risk for atypical antipsychotics compared to placebo.
Cardiovascular (not including cerebrovascular accident) | Insufficient evidence of difference. | Insufficient evidence of difference. | Insufficient evidence of difference.
Cerebrovascular accident (dementia patients only) | Insufficient evidence of difference. | Insufficient evidence of difference. | Small but significant increased risk for risperidone and olanzapine compared to placebo.
Extrapyramidal symptoms | More common in olanzapine and risperidone than in quetiapine. | Insufficient evidence of difference. | More common in risperidone, olanzapine, aripiprazole, and ziprasidone than placebo, quetiapine insufficiently studied.
Neurological (fatigue, headaches, dizziness; excludes movement disorders) | Insufficient evidence of difference. | Insufficient evidence of difference. | More common in risperidone, olanzapine and aripiprazole than placebo, other drugs insufficiently studied.
Sedation | Insufficient evidence of difference | More common in olanzapine than mood stabilizers. | More common in atypical antipsychotics than placebo.
Weight gain | More common in olanzapine than other atypical antipsychotics. | More common in olanzapine than conventional antipsychotics. | More common in olanzapine and risperidone than placebo, other drugs insufficiently studied.