# Methods

## Topic Development

The Agency for Healthcare Research and Quality (AHRQ) originally assigned this topic to us based on a nomination by the Department of Labor and Department of Corrections in the state of Washington. Later, we were asked by AHRQ to develop this as a comparative effectiveness report. Such reviews are being conducted by the Evidence-based Practice Centers (EPCs) for the AHRQ Effective Health Care program. These reviews are one aspect of the program, developed in response to Section 1013 of the Medical Modernization Act (MMA), which called for AHRQ to conduct a range of activities pertinent to evaluating, generating, and disseminating evidence about the comparative effectiveness of medications, devices, and other interventions. The evidence report focuses on the atypical antipsychotics (risperidone, olanzapine, quetiapine, aripiprazole, and ziprasidone) as used for the following psychiatric conditions: dementia/severe geriatric agitation, depression, obsessive-compulsive disorder (OCD), personality disorders, and post-traumatic stress disorder (PTSD). We were asked to review use in children/adolescents for autism and Tourette’s syndrome if time and resources permitted.

## Search Strategy

Our library searches began in December, 2004, with a search of the Cochrane Database of Reviews of Effectiveness (DARE) and Pubmed. In early January, 2005, we followed with a search of PsycInfo and the Cochrane Central Register of Controlled Trials (CENTRAL). Search strategies are available in Appendix A.

AHRQ is dedicated to identifying as many studies as possible that are relevant to the questions for each of its systematic reviews. In order to do so, we supplemented the usual electronic database and hand searches of the literature by systematically requesting information (e.g., details of studies conducted) from pharmaceutical industry stakeholders. The Effective Health Care Program Scientific Resource Center at Oregon Health & Science University requested unpublished data from the five manufacturers of atypical antipsychotics.

In addition, several recent evidence reports related to our research subject were identified. In April, 2004, the EPC at McMaster University completed an evidence report on pharmacological treatment of dementia. We examined the references of the report and ordered any articles that we had not already identified. In December, 2004, the EPC at Oregon Health & Science University completed a drug class review on atypical antipsychotics. Although that report focused on FDA-approved uses (treatment of schizophrenia and bipolar disorder), it contained a chapter on behavioral and psychological symptoms of dementia. We reviewed this chapter and ordered any relevant studies that our literature search had not captured.

## Technical Expert Panel

This evidence report was guided by a Technical Expert Panel (TEP). We invited a distinguished group of scientists and clinicians to participate in the TEP for this report. We aimed to have at least one expert on each psychiatric condition on our TEP. TEP conference calls were held in April and May 2005.

The TEP indicated that trials less than six weeks in length should be excluded from the efficacy analyses as six weeks is an insufficient time to assess outcomes. The TEP was instrumental in deciding appropriate outcome measures for specific psychiatric conditions and identifying recently published or ongoing clinical trials. The TEP reviewed the draft evidence report and provided critical feedback.

## Study Selection

Two trained researchers reviewed the list of titles and selected articles to obtain. Each article retrieved was reviewed with a brief screening form (see Appendix B) that collected data on medication, psychiatric condition, study design, population, sample size, and study duration. Again, to be included in our evidence report, the study had to involve aripiprazole, olanzapine, quetiapine, risperidone, or ziprasidone for any of the following psychiatric conditions: dementia, severe geriatric agitation, depression, obsessive-compulsive disorder (OCD), personality disorders, posttraumatic stress disorder (PTSD), autism, or Tourette’s syndrome. Only studies on humans were included. Our efficacy analyses included only controlled trials of at least 6 weeks duration. Our adverse events analyses included controlled trials of any duration and case series or cohort studies with a comparison group of more than 1,000 subjects. (We found no case control studies.) Observational studies of this size were included because they may provide evidence about the possible existence of rare adverse events that are not normally well assessed in clinical trials of more modest size.

## Data Abstraction

Data were independently abstracted by a physician and a psychiatrist trained in the critical assessment of evidence. The following data were abstracted from included trials: trial name, setting, population characteristics (including sex, age, ethnicity, and diagnosis), eligibility and exclusion criteria, interventions (dose, frequency, and duration), any co-interventions, other allowed medication, comparisons, and results for each outcome. We recorded intent-to-treat results if available. Data abstraction forms are provided in Appendix B.

For efficacy outcomes, a statistician extracted data. Efficacy outcomes abstracted are listed by condition in Table 1 below. Based on important outcomes listed by the TEP, a psychiatrist chose which outcomes were most appropriate to pool. Poolability across studies was also important; the more trials that reported an outcome measure, the more likely we were to use it in our analysis. For each treatment or placebo arm within a trial, the sample size, mean outcome, and standard deviation were extracted. If a study did not report a follow-up mean or if a follow-up mean could not be calculated from the given data, the study was excluded from analysis. For those trials that did not report a follow-up standard deviation, we imputed one by assigning the average standard deviation from other trials that reported the standard deviation for the same outcome. If fewer than two trials were available with standard deviations, then we imputed the follow-up standard deviation by taking one-fourth the theoretical range of the scale.

Table 1

Efficacy outcomes abstracted

Conditions | Outcome Measures
Autism | Aberrant Behavior Checklist – ABC Childhood Autism Rating Scale
Dementia-agitation | Agitation-Calmness Evaluation Scale - ACES Behavioral Pathology in Alzheimer’s Disease Rating Scale - BEHAVE-AD (subscale: aggressiveness) Cohen-Mansfield Agitation Inventory - CMAI Neuropsychiatric Inventory, Nursing Home - NPI-NH (subscale: agitation) Neuropsychiatric Inventory - NPI (subscale: agitation) Positive and Negative Symptom Scale - PANSS (subscale: excitement)
Dementia-cognition | Mini Mental Status Exam - MMSE Alzheimer’s Disease Assessment Scale - ADAS (cognition scale)
Dementia-global | Neuropsychiatric Inventory, Nursing Home - NPI-NH (total) Neuropsychiatric Inventory - NPI (total) Clinician’s Interview-Based Impression of Change - CIBIC Empirical Behavioral Pathology in Alzheimer’s Disease Rating Scale - E-BEHAVE-AD (total) Behavioral Pathology in Alzheimer’s Disease Rating Scale - BEHAVE-AD (total)
Dementia-improvement | Clinical Global Impression Scale - CGI:I (improvement subscale)
Dementia-psychosis | Neuropsychiatric Inventory, Nursing Home - NPI-NH (subscale: psychosis) Positive and Negative Symptom Scale - PANSS (subscale: psychosis) Behavioral Pathology in Alzheimer’s Disease Rating Scale BEHAVE-AD (sum of paranoid and delusional ideation and hallucinations items) Brief Psychiatric Rating Scale - BPRS (subscale: psychosis) - it is the sum of unusual thought content, paranoia(or suspiciousness), hallucinations (or hallucinatory behavior), disorganized thinking (or conceptual disorganization)
Dementia-severity | Clinical Global Impression Scale - CGI:S (severity subscale)
Depression | Hamilton Depression Scale - HAM_D (HDRS) Montgomery - Asberg Depression Rating Scale - MADRS Bech-Rafaelson Melancholia Scale - BRMES Depression cluster - PDC Center for Epidemiologic Studies Depression Scale - CES-D Brief Symptom Inventory - BSI
Depression-improvement | Clinical Global Impression Scale - CGI:I (improvement subscale)
OCD | Yale - Brown Obsessive Compulsive Scale - YBOCS
OCD-severity | Clinical Global Impression Scale - CGI:S (severity subscale)
PTSD | Clinician Administered PTSD Scale - CAPS
PTSD-depression | Center for Epidemiologic Studies Depression Scale - CES-D Hamilton Depression Scale - HAM-D Beck Depression Inventory - BDI
Tourette’s Syndrome | Tic Symptom Self Report – TSSR Yale Global Tic Severity Scale - YGTSS

## Adverse Events

Adverse events were recorded onto a spreadsheet that identified each trial group, the description of the adverse event from the original article, the number of subjects in each group, and the number of subjects affected. Each event was counted as if it represented a unique individual. Because a single individual might have experienced more than one event, this assumption may have overestimated the number of people having an adverse event.

If a trial mentioned a particular type of adverse event in the discussion but did not report data on that adverse event, we did not include that trial in that particular event’s analysis. In other words, we did not assume an adverse event occurred unless the trial report specifically stated that some number of events were observed. By taking this approach, we may have overestimated the number of patients for whom a particular adverse event was observed. Taking the opposite tack, namely assuming a particular adverse event did not occur in any study if it was not mentioned, certainly underestimates the number of patients for whom a particular adverse event occurred.

After abstracting the data, we identified mutually exclusive groups of similar events, based on clinical expertise. For example, events that affected the head, ear, eye, nose, or throat were grouped together as HEENT. A group could contain subgroups; for example, decreased salivation, increased salivation, and eye irritation are subgroups of HEENT, with their own analyses. For each adverse-event subgroup, we report the number of trials that provided data for any event in the subgroup. We also report the total number of individuals in the medication groups in the relevant trials who were observed to have experienced the event and the total number of patients in the medication groups in those trials. We then report the analogous counts for the control groups in the relevant trials.

## Quality Assessment

To assess internal validity, we abstracted data on the adequacy of the randomization method; the adequacy of allocation concealment; maintenance of blinding; similarity of compared groups at baseline and the author’s explanation of the effect of any between-group differences in important confounders or prognostic characteristics; specification of eligibility criteria; maintenance of comparable groups (i.e., reporting of dropouts, attrition, crossover, adherence, and contamination); the overall proportion of subjects lost to follow-up and important differences between treatments; use of intent-to-treat analysis; post-randomization exclusions, and source of funding. We defined loss to follow-up as the number of patients excluded from efficacy analyses, expressed as a proportion of the number of patients randomized.

To assess external validity, we recorded the number screened, eligible, and enrolled; the use of run-in and washout periods or highly selective criteria; the use of standard care in the control group; and overall relevance. Funding source was also abstracted.

To arrive at a quantitative measure, we used the Jadad scale, which was developed for drug trials. This method measures quality on a scale that ranges from 0–5, assigning points for randomization, blinding, and accounting for withdrawals and dropouts.5 Across a broad array of meta-analyses, an evaluation found that trials scoring 0–2 report exaggerated results compared with trials scoring 3–5.^6^ The latter have been called “good” quality and the former called “poor” quality.

## Applicability

Effectiveness studies compare a new drug with viable alternatives rather than with placebo; they produce health, quality of life, and economic outcomes data under real world conditions. For example, an effectiveness trial of a new asthma drug would include asthma-related emergency room visits, the frequency and costs of physician visits, patients’ quality of life, patient compliance with the medications, acquisition costs of the medications, and frequency and costs of short-term and long-term adverse events.

Clinicians and policymakers often distinguish between the [underlined: efficacy] of an intervention (the extent to which the treatment works under ideal circumstances) and the [underlined: effectiveness] of the intervention (the extent to which the treatment works on average patients in average settings). Efficacy studies tend to be smaller, to be performed on referred patients and in specialty settings, and to exclude patients with comorbidities. Effectiveness studies are larger and more generalizable to practice. Please be aware that the vast majority of studies included in our report are efficacy studies. However, effectiveness studies are included in our analyses of adverse events.

## Rating the Body of Evidence

We assessed the overall quality of evidence for outcomes using a method developed by the Grade Working Group, which classified the grade of evidence across outcomes according to the following criteria:7

- ○ High = Further research is very unlikely to change our confidence on the estimate of effect.
- ○ Moderate = Further research is likely to have an important impact on our confidence in the estimate of effect and may change the estimate.
- ○ Low = Further research is very likely to have an important impact on our confidence in the estimate of effect and is likely to change the estimate.
- ○ Very Low = Any estimate of effect is very uncertain.

GRADE also suggests using the following scheme for assigning the “grade” or strength of evidence:

Criteria for assigning grade of evidence
Type of evidence Randomised trial = high Observational study = low Any other evidence = very low
Decrease grade if:; - Serious (−1) or very serious (−2) limitation to study quality; - Important inconsistency (−1); - Some (−1) or major (−2) uncertainty about directness; - Imprecise or sparse data (−1); - High probability of reporting bias (−1)
Increase grade if:; - Strong evidence of association-significant relative risk of > 2 (< 0.5) based on consistent evidence from two or more observational studies, with no plausible confounders (+1); - Very strong evidence of association-significant relative risk of > 5 (< 0.2) based on direct evidence with no major threats to validity (+2); - Evidence of a dose response gradient (+1); - All plausible confounders would have reduced the effect (+1)

For this report, we used both this explicit scoring scheme and the global implicit judgment about “confidence” in the result. Where the two disagreed, we went with the lower of the two classifications.

## Data Synthesis

We constructed evidence tables displaying the study characteristics and results for all included studies (Appendix C). Trials that evaluated one atypical antipsychotic against another and provided direct evidence of comparative effectiveness are classified as “head-to-head” trials. “Active” controlled trials compare an atypical antipsychotic with another class of medication. Trials that compare atypical antipsychotics with a placebo are referred to as “Placebo” controlled trials. Finally, trials that compare an antipsychotic taken with another medication with the other medication alone were examined (referred to as augmentation trials). We provide four separate evidence tables, one for each type of study (head-to-head, active control, placebo control, and augmentation). We also include an evidence table of large case series and cohort studies identified for our adverse events analyses.

Our a priori analytic plan was to summarize the evidence for efficacy (versus placebo or versus conventional therapy) within condition (dementia, depression, personality disorders, etc.) and across class (all five atypical antipsychotics); the evidence of risks (adverse events) was summarized within drug (each atypical antipsychotic separately) across condition. This strategy has ample support in the literature, with many examples of drugs that demonstrate similar efficacy across a class of drugs and are then distinguished on the basis of their adverse events profile.

Because the topic nominator of this report was interested primarily in efficacy, our synthesis deals both with efficacy (do these drugs work?) and comparative effectiveness (are there differences between drugs?).

### Efficacy and Comparative Effectiveness

For the efficacy and comparative effectiveness analyses, we focused on controlled trials that reported outcomes with at least 6 weeks follow-up. Effect sizes were calculated for each comparison. If all trials within a condition and subgroup used the same scale, then the effect size did not need to be standardized and a mean difference was calculated. For subgroups where pooling was done across several scales, we calculated an unbiased estimate using the Hedges’ g effect size.8 Since most of the scales used as outcome measures in the pooled analyses are scored so that more severely symptomatic persons have higher scores, a negative effect size indicates that the atypical drug has a higher efficacy than does the comparison arm (active control or placebo arm). However, for OCD, our approach was to calculate a risk ratio for each trial based on the number of “responders” within the treatment and placebo arms, because the primary outcomes were reported this way in the original trials.

For trials that were judged sufficiently clinically similar to warrant meta-analysis, we estimated a pooled random-effects estimate9 of the overall mean difference in outcome measure. The individual trial mean differences are weighted by both within-study variation and between-study variation in this synthesis. We pooled the risk ratios using the same method as above for the OCD condition. We constructed forest plots in which each individual trial mean difference is shown as a box whose area is inversely proportional to the estimated variance of the mean difference in that trial. The trial’s confidence interval is shown as a horizontal line through the box. The pooled “weighted mean difference” and its confidence interval are shown as a diamond at the bottom of the plot with a dotted vertical line indicating the pooled estimate value. A vertical solid line at zero indicates no effect of medication. We also report the chi-squared test of heterogeneity p-value based on Cochran’s Q8 and the I-squared statistic.10 A significant Q statistic or I2 values close to 100 percent represent very high degrees of heterogeneity. I2 values of 25 percent, 50 percent, and 75 percent represent low, moderate, and high heterogeneity. The numbers of trials of atypical antipsychotics for depression, dementia, and OCD were sufficient for meta-analysis. For the pooled analysis of trials of OCD, the calculations were performed on the relative risk of “responding” to the drug, so the “no effect” line is at a relative risk of 1. We also calculated Number Needed to treat (NNT) where applicable.

We assessed publication bias for each condition that was pooled. Tests were conducted using the Begg11 adjusted rank correlation test and the Egger12 regression asymmetry test.

All meta-analyses were conducted with Stata statistical software, version 8.2 (Stata Corp., College Station, Texas).

For groups of trials not judged sufficiently clinically similar to support meta-analysis, we performed a narrative synthesis. Trials of atypical antipsychotic drugs for PTSD, personality disorders, Tourette’s syndrome, and autism were summarized narratively.

### Adverse Events

For reporting the data on adverse events, we treated each atypical antipsychotic separately and (in general) did not group them together as a class. However, we did summarize the findings of other systematic reviews and meta-analyses that treated these drugs as a class. For our own analyses, we divided the study populations into three groups to make them more clinically homogeneous with respect to adverse events: dementia (elderly subjects), autism and Tourette’s (children and adolescents), and everything else (adults).

For subgroups of events that occurred in two or more trials, we performed a meta-analysis to estimate the pooled odds ratio and its associated 95 percent confidence interval. Given that many of the events were rare, we used exact conditional inference to perform the pooling rather than applying the usual asymptotic methods that assume normality. Asymptotic methods require corrections if zero events are observed; generally, half an event is added to all cells in the outcome-by-treatment (two-by-two) table in order to allow estimation, because these methods are based on assuming continuity. Such corrections can have a major impact on the results when the outcome event is rare. Exact methods do not require such corrections. We conducted the meta-analyses using the statistical software package StatXact Procs v6.1 (Cytel Software, Cambridge, MA).

Any significant pooled odds ratio greater than one indicates the odds of the adverse event associated with the atypical antipsychotic is larger than the odds associated with the comparison (placebo, active control, or other antipsychotic) group. We calculated Number Needed to Harm (NNH) where this occurred. We note that if no events were observed in the comparison group, but events were observed in the intervention group, the odds ratio is infinity and the associated confidence interval is bounded only from below. In such a case, we report the lower bound of the confidence interval. If no events were observed in either group, the odds ratio is undefined, which we denote as “Not calculated (NC)” in the results tables.

## Peer Review

We requested review of the draft report from our Technical Expert Panel and various additional content and methods experts. In addition, review was performed by the Effective Health Care Program Scientific Resource Center (SRC) located at Oregon Health & Science University and by pharmaceutical companies. More than 100 articles, abstracts, and reports were submitted by these reviewers for consideration. A blinded list of peer reviewer comments and author responses has been provided to the SRC.