# Adverse Event Analysis

Table A

Dementia studies – Atypical Antipsychotics Compared to Placebo

Adverse Events | Drug | # of studies | Placebo | | Intervention Groups | | Pooled OR | 95% CI | NNH1 | 95% CI NNH
Adverse Events | Drug | # of studies | # adverse events | sample size | # adverse events | sample size | Pooled OR | 95% CI | NNH1 | 95% CI NNH
Anticholinergic Events | Olanzapine | 1 | 12 | 90 | 60 | 178 | 3.29 | (1.62, 7.17) | 5.00 | (3.00, 10.00)
Appetite or Weight/Decrease | Aripiprazol | 1 | 13 | 121 | 23 | 122 | 1.93 | (0.88, 4.38) | NC | NC
Appetite or Weight/Decrease | Olanzapine | 2 | 15 | 141 | 32 | 363 | 0.75 | (0.38, 1.56) | NC | NC
Appetite or Weight/Decrease | Risperidone | 1 | 8 | 94 | 11 | 196 | 0.64 | (0.23, 1.90) | NC | NC
Appetite or Weight/Increase | Aripiprazol | 1 | 3 | 102 | 5 | 106 | 1.63 | (0.31, 10.78) | NC | NC
Appetite or Weight/Increase | Olanzapine | 2 | 2 | 184 | 24 | 382 | 6.12 | (1.49, 54.04) | 19.00 | (12.00, 43.00)
Appetite or Weight/Increase | Risperidone | 1 | 1 | 94 | 6 | 196 | 2.93 | (0.35, 136.52) | NC | NC
Cardiovascular | Aripiprazol | 1 | 10 | 121 | 32 | 122 | 4.22 | (1.84, 10.63) | 6.00 | (4.00, 11.00)
Cardiovascular | Olanzapine | 4 | 5 | 298 | 38 | 678 | 3.31 | (1.27, 10.91) | 25.00 | (16.00, 60.00)
Cardiovascular | Risperidone | 4 | 27 | 665 | 110 | 1060 | 2.33 | (1.48, 3.78) | 16.00 | (12.00, 25.00)
Cardiovascular/BP/Decrease | Aripiprazol | 1 | 6 | 125 | 4 | 131 | 0.63 | (0.13, 2.71) | NC | NC
Cardiovascular/BP/Increase | Aripiprazol | 1 | 5 | 102 | 4 | 106 | 0.76 | (0.15, 3.65) | NC | NC
Cardiovascular/BP/Increase | Olanzapine | 1 | 1 | 67 | 2 | 137 | 0.98 | (0.05, 58.55) | NC | NC
Cardiovascular/Rhythm | Aripiprazol | 1 | 1 | 102 | 2 | 106 | 1.94 | (0.10, 115.71) | NC | NC
Cardiovascular/Rhythm | Olanzapine | 1 | 2 | 67 | 3 | 137 | 0.73 | (0.08, 8.92) | NC | NC
Cardiovascular/Rhythm | Risperidone | 1 | 6 | 19 | 7 | 20 | 1.16 | (0.25, 5.49) | NC | NC
Constitutional/Fever or Infection | Olanzapine | 3 | 5 | 231 | 38 | 541 | 3.23 | (1.23, 10.71) | 21.00 | (13.00, 50.00)
Constitutional/Fever or Infection | Risperidone | 3 | 19 | 427 | 59 | 825 | 1.41 | (0.80, 2.57) | NC | NC
Dermatologic | Aripiprazol | 2 | 52 | 246 | 96 | 253 | 2.35 | (1.54, 3.62) | 6.00 | (4.00, 11.00)
Dermatologic | Olanzapine | 1 | 7 | 47 | 19 | 159 | 0.78 | (0.29, 2.35) | NC | NC
Dermatologic | Risperidone | 2 | 82 | 333 | 133 | 629 | 1.24 | (0.87, 1.79) | NC | NC
Endocrine/Diabetes | Risperidone | 1 | 5 | 238 | 4 | 235 | 0.81 | (0.16, 3.80) | NC | NC
Endocrine/Prolactin | Risperidone | 1 | 0 | 238 | 0 | 235 | NC | NC | NC | NC
Gastrointestinal | Aripiprazol | 2 | 18 | 246 | 45 | 253 | 2.72 | (1.48, 5.18) | 10.00 | (6.00, 21.00)
Gastrointestinal | Olanzapine | 1 | 6 | 90 | 24 | 178 | 2.18 | (0.82, 6.77) | NC | NC
Gastrointestinal | Risperidone | 1 | 61 | 170 | 38 | 167 | 0.53 | (0.32, 0.87) | −8.00 | (−28.00, −4.00)
HEENT | Olanzapine | 1 | 3 | 47 | 16 | 159 | 1.64 | (0.44, 9.17) | NC | NC
HEENT | Risperidone | 2 | 27 | 333 | 80 | 629 | 1.27 | (0.78, 2.12) | NC | NC
HEENT/Eye | Risperidone | 1 | 18 | 170 | 20 | 167 | 1.15 | (0.55, 2.40) | NC | NC
Heme | Risperidone | 1 | 12 | 238 | 8 | 235 | 0.66 | (0.23, 1.81) | NC | NC
Infections | Olanzapine | 1 | 5 | 90 | 10 | 178 | 1.01 | (0.30, 3.90) | NC | NC
Infections | Risperidone | 2 | 33 | 333 | 54 | 629 | 1.05 | (0.64, 1.75) | NC | NC
Liver Function Test Abnormality | Aripiprazol | 1 | 1 | 102 | 0 | 106 | 0.00 | (0.00, 37.53) | NC | NC
Musculoskeletal | Olanzapine | 1 | 3 | 90 | 0 | 178 | 0.00 | (0.00, 1.21) | NC | NC
Neuro | Olanzapine | 3 | 35 | 326 | 95 | 482 | 2.23 | (1.43, 3.55) | 11.00 | (7.00, 24.00)
Neuro | Quetiapine | 1 | 16 | 142 | 13 | 94 | 1.26 | (0.53, 2.97) | NC | NC
Neuro | Risperidone | 2 | 26 | 236 | 44 | 281 | 1.50 | (0.85, 2.70) | NC | NC
Neuro/CVA | Aripiprazol | 1 | 1 | 102 | 1 | 106 | 0.96 | (0.01, 76.25) | NC | NC
Neuro/CVA | Olanzapine | 2 | 2 | 232 | 5 | 278 | 2.09 | (0.32, 23.27) | NC | NC
Neuro/CVA | Quetiapine | 1 | 1 | 142 | 1 | 94 | 1.51 | (0.02, 119.85) | NC | NC
Neuro/CVA | Risperidone | 3 | 6 | 550 | 21 | 487 | 3.88 | (1.49, 11.91) | 31.00 | (19.00, 82.00)
Neuro/Fatigue | Aripiprazol | 2 | 14 | 246 | 41 | 253 | 3.67 | (1.83, 7.90) | 10.00 | (6.00, 19.00)
Neuro/Fatigue | Olanzapine | 3 | 9 | 326 | 36 | 482 | 2.37 | (1.08, 5.75) | 21.00 | (13.00, 57.00)
Neuro/Fatigue | Quetiapine | 1 | 2 | 142 | 4 | 94 | 3.10 | (0.43, 34.89) | NC | NC
Neuro/Fatigue | Risperidone | 2 | 4 | 236 | 20 | 281 | 3.56 | (1.13, 14.96) | 18.00 | (11.00, 50.00)
Neuro/Headache | Olanzapine | 2 | 2 | 209 | 9 | 237 | 4.86 | (0.95, 48.01) | NC | NC
Neuro/Headache | Quetiapine | 1 | 2 | 142 | 1 | 94 | 0.75 | (0.01, 14.67) | NC | NC
Neuro/Headache | Risperidone | 2 | 13 | 312 | 13 | 252 | 1.17 | (0.49, 2.81) | NC | NC
Neuro/Movement Disorder/EPS | Aripiprazol | 3 | 16 | 348 | 39 | 359 | 2.53 | (1.34, 5.01) | 16.00 | (10.00, 42.00)
Neuro/Movement Disorder/EPS | Olanzapine | 1 | 1 | 142 | 12 | 100 | 19.04 | (2.73, 827.61) | 9.00 | (6.00, 21.00)
Neuro/Movement Disorder/EPS | Quetiapine | 1 | 1 | 142 | 2 | 94 | 3.05 | (0.16, 182.09) | NC | NC
Neuro/Movement Disorder/EPS | Risperidone | 4 | 29 | 713 | 114 | 949 | 2.82 | (1.81, 4.51) | 13.00 | (10.00, 18.00)
Neuro/Movement Disorder/Gait | Olanzapine | 4 | 15 | 373 | 79 | 641 | 2.75 | (1.52, 5.29) | 12.00 | (9.00, 20.00)
Neuro/Movement Disorder/Gait | Quetiapine | 1 | 3 | 142 | 3 | 94 | 1.52 | (0.20, 11.63) | NC | NC
Neuro/Movement Disorder/Gait | Risperidone | 3 | 8 | 406 | 32 | 448 | 3.04 | (1.32, 7.84) | 19.00 | (13.00, 41.00)
Neuro/Movement Disorder/Tardive Dyskinesia | Olanzapine | 1 | 4 | 142 | 3 | 100 | 1.07 | (0.15, 6.46) | NC | NC
Neuro/Movement Disorder/Tardive Dyskinesia | Quetiapine | 1 | 4 | 142 | 2 | 94 | 0.75 | (0.07, 5.36) | NC | NC
Neuro/Movement Disorder/Tardive Dyskinesia | Risperidone | 3 | 14 | 475 | 4 | 714 | 0.31 | (0.07, 1.03) | NC | NC
Neuro/Pain | Aripiprazol | 1 | 7 | 121 | 32 | 122 | 5.52 | (2.25, 15.57) | 5.00 | (3.00, 9.00)
Neuro/Pain | Olanzapine | 2 | 10 | 137 | 36 | 337 | 1.31 | (0.60, 3.10) | NC | NC
Neuro/Pain | Risperidone | 1 | 13 | 163 | 33 | 462 | 0.89 | (0.44, 1.89) | NC | NC
Neuro/Sedation | Aripiprazol | 3 | 10 | 348 | 54 | 359 | 6.68 | (3.19, 15.72) | 8.00 | (6.00, 12.00)
Neuro/Sedation | Olanzapine | 5 | 24 | 440 | 152 | 778 | 4.26 | (2.66, 7.08) | 7.00 | (6.00, 9.00)
Neuro/Sedation | Quetiapine | 1 | 7 | 142 | 21 | 94 | 5.51 | (2.13, 16.08) | 6.00 | (4.00, 12.00)
Neuro/Sedation | Risperidone | 6 | 87 | 922 | 249 | 1260 | 2.50 | (1.89, 3.34) | 10.00 | (8.00, 13.00)
Psychiatric/Aggression | Olanzapine | 1 | 1 | 94 | 14 | 204 | 6.82 | (1.01, 292.81) | 17.00 | (10.00, 57.00)
Psychiatric/Aggression | Risperidone | 2 | 19 | 264 | 22 | 363 | 0.91 | (0.45, 1.85) | NC | NC
Psychiatric/Agitation | Aripiprazol | 1 | 19 | 121 | 37 | 122 | 2.24 | (1.16, 4.47) | 7.00 | (4.00, 24.00)
Psychiatric/Agitation | Olanzapine | 4 | 36 | 373 | 76 | 641 | 1.19 | (0.76, 1.90) | NC | NC
Psychiatric/Agitation | Quetiapine | 1 | 14 | 142 | 11 | 94 | 1.21 | (0.47, 3.03) | NC | NC
Psychiatric/Agitation | Risperidone | 5 | 102 | 807 | 120 | 1145 | 0.84 | (0.62, 1.14) | NC | NC
Psychiatric/Anxiety | Olanzapine | 4 | 19 | 373 | 40 | 641 | 1.04 | (0.57, 1.95) | NC | NC
Psychiatric/Anxiety | Quetiapine | 1 | 3 | 142 | 0 | 94 | 0.00 | (0.00, 3.65) | NC | NC
Psychiatric/Anxiety | Risperidone | 2 | 12 | 236 | 20 | 281 | 0.89 | (0.39, 2.12) | NC | NC
Psychiatric/Cognitive | Olanzapine | 2 | 3 | 232 | 15 | 278 | 4.00 | (1.08, 22.38) | 24.00 | (14.00, 93.00)
Psychiatric/Cognitive | Quetiapine | 1 | 1 | 142 | 0 | 94 | 0.00 | (0.00, 58.92) | NC | NC
Psychiatric/Cognitive | Risperidone | 1 | 1 | 142 | 1 | 85 | 1.67 | (0.02, 132.68) | NC | NC
Psychiatric/Depression | Olanzapine | 2 | 4 | 232 | 16 | 278 | 3.05 | (0.94, 13.04) | NC | NC
Psychiatric/Depression | Quetiapine | 1 | 2 | 142 | 2 | 94 | 1.52 | (0.11, 21.30) | NC | NC
Psychiatric/Depression | Risperidone | 1 | 2 | 142 | 0 | 85 | 0.00 | (0.00, 8.90) | NC | NC
Psychiatric/Psychotic | Olanzapine | 3 | 14 | 326 | 62 | 482 | 2.81 | (1.49, 5.64) | 12.00 | (8.00, 21.00)
Psychiatric/Psychotic | Quetiapine | 1 | 3 | 142 | 0 | 94 | 0.00 | (0.00, 3.65) | NC | NC
Psychiatric/Psychotic | Risperidone | 2 | 13 | 236 | 32 | 281 | 1.35 | (0.65, 2.96) | NC | NC
Psychiatric/Sleep | Olanzapine | 3 | 13 | 326 | 30 | 482 | 1.50 | (0.73, 3.26) | NC | NC
Psychiatric/Sleep | Quetiapine | 1 | 5 | 142 | 5 | 94 | 1.54 | (0.34, 6.88) | NC | NC
Psychiatric/Sleep | Risperidone | 3 | 24 | 474 | 28 | 516 | 1.03 | (0.56, 1.92) | NC | NC
Pulmonary | Aripiprazol | 1 | 3 | 102 | 6 | 106 | 1.97 | (0.41, 12.54) | NC | NC
Pulmonary | Olanzapine | 1 | 3 | 94 | 0 | 204 | 0.00 | (0.00, 1.10) | NC | NC
Pulmonary | Risperidone | 1 | 3 | 94 | 6 | 196 | 0.96 | (0.20, 6.05) | NC | NC
Severe | Risperidone | 2 | 36 | 333 | 97 | 629 | 1.49 | (0.96, 2.33) | NC | NC
Trauma | Aripiprazol | 3 | 61 | 348 | 126 | 359 | 3.12 | (2.09, 4.72) | 6.00 | (4.00, 9.00)
Trauma | Olanzapine | 5 | 50 | 440 | 114 | 778 | 1.31 | (0.89, 1.96) | NC | NC
Trauma | Quetiapine | 1 | 21 | 142 | 7 | 94 | 0.46 | (0.16, 1.20) | NC | NC
Trauma | Risperidone | 5 | 289 | 807 | 403 | 1145 | 0.79 | (0.63, 0.99) | -163.0 | (27.00, -20.00)
Urinary | Aripiprazol | 3 | 45 | 348 | 115 | 359 | 4.07 | (2.61, 6.44) | 5.00 | (4.00, 8.00)
Urinary | Olanzapine | 1 | 1 | 94 | 19 | 204 | 9.51 | (1.47, 401.07) | 12.00 | (8.00, 27.00)
Urinary | Risperidone | 4 | 71 | 665 | 164 | 1060 | 1.55 | (1.13, 2.13) | 21.00 | (13.00, 63.00)

NC = Not Calculated

Table B

Dementia studies – Atypical Antipsychotics Compared to Acetylcholinesterase inhibitors

Adverse Events | Drug | # of studies | Acetylcholinesterase inhibitors | | Intervention Groups | | Pooled OR | 95% CI
Adverse Events | Drug | # of studies | # adverse events | sample size | # adverse events | sample size | Pooled OR | 95% CI
Appetite or Weight/Decrease | Risperidone | 1 | 0 | 14 | 0 | 13 | NC | NC
Gastrointestinal | Risperidone | 1 | 10 | 14 | 2 | 13 | 0.10 | (0.01, 0.78)
Neuro/Fatigue | Risperidone | 1 | 2 | 14 | 1 | 13 | 1.09 | (0.01, 92.68)
Neuro/Movement Disorder/EPS | Risperidone | 1 | 0 | 14 | 2 | 13 | +Inf | (0.03, Inf+ )
Neuro/Sedation | Risperidone | 1 | 0 | 14 | 4 | 13 | +Inf | (0.88, Inf+ )
Psychiatric/Agitation | Risperidone | 1 | 1 | 14 | 1 | 13 | +Inf | (0.03, Inf+ )

NC = Not Calculated

Table C

Dementia studies – Atypical Antipsychotics Compared to Benzodiazepines

Adverse Events | Drug | # of studies | Benzodiazepines | | Intervention Groups | | Pooled OR | 95% CI
Adverse Events | Drug | # of studies | # adverse events | sample size | # adverse events | sample size | Pooled OR | 95% CI
Cardiovascular | Olanzapine | 1 | 0 | 68 | 2 | 137 | +Inf | (0.09, Inf+ )
Cardiovascular/BP/Increase | Olanzapine | 1 | 2 | 68 | 2 | 137 | 0.49 | (0.03, 6.91)
Cardiovascular/Rhythm | Olanzapine | 1 | 0 | 68 | 3 | 137 | +Inf | (0.20, Inf+ )
Neuro/Headache | Olanzapine | 1 | 1 | 68 | 4 | 137 | 2.01 | (0.19, 100.69)
Neuro/Sedation | Olanzapine | 1 | 7 | 68 | 5 | 137 | 0.33 | (0.08, 1.27)
Trauma | Olanzapine | 1 | 3 | 68 | 3 | 137 | 0.49 | (0.06, 3.74)

NC = Not Calculated

Table D

Dementia studies – Atypical Antipsychotics Compared to Conventional Antipsychotics

Adverse Events | Drug | # of studies | Conventionals | | Intervention Groups | | Pooled OR | 95% CI
Adverse Events | Drug | # of studies | # adverse events | sample size | # adverse events | sample size | Pooled OR | 95% CI
Appetite or Weight/Increase | Olanzapine | 1 | 0 | 20 | 6 | 20 | +Inf | (1.48, Inf+ )
Appetite or Weight/Increase | Risperidone | 1 | 0 | 20 | 0 | 20 | NC | NC
Cardiovascular/BP/Decrease | Olanzapine | 1 | 7 | 20 | 2 | 20 | 0.11 | (0.00, 1.01)
Cardiovascular/BP/Decrease | Risperidone | 1 | 7 | 20 | 4 | 20 | 0.47 | (0.08, 2.36)
Cardiovascular/Rhythm | Olanzapine | 1 | 5 | 20 | 0 | 20 | 0.00 | (0.00, 0.98)
Cardiovascular/Rhythm | Risperidone | 1 | 5 | 20 | 2 | 20 | 0.17 | (0.00, 1.80)
Endocrine/Diabetes | Olanzapine | 1 | 0 | 20 | 1 | 20 | +Inf | (0.03, Inf+ )
Endocrine/Diabetes | Risperidone | 1 | 0 | 20 | 0 | 20 | NC | NC
Gastrointestinal | Olanzapine | 1 | 8 | 20 | 3 | 20 | 0.29 | (0.04, 1.55)
Gastrointestinal | Risperidone | 2 | 10 | 49 | 6 | 49 | 0.43 | (0.10, 1.65)
HEENT/Decreased Salivation | Olanzapine | 1 | 6 | 20 | 0 | 20 | 0.00 | (0.00, 0.72)
HEENT/Decreased Salivation | Risperidone | 1 | 6 | 20 | 0 | 20 | 0.00 | (0.00, 0.72)
Neuro | Olanzapine | 1 | 3 | 20 | 3 | 20 | 1.06 | (0.12, 9.13)
Neuro | Risperidone | 1 | 3 | 20 | 0 | 20 | 0.00 | (0.00, 2.34)
Neuro/CVA | Olanzapine | 2 | 116 | 5478 | 97 | 5347 | 1.11 | (0.83, 1.49)
Neuro/CVA | Quetiapine | 2 | 116 | 5478 | 44 | 2057 | 1.11 | (0.76, 1.59)
Neuro/CVA | Risperidone | 2 | 116 | 5478 | 229 | 9676 | 1.35 | (1.07, 1.71)
Neuro/Fatigue | Olanzapine | 1 | 0 | 20 | 0 | 20 | NC | NC
Neuro/Fatigue | Risperidone | 1 | 0 | 20 | 2 | 20 | +Inf | (0.03, Inf+ )
Neuro/Movement Disorder/Akathisia | Olanzapine | 1 | 0 | 20 | 1 | 20 | NC | NC
Neuro/Movement Disorder/Akathisia | Risperidone | 1 | 0 | 20 | 0 | 20 | NC | NC
Neuro/Movement Disorder/EPS | Olanzapine | 1 | 4 | 20 | 0 | 20 | 0.00 | (0.00, 1.42)
Neuro/Movement Disorder/EPS | Risperidone | 1 | 4 | 20 | 2 | 20 | 0.23 | (0.00, 2.65)
Neuro/Sedation | Olanzapine | 1 | 2 | 20 | 6 | 20 | 4.01 | (0.59, 46.77)
Neuro/Sedation | Risperidone | 3 | 25 | 163 | 18 | 164 | 0.68 | (0.33, 1.36)
Psychiatric/Sexual | Olanzapine | 1 | 0 | 20 | 0 | 20 | NC | NC
Psychiatric/Sexual | Risperidone | 1 | 0 | 20 | 1 | 20 | NC | NC
Psychiatric/Sleep | Olanzapine | 1 | 0 | 20 | 0 | 20 | NC | NC
Psychiatric/Sleep | Risperidone | 1 | 0 | 20 | 1 | 20 | NC | NC
Urinary | Risperidone | 1 | 0 | 29 | 1 | 29 | +Inf | (0.03, Inf+ )

NC = Not Calculated

Table E

Dementia studies – Atypical Antipsychotic Compared to Another Atypical Antipsychotic

Adverse Events | Atypical antipsychotic 1 | Atypical antipsychotic 2 | # of studies | Atypical antipsychotic 1 | | Atypical antipsychotic 2 | | Pooled OR | 95% CI
Adverse Events | Atypical antipsychotic 1 | Atypical antipsychotic 2 | # of studies | # adverse events | sample size | # adverse events | sample size | Pooled OR | 95% CI
Cardiovascular/Rhythm | Risperidone | Olanzapine | 1 | 0 | 19 | 1 | 20 | +Inf | (0.02, Inf+ )
Gastrointestinal | Risperidone | Olanzapine | 1 | 1 | 20 | 0 | 20 | NC | NC
Neuro | Quetiapine | Olanzapine | 1 | 13 | 94 | 27 | 100 | 2.30 | (1.34, 4.04)
Neuro | Risperidone | Olanzapine | 1 | 13 | 85 | 27 | 100 | 2.04 | (0.93, 4.67)
Neuro | Risperidone | Quetiapine | 1 | 13 | 85 | 13 | 94 | 0.89 | (0.35, 2.23)
Neuro/CVA | Quetiapine | Olanzapine | 4 | 55 | 3877 | 105 | 14273 | 0.84 | (0.66, 1.08)
Neuro/CVA | Risperidone | Olanzapine | 3 | 60 | 11906 | 36 | 11854 | 0.71 | (0.46, 1.10)
Neuro/CVA | Risperidone | Quetiapine | 4 | 253 | 17445 | 55 | 3877 | 0.92 | (0.67, 1.25)
Neuro/Fatigue | Quetiapine | Olanzapine | 1 | 4 | 94 | 3 | 100 | 0.70 | (0.20, 2.34)
Neuro/Fatigue | Risperidone | Olanzapine | 1 | 3 | 85 | 3 | 100 | 0.85 | (0.11, 6.49)
Neuro/Fatigue | Risperidone | Quetiapine | 1 | 3 | 85 | 4 | 94 | 1.21 | (0.20, 8.53)
Neuro/Headache | Quetiapine | Olanzapine | 1 | 1 | 94 | 5 | 100 | 4.88 | (1.02, 46.38)
Neuro/Headache | Risperidone | Olanzapine | 1 | 5 | 85 | 5 | 100 | 0.84 | (0.19, 3.80)
Neuro/Headache | Risperidone | Quetiapine | 1 | 5 | 85 | 1 | 94 | 0.17 | (0.00, 1.60)
Neuro/Movement Disorder/EPS | Quetiapine | Olanzapine | 1 | 2 | 94 | 12 | 100 | 6.25 | (2.09, 25.27)
Neuro/Movement Disorder/EPS | Risperidone | Olanzapine | 1 | 10 | 85 | 12 | 100 | 1.02 | (0.38, 2.81)
Neuro/Movement Disorder/EPS | Risperidone | Quetiapine | 1 | 10 | 85 | 2 | 94 | 0.16 | (0.02, 0.81)
Neuro/Movement Disorder/Gait | Quetiapine | Olanzapine | 1 | 3 | 94 | 4 | 100 | 1.26 | (0.38, 4.51)
Neuro/Movement Disorder/Gait | Risperidone | Olanzapine | 1 | 1 | 85 | 4 | 100 | 3.48 | (0.34, 174.38)
Neuro/Movement Disorder/Gait | Risperidone | Quetiapine | 1 | 1 | 85 | 3 | 94 | 2.75 | (0.22, 147.08)
Neuro/Movement Disorder/Tardive Dyskinesia | Quetiapine | Olanzapine | 1 | 2 | 94 | 3 | 100 | 1.42 | (0.33, 6.96)
Neuro/Movement Disorder/Tardive Dyskinesia | Risperidone | Olanzapine | 1 | 3 | 85 | 3 | 100 | 0.85 | (0.11, 6.49)
Neuro/Movement Disorder/Tardive Dyskinesia | Risperidone | Quetiapine | 1 | 3 | 85 | 2 | 94 | 0.60 | (0.05, 5.34)
Neuro/Sedation | Quetiapine | Olanzapine | 1 | 21 | 94 | 24 | 100 | 1.10 | (0.67, 1.81)
Neuro/Sedation | Risperidone | Olanzapine | 3 | 52 | 352 | 77 | 388 | 1.47 | (0.98, 2.22)
Neuro/Sedation | Risperidone | Quetiapine | 1 | 13 | 85 | 21 | 94 | 1.59 | (0.70, 3.74)
Psychiatric/Agitation | Quetiapine | Olanzapine | 1 | 11 | 94 | 7 | 100 | 0.57 | (0.26, 1.21)
Psychiatric/Agitation | Risperidone | Olanzapine | 1 | 5 | 85 | 7 | 100 | 1.20 | (0.31, 5.00)
Psychiatric/Agitation | Risperidone | Quetiapine | 1 | 5 | 85 | 11 | 94 | 2.11 | (0.64, 8.11)
Psychiatric/Anxiety | Quetiapine | Olanzapine | 1 | 0 | 94 | 3 | 100 | +Inf | (1.12, Inf+ )
Psychiatric/Anxiety | Risperidone | Olanzapine | 1 | 0 | 85 | 3 | 100 | +Inf | (0.35, Inf+ )
Psychiatric/Anxiety | Risperidone | Quetiapine | 1 | 0 | 85 | 0 | 94 | NC | NC
Psychiatric/Cognitive | Quetiapine | Olanzapine | 1 | 0 | 94 | 5 | 100 | +Inf | (2.17, Inf+ )
Psychiatric/Cognitive | Risperidone | Olanzapine | 1 | 1 | 85 | 5 | 100 | 4.39 | (0.48, 211.54)
Psychiatric/Cognitive | Risperidone | Quetiapine | 1 | 1 | 85 | 0 | 94 | 0.00 | (0.00, 35.27)
Psychiatric/Depression | Quetiapine | Olanzapine | 1 | 2 | 94 | 4 | 100 | 1.91 | (0.50, 8.83)
Psychiatric/Depression | Risperidone | Olanzapine | 1 | 0 | 85 | 4 | 100 | +Inf | (0.57, Inf+ )
Psychiatric/Depression | Risperidone | Quetiapine | 1 | 0 | 85 | 2 | 94 | +Inf | (0.17, Inf+ )
Psychiatric/Psychotic | Quetiapine | Olanzapine | 1 | 0 | 94 | 7 | 100 | +Inf | (3.28, Inf+ )
Psychiatric/Psychotic | Risperidone | Olanzapine | 1 | 0 | 85 | 7 | 100 | +Inf | (1.27, Inf+ )
Psychiatric/Psychotic | Risperidone | Quetiapine | 1 | 0 | 85 | 0 | 94 | NC | NC
Psychiatric/Sleep | Quetiapine | Olanzapine | 1 | 5 | 94 | 5 | 100 | 0.94 | (0.34, 2.57)
Psychiatric/Sleep | Risperidone | Olanzapine | 1 | 4 | 85 | 5 | 100 | 1.07 | (0.22, 5.56)
Psychiatric/Sleep | Risperidone | Quetiapine | 1 | 4 | 85 | 5 | 94 | 1.14 | (0.24, 5.93)
Trauma | Quetiapine | Olanzapine | 1 | 7 | 94 | 17 | 100 | 2.54 | (1.27, 5.32)
Trauma | Risperidone | Olanzapine | 1 | 10 | 85 | 17 | 100 | 1.53 | (0.62, 3.99)
Trauma | Risperidone | Quetiapine | 1 | 10 | 85 | 7 | 94 | 0.61 | (0.19, 1.86)

NC = Not Calculated

Table F

Dementia studies – Risperidone with Rivastigamine Compared to Rivastigamine

Adverse Events | # of studies | Rivastigamine | | Risperidone + Rivastigamine | | Pooled OR | 95% CI
Adverse Events | # of studies | # adverse events | sample size | # adverse events | sample size | Pooled OR | 95% CI
Appetite or Weight/Decrease | 1 | 0 | 14 | 14 | 63 | +Inf | (0.75, +Inf)
Gastrointestinal | 1 | 10 | 14 | 30 | 63 | 0.40 | (0.08, 1.60)
Neuro/Fatigue | 1 | 2 | 14 | 17 | 63 | 4.12 | (0.53, 189.40)
Neuro/Movement Disorder/EPS | 1 | 0 | 14 | 3 | 63 | +Inf | (0.04, +Inf)
Neuro/Sedation | 1 | 0 | 14 | 17 | 63 | +Inf | (1.09, +Inf)
Psychiatric/Agitation | 1 | 1 | 14 | 7 | 63 | +Inf | (0.30, +Inf)

NC = Not Calculated

Table G

Autism/Tourette’s studies – Atypical Antipsychotics Compared to Placebo

Adverse Events | Drug | # of studies | Placebo | | Intervention Groups | | Pooled OR | 95% CI
Adverse Events | Drug | # of studies | # adverse events | sample size | # adverse events | sample size | Pooled OR | 95% CI
Accidental Overdose | Risperidone | 1 | 1 | 39 | 1 | 40 | 0.97 | (0.01, 78.47)
Appetite or Weight/Decrease | Risperidone | 3 | 7 | 109 | 8 | 105 | 1.20 | (0.37, 4.03)
Appetite or Weight/Increase | Risperidone | 3 | 20 | 149 | 56 | 144 | 5.94 | (2.94, 12.62)
Cardiovascular/BP/Decrease | Risperidone | 2 | 1 | 91 | 11 | 89 | 12.47 | (1.75, 547.58)
Cardiovascular/Rhythm | Risperidone | 1 | 1 | 52 | 0 | 49 | 0.00 | (0.00, 41.39)
Constitutional/Fever or Infection | Risperidone | 2 | 19 | 131 | 20 | 128 | 1.10 | (0.52, 2.30)
Dermatologic | Risperidone | 1 | 7 | 52 | 11 | 49 | 1.85 | (0.59, 6.22)
Endocrine | Ziprasidone | 1 | 0 | 12 | 1 | 16 | +Inf | (0.02, Inf+ )
Endocrine/Prolactin | Ziprasidone | 1 | 0 | 12 | 5 | 16 | +Inf | (0.78, Inf+ )
Gastrointestinal | Risperidone | 3 | 54 | 109 | 68 | 105 | 3.24 | (1.41, 7.92)
HEENT | Risperidone | 2 | 33 | 91 | 49 | 89 | 2.31 | (1.19, 4.54)
HEENT/Decreased Salivation | Risperidone | 1 | 5 | 52 | 9 | 49 | 2.10 | (0.58, 8.66)
HEENT/Eye | Risperidone | 1 | 0 | 18 | 2 | 16 | +Inf | (0.21, Inf+ )
HEENT/Increased Salivation | Risperidone | 2 | 4 | 91 | 17 | 89 | 5.35 | (1.63, 23.08)
Infections | Risperidone | 2 | 8 | 91 | 20 | 89 | 3.12 | (1.18, 9.02)
Liver Function Test Abnormality | Risperidone | 1 | 2 | 52 | 1 | 49 | 0.52 | (0.01, 10.37)
Neuro | Risperidone | 2 | 5 | 70 | 8 | 65 | 1.81 | (0.49, 7.40)
Neuro/Fatigue | Risperidone | 3 | 16 | 109 | 39 | 105 | 4.40 | (2.04, 9.94)
Neuro/Headache | Risperidone | 2 | 8 | 91 | 14 | 89 | 1.96 | (0.72, 5.72)
Neuro/Movement Disorder | Risperidone | 1 | 0 | 79 | 3 | 79 | +Inf | (0.42, Inf+ )
Neuro/Movement Disorder/Akathisia | Ziprasidone | 1 | 0 | 12 | 1 | 16 | +Inf | (0.02, Inf+ )
Neuro/Movement Disorder/EPS | Risperidone | 2 | 9 | 131 | 34 | 128 | 4.85 | (2.15, 12.08)
Neuro/Movement Disorder/Gait | Risperidone | 1 | 2 | 39 | 0 | 40 | 0.00 | (0.00, 5.17)
Neuro/Movement Disorder/Tardive Dyskinesia | Risperidone | 2 | 5 | 91 | 6 | 89 | 1.27 | (0.31, 5.55)
Neuro/Sedation | Risperidone | 3 | 10 | 109 | 56 | 105 | 12.09 | (5.40, 29.61)
Neuro/Sedation | Ziprasidone | 1 | 5 | 12 | 12 | 16 | 3.97 | (0.66, 28.56)
Psychiatric | Risperidone | 1 | 0 | 18 | 2 | 16 | +Inf | (0.21, Inf+ )
Psychiatric/Aggression | Risperidone | 1 | 0 | 39 | 1 | 40 | +Inf | (0.02, Inf+ )
Psychiatric/Agitation | Risperidone | 1 | 3 | 52 | 3 | 49 | 1.06 | (0.14, 8.36)
Psychiatric/Anxiety | Risperidone | 1 | 10 | 52 | 12 | 49 | 1.36 | (0.47, 3.96)
Psychiatric/Apathy | Risperidone | 1 | 0 | 39 | 5 | 40 | +Inf | (0.94, Inf+ )
Psychiatric/Cognitive | Risperidone | 1 | 0 | 18 | 2 | 16 | +Inf | (0.21, Inf+ )
Psychiatric/Sexual/Decreased Function | Risperidone | 1 | 0 | 18 | 2 | 16 | +Inf | (0.21, Inf+ )
Psychiatric/Sleep | Risperidone | 3 | 31 | 110 | 25 | 104 | 0.78 | (0.39, 1.57)
Thirst | Risperidone | 1 | 5 | 52 | 6 | 49 | 1.31 | (0.31, 5.84)
Urinary | Risperidone | 1 | 15 | 52 | 15 | 49 | 1.09 | (0.42, 2.79)

NC = Not Calculated

Table H

Autism/Tourette’s studies – Atypical Antipsychotics Compared to Clondine

Adverse Events | Drug | # of studies | Clonidine | | Intervention Groups | | Pooled OR | 95% CI
Adverse Events | Drug | # of studies | # adverse events | sample size | # adverse events | sample size | Pooled OR | 95% CI
HEENT/Decreased Salivation | Risperidone | 1 | 1 | 12 | 0 | 9 | 0.00 | (0.00, 52.00)
Neuro | Risperidone | 1 | 2 | 12 | 1 | 9 | 0.64 | (0.01, 14.44)
Neuro/Movement Disorder/EPS | Risperidone | 1 | 1 | 12 | 2 | 9 | 2.97 | (0.13, 201.94)
Neuro/Sedation | Risperidone | 1 | 5 | 12 | 1 | 9 | 0.19 | (0.00, 2.32)

NC = Not Calculated

Table I

Autism/Tourette’s studies – Atypical Antipsychotics Compared to Conventional Antipsychotics

Adverse Events | Drug | # of studies | Conventionals | | Intervention Groups | | Pooled OR | 95% CI
Adverse Events | Drug | # of studies | # adverse events | sample size | # adverse events | sample size | Pooled OR | 95% CI
Appetite or Weight/Decrease | Olanzapine | 1 | 1 | 6 | 0 | 6 | 0.00 | (0.00, 39.00)
Appetite or Weight/Increase | Olanzapine | 1 | 5 | 6 | 6 | 6 | +Inf | (0.03, Inf+ )
Appetite or Weight/Increase | Risperidone | 1 | 20 | 24 | 22 | 26 | 1.10 | (0.18, 6.75)
Cardiovascular/BP/Decrease | Olanzapine | 1 | 1 | 6 | 0 | 6 | 0.00 | (0.00, 39.00)
Dermatologic | Olanzapine | 1 | 1 | 6 | 0 | 6 | 0.00 | (0.00, 39.00)
Gastrointestinal | Olanzapine | 1 | 0 | 6 | 2 | 6 | +Inf | (0.19, Inf+ )
HEENT/Decreased Salivation | Olanzapine | 1 | 1 | 6 | 1 | 6 | 1.00 | (0.01, 94.01)
Neuro/Fatigue | Risperidone | 1 | 9 | 24 | 10 | 26 | 1.04 | (0.29, 3.81)
Neuro/Headache | Risperidone | 1 | 2 | 24 | 5 | 26 | 2.57 | (0.37, 29.80)
Neuro/Movement Disorder | Risperidone | 1 | 5 | 24 | 2 | 26 | 0.32 | (0.03, 2.25)
Neuro/Movement Disorder/EPS | Olanzapine | 1 | 2 | 6 | 0 | 6 | 0.00 | (0.00, 5.16)
Neuro/Movement Disorder/EPS | Risperidone | 1 | 8 | 24 | 4 | 26 | 0.37 | (0.07, 1.68)
Neuro/Movement Disorder/Gait | Olanzapine | 1 | 1 | 6 | 0 | 6 | 0.00 | (0.00, 39.00)
Neuro/Movement Disorder/Tardive Dyskinesia | Olanzapine | 1 | 0 | 6 | 0 | 6 | NC | NC
Neuro/Sedation | Olanzapine | 1 | 2 | 6 | 5 | 6 | 7.96 | (0.43, 588.32)
Neuro/Sedation | Risperidone | 1 | 10 | 24 | 12 | 26 | 1.20 | (0.34, 4.25)
Psychiatric/Depression | Risperidone | 1 | 6 | 24 | 8 | 26 | 1.33 | (0.33, 5.68)
Psychiatric/Sleep | Olanzapine | 1 | 0 | 6 | 1 | 6 | +Inf | (0.03, Inf+ )
Psychiatric/Sleep | Risperidone | 1 | 7 | 24 | 1 | 26 | 0.10 | (0.00, 0.90)
Trauma | Risperidone | 1 | 6 | 24 | 1 | 26 | 0.12 | (0.00, 1.16)
Urinary | Olanzapine | 1 | 1 | 6 | 1 | 6 | 1.00 | (0.01, 94.01)

NC = Not Calculated

Table J

Depression/OCD/PD/PTSD studies – Atypical Antipsychotics Compared to Placebo

Adverse Events | Drug | # of studies | Placebo | | Intervention Groups | | Pooled OR | 95% CI
Adverse Events | Drug | # of studies | # adverse events | sample size | # adverse events | sample size | Pooled OR | 95% CI
Appetite or Weight/Increase | Olanzapine | 5 | 33 | 575 | 213 | 580 | 11.16 | (7.40, 17.24)
Appetite or Weight/Increase | Quetiapine | 1 | 2 | 21 | 2 | 21 | 1.00 | (0.07, 15.13)
Appetite or Weight/Increase | Risperidone | 1 | 0 | 19 | 3 | 20 | +Inf | (0.40, Inf+ )
Appetite or Weight/Increase | Ziprasidone | 1 | 0 | 92 | 2 | 210 | +Inf | (0.08, Inf+ )
Cardiovascular | Olanzapine | 1 | 0 | 100 | 7 | 101 | +Inf | (1.21, Inf+ )
Cardiovascular | Ziprasidone | 1 | 0 | 48 | 2 | 91 | +Inf | (0.10, Inf+ )
Cardiovascular/BP/Decrease | Olanzapine | 1 | 5 | 377 | 5 | 370 | 1.02 | (0.23, 4.47)
Cardiovascular/BP/Decrease | Ziprasidone | 1 | 0 | 92 | 3 | 210 | +Inf | (0.18, Inf+ )
Cardiovascular/BP/Increase | Olanzapine | 1 | 6 | 377 | 2 | 370 | 0.34 | (0.03, 1.90)
Cardiovascular/Rhythm | Olanzapine | 1 | 1 | 377 | 1 | 370 | 1.02 | (0.01, 80.20)
Dermatologic | Ziprasidone | 1 | 0 | 48 | 7 | 91 | +Inf | (0.78, Inf+ )
Endocrine/Diabetes | Olanzapine | 2 | 86 | 10673 | 20 | 3073 | 0.80 | (0.46, 1.32)
Endocrine/Diabetes | Quetiapine | 1 | 85 | 10296 | 3 | 922 | 0.39 | (0.08, 1.19)
Endocrine/Diabetes | Risperidone | 1 | 85 | 10296 | 5 | 2860 | 0.21 | (0.07, 0.51)
Endocrine/Prolactin | Risperidone | 1 | 0 | 10 | 1 | 15 | +Inf | (0.02, Inf+ )
Gastrointestinal | Olanzapine | 5 | 78 | 615 | 70 | 615 | 0.86 | (0.60, 1.24)
Gastrointestinal | Quetiapine | 2 | 10 | 202 | 43 | 382 | 2.45 | (1.18, 5.61)
Gastrointestinal | Risperidone | 1 | 0 | 18 | 1 | 19 | +Inf | (0.02, Inf+ )
Gastrointestinal | Ziprasidone | 2 | 61 | 140 | 131 | 301 | 0.97 | (0.63, 1.50)
HEENT | Ziprasidone | 1 | 1 | 48 | 4 | 91 | 2.15 | (0.21, 108.65)
HEENT/Decreased Salivation | Olanzapine | 4 | 40 | 606 | 93 | 596 | 2.71 | (1.80, 4.13)
HEENT/Decreased Salivation | Quetiapine | 2 | 14 | 202 | 161 | 393 | 8.90 | (4.93, 17.27)
HEENT/Decreased Salivation | Risperidone | 1 | 1 | 6 | 2 | 10 | 1.23 | (0.05, 88.30)
HEENT/Decreased Salivation | Ziprasidone | 1 | 4 | 92 | 17 | 210 | 1.93 | (0.61, 8.13)
HEENT/Eye | Olanzapine | 1 | 5 | 100 | 1 | 101 | 0.19 | (0.00, 1.77)
Liver Function Test Abnormality | Olanzapine | 2 | 0 | 169 | 12 | 171 | +Inf | (3.16, Inf+ )
Liver Function Test Abnormality | Ziprasidone | 1 | 0 | 48 | 1 | 91 | +Inf | (0.01, Inf+ )
Musculoskeletal | Quetiapine | 1 | 0 | 21 | 1 | 21 | +Inf | (0.03, Inf+ )
Neuro | Aripiprazol | 1 | 14 | 83 | 6 | 78 | 0.41 | (0.12, 1.22)
Neuro | Olanzapine | 2 | 8 | 129 | 23 | 125 | 3.36 | (1.38, 9.08)
Neuro | Quetiapine | 2 | 26 | 202 | 81 | 393 | 1.81 | (1.08, 3.10)
Neuro | Risperidone | 1 | 0 | 6 | 1 | 10 | +Inf | (0.02, Inf+ )
Neuro | Ziprasidone | 2 | 9 | 140 | 31 | 301 | 1.61 | (0.72, 3.99)
Neuro/Fatigue | Olanzapine | 3 | 20 | 506 | 55 | 495 | 2.98 | (1.72, 5.35)
Neuro/Fatigue | Quetiapine | 1 | 4 | 21 | 4 | 32 | 0.71 | (0.09, 4.92)
Neuro/Fatigue | Risperidone | 1 | 0 | 10 | 1 | 15 | +Inf | (0.02, Inf+ )
Neuro/Fatigue | Ziprasidone | 1 | 0 | 48 | 3 | 91 | +Inf | (0.22, Inf+ )
Neuro/Headache | Olanzapine | 3 | 94 | 506 | 68 | 495 | 0.69 | (0.48, 0.98)
Neuro/Headache | Ziprasidone | 2 | 40 | 140 | 68 | 301 | 0.72 | (0.44, 1.17)
Neuro/Movement Disorder | Olanzapine | 1 | 0 | 9 | 0 | 19 | NC | NC
Neuro/Movement Disorder/Akathisia | Aripiprazol | 1 | 1 | 83 | 5 | 78 | +Inf | (1.00, Inf+ )
Neuro/Movement Disorder/Akathisia | Risperidone | 1 | 0 | 18 | 1 | 19 | +Inf | (0.02, Inf+ )
Neuro/Movement Disorder/Akathisia | Ziprasidone | 2 | 9 | 140 | 32 | 301 | 1.69 | (0.76, 4.15)
Neuro/Movement Disorder/EPS | Aripiprazol | 1 | 1 | 83 | 0 | 78 | NC | NC
Neuro/Movement Disorder/EPS | Olanzapine | 1 | 0 | 9 | 1 | 19 | +Inf | (0.01, Inf+ )
Neuro/Movement Disorder/EPS | Risperidone | 1 | 1 | 10 | 0 | 15 | 0.00 | (0.00, 26.00)
Neuro/Movement Disorder/EPS | Ziprasidone | 2 | 5 | 140 | 26 | 301 | 3.32 | (1.12, 13.41)
Neuro/Movement Disorder/Tardive Dyskinesia | Olanzapine | 1 | 0 | 9 | 0 | 19 | NC | NC
Neuro/Pain | Olanzapine | 1 | 3 | 69 | 8 | 70 | 2.82 | (0.64, 17.24)
Neuro/Pain | Ziprasidone | 2 | 12 | 140 | 26 | 301 | 1.02 | (0.48, 2.29)
Neuro/Sedation | Aripiprazol | 1 | 6 | 83 | 4 | 78 | 0.84 | (0.16, 4.09)
Neuro/Sedation | Olanzapine | 7 | 72 | 644 | 179 | 645 | 3.02 | (2.21, 4.14)
Neuro/Sedation | Quetiapine | 2 | 33 | 202 | 227 | 393 | 7.33 | (4.69, 11.73)
Neuro/Sedation | Risperidone | 3 | 0 | 35 | 11 | 45 | +Inf | (2.55, Inf+ )
Neuro/Sedation | Ziprasidone | 2 | 9 | 140 | 47 | 301 | 2.64 | (1.23, 6.33)
Neuro/Speech Disorder | Quetiapine | 1 | 0 | 21 | 1 | 21 | +Inf | (0.03, Inf+ )
Psychiatric | Olanzapine | 2 | 15 | 129 | 6 | 125 | 0.38 | (0.12, 1.09)
Psychiatric | Quetiapine | 1 | 1 | 21 | 1 | 21 | 1.00 | (0.01, 82.37)
Psychiatric/Aggression | Olanzapine | 2 | 14 | 129 | 7 | 125 | 0.48 | (0.16, 1.33)
Psychiatric/Agitation | Aripiprazol | 1 | 9 | 83 | 5 | 78 | 0.57 | (0.14, 1.99)
Psychiatric/Agitation | Olanzapine | 2 | 31 | 129 | 18 | 125 | 0.53 | (0.26, 1.05)
Psychiatric/Agitation | Ziprasidone | 2 | 16 | 140 | 22 | 301 | 0.60 | (0.29, 1.27)
Psychiatric/Anxiety | Aripiprazol | 1 | 17 | 83 | 22 | 78 | 1.43 | (0.65, 3.20)
Psychiatric/Anxiety | Olanzapine | 3 | 67 | 506 | 62 | 495 | 0.92 | (0.62, 1.37)
Psychiatric/Cognitive | Quetiapine | 1 | 0 | 21 | 3 | 21 | +Inf | (0.43, Inf+ )
Psychiatric/Depression | Aripiprazol | 1 | 12 | 83 | 9 | 78 | 0.75 | (0.25, 2.19)
Psychiatric/Depression | Olanzapine | 1 | 8 | 69 | 9 | 70 | 1.12 | (0.36, 3.59)
Psychiatric/Irritability | Quetiapine | 1 | 1 | 21 | 2 | 21 | 2.07 | (0.10, 130.31)
Psychiatric/Mania | Aripiprazol | 1 | 11 | 83 | 5 | 78 | 0.40 | (0.09, 1.45)
Psychiatric/Mania | Quetiapine | 1 | 7 | 181 | 9 | 361 | 0.63 | (0.21, 2.04)
Psychiatric/Psychotic | Olanzapine | 1 | 10 | 45 | 4 | 50 | 0.23 | (0.04, 0.96)
Psychiatric/Self-injurious behavior | Olanzapine | 1 | 0 | 9 | 0 | 19 | NC | NC
Psychiatric/Sexual/Decreased Function | Quetiapine | 1 | 0 | 21 | 1 | 21 | +Inf | (0.03, Inf+ )
Psychiatric/Sexual/Decreased Function | Risperidone | 2 | 1 | 16 | 1 | 25 | 0.63 | (0.01, 49.71)
Psychiatric/Sexual/Decreased Function | Ziprasidone | 1 | 0 | 92 | 2 | 210 | +Inf | (0.08, Inf+ )
Psychiatric/Sleep | Aripiprazol | 1 | 17 | 83 | 12 | 78 | 0.76 | (0.30, 1.87)
Psychiatric/Sleep | Olanzapine | 2 | 77 | 477 | 39 | 471 | 0.46 | (0.30, 0.71)
Psychiatric/Sleep | Ziprasidone | 2 | 15 | 140 | 26 | 301 | 0.74 | (0.36, 1.58)
Psychiatric/Suicidal Ideation | Aripiprazol | 1 | 0 | 26 | 0 | 26 | NC | NC
Psychiatric/Suicidal Ideation | Olanzapine | 1 | 0 | 9 | 0 | 19 | NC | NC
Psychiatric/Suicidal Ideation | Risperidone | 1 | 0 | 10 | 1 | 15 | +Inf | (0.02, Inf+ )
Pulmonary | Ziprasidone | 1 | 2 | 48 | 8 | 91 | 2.21 | (0.42, 22.18)
Urinary | Risperidone | 1 | 0 | 8 | 1 | 8 | +Inf | (0.03, Inf+ )

NC = Not Calculated

Table K

Depression/OCD/PD/PTSD studies – Atypical Antipsychotics Compared to Conventional Antipsychotics

Adverse Events | Drug | # of studies | Conventionals | | Intervention Groups | | Pooled OR | 95% CI
Adverse Events | Drug | # of studies | # adverse events | sample size | # adverse events | sample size | Pooled OR | 95% CI
Appetite or Weight/Decrease | Olanzapine | 1 | 115 | 636 | 149 | 1306 | 0.58 | (0.44, 0.77)
Appetite or Weight/Increase | Aripiprazol | 1 | 14 | 431 | 44 | 859 | 1.61 | (0.85, 3.21)
Appetite or Weight/Increase | Olanzapine | 2 | 112 | 768 | 392 | 1437 | 2.59 | (2.02, 3.34)
Cardiovascular/Rhythm | Olanzapine | 1 | 63 | 636 | 86 | 1306 | 0.64 | (0.45, 0.92)
Constitutional | Olanzapine | 1 | 36 | 636 | 45 | 1306 | 0.59 | (0.37, 0.96)
Constitutional/Fever or Infection | Olanzapine | 1 | 48 | 636 | 56 | 1306 | 0.55 | (0.36, 0.84)
Endocrine/Diabetes | Olanzapine | 1 | 7 | 2756 | 15 | 2703 | 2.19 | (0.84, 6.36)
Endocrine/Diabetes | Quetiapine | 1 | 7 | 2756 | 3 | 922 | 1.28 | (0.21, 5.63)
Endocrine/Diabetes | Risperidone | 1 | 7 | 2756 | 5 | 2860 | 0.69 | (0.17, 2.52)
Gastrointestinal | Olanzapine | 2 | 161 | 768 | 209 | 1437 | 0.60 | (0.48, 0.77)
HEENT/Decreased Salivation | Olanzapine | 1 | 103 | 636 | 290 | 1306 | 1.48 | (1.15, 1.91)
HEENT/Eye | Olanzapine | 1 | 96 | 636 | 139 | 1306 | 0.67 | (0.50, 0.90)
HEENT/Increased Salivation | Olanzapine | 1 | 124 | 636 | 113 | 1306 | 0.39 | (0.29, 0.52)
Heme | Olanzapine | 1 | 0 | 132 | 6 | 131 | +Inf | (1.22, Inf+ )
Musculoskeletal | Olanzapine | 1 | 16 | 132 | 4 | 131 | 0.25 | (0.06, 0.80)
Neuro | Aripiprazol | 1 | 38 | 431 | 65 | 859 | 0.85 | (0.55, 1.32)
Neuro/Fatigue | Olanzapine | 1 | 104 | 636 | 150 | 1306 | 0.66 | (0.50, 0.88)
Neuro/Movement Disorder | Olanzapine | 1 | 115 | 636 | 102 | 1306 | 0.38 | (0.29, 0.52)
Neuro/Movement Disorder/Akathisia | Aripiprazol | 1 | 108 | 431 | 111 | 859 | 0.44 | (0.33, 0.60)
Neuro/Movement Disorder/Akathisia | Olanzapine | 2 | 266 | 768 | 203 | 1437 | 0.31 | (0.25, 0.38)
Neuro/Movement Disorder/EPS | Aripiprazol | 1 | 171 | 431 | 118 | 859 | 0.24 | (0.18, 0.32)
Neuro/Movement Disorder/EPS | Olanzapine | 2 | 389 | 768 | 369 | 1437 | 0.29 | (0.24, 0.36)
Neuro/Movement Disorder/Gait | Olanzapine | 1 | 20 | 636 | 22 | 1306 | 0.53 | (0.27, 1.03)
Neuro/Sedation | Aripiprazol | 1 | 32 | 431 | 43 | 859 | 0.66 | (0.40, 1.09)
Neuro/Sedation | Olanzapine | 1 | 199 | 636 | 339 | 1306 | 0.77 | (0.62, 0.95)
Psychiatric | Olanzapine | 1 | 15 | 636 | 13 | 1306 | 0.42 | (0.18, 0.94)
Psychiatric/Agitation | Aripiprazol | 1 | 30 | 431 | 53 | 859 | 0.88 | (0.54, 1.45)
Psychiatric/Anxiety | Aripiprazol | 1 | 50 | 431 | 108 | 859 | 1.10 | (0.76, 1.60)
Psychiatric/Anxiety | Olanzapine | 1 | 51 | 132 | 27 | 131 | 0.41 | (0.22, 0.73)
Psychiatric/Lability | Olanzapine | 1 | 7 | 132 | 10 | 131 | 1.55 | (0.48, 5.45)
Psychiatric/Psychotic | Aripiprazol | 1 | 70 | 431 | 156 | 859 | 1.14 | (0.83, 1.58)
Psychiatric/Sleep | Aripiprazol | 1 | 88 | 431 | 185 | 859 | 1.07 | (0.80, 1.44)
Psychiatric/Sleep | Olanzapine | 1 | 632 | 636 | 1122 | 1306 | 0.03 | (0.01, 0.09)
Sweating | Olanzapine | 1 | 84 | 636 | 89 | 1306 | 0.48 | (0.35, 0.67)
Urinary | Olanzapine | 1 | 39 | 636 | 47 | 1306 | 0.57 | (0.36, 0.91)

NC = Not Calculated

Table L

Depression/OCD/PD/PTSD studies – Atypical Antipsychotics Compared to Mood Stabilizers

Adverse Events | Drug | # of studies | Mood Stabilizers | | Intervention Groups | | Pooled OR | 95% CI
Adverse Events | Drug | # of studies | # adverse events | sample size | # adverse events | sample size | Pooled OR | 95% CI
Gastrointestinal | Quetiapine | 1 | 0 | 14 | 2 | 14 | +Inf | (0.19, Inf+ )
HEENT | Olanzapine | 1 | 0 | 126 | 6 | 125 | +Inf | (1.21, Inf+ )
HEENT/Decreased Salivation | Olanzapine | 1 | 8 | 126 | 42 | 125 | 7.41 | (3.22, 19.23)
Heme/Low platelets | Olanzapine | 1 | 10 | 126 | 0 | 125 | 0.00 | (0.00, 0.42)
Liver Function Test Abnormality | Olanzapine | 1 | 0 | 126 | 6 | 125 | +Inf | (1.22, Inf+ )
Neuro | Olanzapine | 1 | 15 | 126 | 20 | 125 | 1.41 | (0.65, 3.12)
Neuro/Fatigue | Olanzapine | 1 | 17 | 126 | 20 | 125 | 1.22 | (0.57, 2.63)
Neuro/Headache | Olanzapine | 2 | 40 | 340 | 37 | 342 | 0.91 | (0.54, 1.54)
Neuro/Movement Disorder/EPS | Olanzapine | 1 | 6 | 126 | 21 | 125 | 4.02 | (1.50, 12.64)
Neuro/Pain | Olanzapine | 1 | 18 | 126 | 17 | 125 | 0.94 | (0.43, 2.06)
Neuro/Sedation | Olanzapine | 2 | 26 | 340 | 55 | 342 | 2.81 | (1.59, 5.07)
Neuro/Sedation | Quetiapine | 1 | 0 | 14 | 2 | 14 | +Inf | (0.19, Inf+ )
Neuro/Speech Disorder | Olanzapine | 1 | 1 | 126 | 10 | 125 | 10.79 | (1.49, 475.41)
Psychiatric/Agitation | Olanzapine | 1 | 14 | 126 | 14 | 125 | 1.01 | (0.42, 2.40)
Psychiatric/Anxiety | Olanzapine | 2 | 31 | 340 | 25 | 342 | 0.79 | (0.43, 1.42)
Psychiatric/Depression | Olanzapine | 1 | 25 | 214 | 45 | 217 | 1.97 | (1.13, 3.51)
Psychiatric/Mania | Olanzapine | 1 | 44 | 214 | 17 | 217 | 0.33 | (0.17, 0.61)
Psychiatric/Sleep | Olanzapine | 2 | 49 | 340 | 24 | 342 | 0.43 | (0.25, 0.75)

NC = Not Calculated

Table M

Depression/OCD/PD/PTSD studies – Atypical Antipsychotics Compared to SRIs

Adverse Events | Drug | # of studies | SRI | | Intervention Groups | | Pooled OR | 95% CI
Adverse Events | Drug | # of studies | # adverse events | sample size | # adverse events | sample size | Pooled OR | 95% CI
Cardiovascular | Risperidone | 1 | 0 | 10 | 1 | 10 | +Inf | (0.03, Inf+ )
Dermatologic | Risperidone | 1 | 1 | 10 | 1 | 10 | 1.00 | (0.01, 87.11)
Gastrointestinal | Risperidone | 1 | 7 | 10 | 5 | 10 | 0.45 | (0.05, 3.67)
Gastrointestinal | Ziprasidone | 1 | 0 | 21 | 9 | 43 | +Inf | (1.07, Inf+ )
HEENT | Ziprasidone | 1 | 0 | 21 | 3 | 43 | +Inf | (0.20, Inf+ )
HEENT/Decreased Salivation | Olanzapine | 1 | 4 | 60 | 10 | 62 | 2.36 | (0.61, 11.16)
HEENT/Decreased Salivation | Risperidone | 1 | 3 | 10 | 1 | 10 | 0.28 | (0.00, 4.35)
HEENT/Decreased Salivation | Ziprasidone | 1 | 0 | 21 | 6 | 43 | +Inf | (0.60, Inf+ )
HEENT/Eye | Risperidone | 1 | 0 | 10 | 0 | 10 | NC | NC
HEENT/Eye | Ziprasidone | 1 | 0 | 21 | 5 | 43 | +Inf | (0.46, Inf+ )
HEENT/Increased Salivation | Risperidone | 1 | 0 | 10 | 0 | 10 | NC | NC
Infections | Ziprasidone | 1 | 0 | 21 | 5 | 43 | +Inf | (0.46, Inf+ )
Musculoskeletal | Risperidone | 1 | 0 | 10 | 1 | 10 | +Inf | (0.03, Inf+ )
Neuro | Olanzapine | 2 | 16 | 74 | 12 | 78 | 0.66 | (0.25, 1.68)
Neuro | Risperidone | 1 | 1 | 10 | 0 | 10 | 0.00 | (0.00, 39.00)
Neuro | Ziprasidone | 1 | 1 | 21 | 15 | 43 | 10.42 | (1.38, 473.14)
Neuro/Fatigue | Olanzapine | 1 | 5 | 60 | 11 | 62 | 3.00 | (0.82, 13.75)
Neuro/Fatigue | Risperidone | 1 | 2 | 10 | 2 | 10 | 1.00 | (0.06, 17.08)
Neuro/Fatigue | Ziprasidone | 1 | 0 | 21 | 9 | 43 | +Inf | (1.07, Inf+ )
Neuro/Headache | Risperidone | 1 | 1 | 10 | 1 | 10 | 1.00 | (0.01, 87.11)
Neuro/Movement Disorder | Olanzapine | 1 | 0 | 14 | 0 | 16 | NC | NC
Neuro/Movement Disorder | Risperidone | 1 | 0 | 10 | 1 | 10 | +Inf | (0.03, Inf+ )
Neuro/Movement Disorder/Akathisia | Olanzapine | 1 | 5 | 14 | 4 | 16 | 0.61 | (0.09, 3.78)
Neuro/Movement Disorder/EPS | Risperidone | 1 | 1 | 10 | 1 | 10 | 1.00 | (0.01, 87.11)
Neuro/Movement Disorder/EPS | Ziprasidone | 1 | 1 | 21 | 7 | 43 | 3.82 | (0.44, 183.88)
Neuro/Movement Disorder/Tardive Dyskinesia | Olanzapine | 1 | 0 | 14 | 0 | 16 | NC | NC
Neuro/Pain | Ziprasidone | 1 | 0 | 21 | 4 | 43 | +Inf | (0.32, Inf+ )
Neuro/Sedation | Olanzapine | 2 | 6 | 74 | 23 | 78 | 6.04 | (1.95, 22.41)
Neuro/Sedation | Risperidone | 1 | 2 | 10 | 5 | 10 | 3.72 | (0.40, 53.84)
Neuro/Sedation | Ziprasidone | 1 | 2 | 21 | 8 | 43 | 2.15 | (0.37, 22.77)
Neuro/Sensory | Risperidone | 1 | 0 | 10 | 0 | 10 | NC | NC
Psychiatric/Agitation | Risperidone | 1 | 0 | 10 | 0 | 10 | NC | NC
Psychiatric/Agitation | Ziprasidone | 1 | 0 | 21 | 9 | 43 | +Inf | (1.07, Inf+ )
Psychiatric/Anxiety | Risperidone | 1 | 0 | 10 | 1 | 10 | +Inf | (0.03, Inf+ )
Psychiatric/Anxiety | Ziprasidone | 1 | 2 | 21 | 0 | 43 | 0.00 | (0.00, 2.55)
Psychiatric/Cognitive | Risperidone | 1 | 1 | 10 | 0 | 10 | 0.00 | (0.00, 39.00)
Psychiatric/Cognitive | Ziprasidone | 1 | 0 | 21 | 4 | 43 | +Inf | (0.32, Inf+ )
Psychiatric/Depression | Risperidone | 1 | 0 | 10 | 0 | 10 | NC | NC
Psychiatric/Sexual/Decreased Function | Risperidone | 1 | 2 | 10 | 0 | 10 | 0.00 | (0.00, 5.23)
Psychiatric/Sexual/Decreased Function | Ziprasidone | 1 | 1 | 21 | 0 | 43 | 0.00 | (0.00, 19.05)
Psychiatric/Sleep | Risperidone | 1 | 2 | 10 | 1 | 10 | 0.46 | (0.01, 10.51)
Psychiatric/Sleep | Ziprasidone | 1 | 1 | 21 | 13 | 43 | 8.45 | (1.10, 386.39)
Psychiatric/Suicide Attempt | Olanzapine | 1 | 1 | 14 | 0 | 16 | 0.00 | (0.00, 34.12)
Sweating | Risperidone | 1 | 1 | 10 | 1 | 10 | 1.00 | (0.01, 87.11)
Urinary | Risperidone | 1 | 1 | 10 | 0 | 10 | 0.00 | (0.00, 39.00)

NC = Not Calculated

Table N

Depression/OCD/PD/PTSD studies – Atypical Antipsychotics Compared to Tricyclic Antidepressants

Adverse Events | Drug | # of studies | Tricyclic Antidepressants | | Intervention Groups | | Pooled OR | 95% CI
Adverse Events | Drug | # of studies | # adverse events | sample size | # adverse events | sample size | Pooled OR | 95% CI
Cardiovascular/BP/Decrease | Olanzapine | 1 | 10 | 20 | 4 | 20 | 0.26 | (0.05, 1.21)
Endocrine/Prolactin | Olanzapine | 1 | 1 | 20 | 6 | 20 | 7.76 | (0.80, 393.79)

NC = Not Calculated

Table O

Depression/OCD/PD/PTSD studies – Atypical Antipsychotics Compared to SNRIs

Adverse Events | Drug | # of studies | SNRI | | Intervention Groups | | Pooled OR | 95% CI
Adverse Events | Drug | # of studies | # adverse events | sample size | # adverse events | sample size | Pooled OR | 95% CI
Neuro/Fatigue | Olanzapine | 1 | 5 | 59 | 11 | 62 | 2.94 | (0.81, 13.51)
Neuro/Sedation | Olanzapine | 1 | 5 | 59 | 11 | 62 | 2.94 | (0.81, 13.51)

NC = Not Calculated

Table P

Depression/OCD/PD/PTSD studies – Atypical Antipsychotic Compared to Another Atypical Antipsychotic

Adverse Events | Atypical antipsychotic 1 | Atypical antipsychotic 2 | # of studies | Atypical antipsychotic 1 | | Atypical antipsychotic 2 | | Pooled OR | 95% CI
Adverse Events | Atypical antipsychotic 1 | Atypical antipsychotic 2 | # of studies | # adverse events | sample size | # adverse events | sample size | Pooled OR | 95% CI
Appetite or Weight/Decrease | Risperidone | Quetiapine | 1 | 0 | 175 | 4 | 553 | +Inf | (0.21, Inf+ )
Appetite or Weight/Decrease | Ziprasidone | Olanzapine | 1 | 10 | 192 | 2 | 202 | 0.18 | (0.02, 0.87)
Appetite or Weight/Increase | Risperidone | Quetiapine | 1 | 6 | 175 | 14 | 553 | 0.73 | (0.26, 2.36)
Appetite or Weight/Increase | Ziprasidone | Olanzapine | 1 | 19 | 192 | 62 | 202 | 4.02 | (2.25, 7.48)
Cardiovascular | Ziprasidone | Olanzapine | 2 | 7 | 328 | 16 | 335 | 2.39 | (0.91, 7.01)
Constitutional | Ziprasidone | Olanzapine | 1 | 52 | 136 | 39 | 133 | 0.67 | (0.39, 1.15)
Constitutional/Fever or Infection | Ziprasidone | Olanzapine | 1 | 5 | 192 | 0 | 202 | 0.00 | (0.00, 1.42)
Dermatologic | Ziprasidone | Olanzapine | 1 | 14 | 136 | 10 | 133 | 0.71 | (0.27, 1.79)
Endocrine | Ziprasidone | Olanzapine | 1 | 6 | 136 | 14 | 133 | 2.54 | (0.88, 8.34)
Endocrine/Diabetes | Quetiapine | Olanzapine | 1 | 3 | 922 | 15 | 2703 | 1.71 | (0.70, 5.03)
Endocrine/Diabetes | Risperidone | Olanzapine | 1 | 5 | 2860 | 15 | 2703 | 3.19 | (1.10, 11.22)
Endocrine/Diabetes | Risperidone | Quetiapine | 1 | 5 | 2860 | 3 | 922 | 1.86 | (0.29, 9.60)
Gastrointestinal | Ziprasidone | Olanzapine | 2 | 76 | 328 | 57 | 335 | 0.66 | (0.43, 1.00)
HEENT/Bruxism | Ziprasidone | Olanzapine | 1 | 4 | 192 | 0 | 202 | 0.00 | (0.00, 1.42)
HEENT/Decreased Salivation | Risperidone | Quetiapine | 1 | 12 | 175 | 80 | 553 | 2.30 | (1.20, 4.75)
HEENT/Decreased Salivation | Ziprasidone | Olanzapine | 1 | 20 | 192 | 32 | 202 | 1.56 | (0.82, 3.01)
Heme | Ziprasidone | Olanzapine | 1 | 3 | 136 | 5 | 133 | 1.73 | (0.33, 11.36)
Musculoskeletal | Ziprasidone | Olanzapine | 1 | 8 | 136 | 8 | 133 | 1.02 | (0.32, 3.24)
Neuro | Risperidone | Quetiapine | 1 | 12 | 175 | 70 | 553 | 1.97 | (1.02, 4.09)
Neuro/Headache | Risperidone | Quetiapine | 1 | 11 | 175 | 52 | 553 | 1.55 | (0.77, 3.37)
Neuro/Headache | Ziprasidone | Olanzapine | 1 | 25 | 192 | 32 | 202 | 1.21 | (0.66, 2.24)
Neuro/Movement Disorder | Ziprasidone | Olanzapine | 1 | 0 | 192 | 5 | 202 | +Inf | (0.88, Inf+ )
Neuro/Movement Disorder/EPS | Risperidone | Quetiapine | 1 | 75 | 175 | 227 | 553 | 0.92 | (0.64, 1.31)
Neuro/Sedation | Risperidone | Quetiapine | 1 | 27 | 175 | 173 | 553 | 2.49 | (1.57, 4.06)
Neuro/Sensory | Ziprasidone | Olanzapine | 1 | 8 | 136 | 6 | 133 | 0.76 | (0.21, 2.57)
Psychiatric/Agitation | Risperidone | Quetiapine | 1 | 3 | 175 | 34 | 553 | 3.75 | (1.16, 19.33)
Psychiatric/Anxiety | Ziprasidone | Olanzapine | 1 | 82 | 136 | 64 | 133 | 0.61 | (0.37, 1.02)
Psychiatric/Irritability | Ziprasidone | Olanzapine | 1 | 7 | 192 | 2 | 202 | 0.26 | (0.03, 1.42)
Psychiatric/Psychotic | Ziprasidone | Olanzapine | 1 | 15 | 192 | 5 | 202 | 0.30 | (0.08, 0.89)

NC = Not Calculated

Table P

Depression/OCD/PD/PTSD studies – Atypical Antipsychotic Compared to Another Atypical Antipsychotic (continued)

Adverse Events | Atypical antipsychotic 1 | Atypical antipsychotic 2 | # of studies | Atypical antipsychotic 1 | | Atypical antipsychotic 2 | | Pooled OR | 95% CI
Adverse Events | Atypical antipsychotic 1 | Atypical antipsychotic 2 | # of studies | # adverse events | sample size | # adverse events | sample size | Pooled OR | 95% CI
Psychiatric/Sleep | Risperidone | Quetiapine | 1 | 17 | 175 | 65 | 553 | 1.24 | (0.69, 2.32)
Psychiatric/Sleep | Ziprasidone | Olanzapine | 1 | 35 | 192 | 25 | 202 | 0.66 | (0.36, 1.19)
Pulmonary | Ziprasidone | Olanzapine | 1 | 24 | 136 | 16 | 133 | 0.64 | (0.30, 1.33)
Urinary | Ziprasidone | Olanzapine | 1 | 9 | 136 | 5 | 133 | 0.55 | (0.14, 1.90)

NC = Not Calculated

Table Q

Depression/OCD/PD/PTSD studies – Olanzapine with Fluoxetine Comapred to Fluoxetine

Adverse Events | # of studies | Fluoxetine | | Olanzapine + Fluoxetine | | Pooled OR | 95% CI
Adverse Events | # of studies | # adverse events | sample size | # adverse events | sample size | Pooled OR | 95% CI
Neuro | 1 | 0 | 14 | 1 | 15 | +Inf | (0.02, +Inf)
Neuro/Movement Disorder | 1 | 0 | 14 | 0 | 15 | NC | NC
Neuro/Movement Disorder/Akathisia | 1 | 5 | 14 | 5 | 15 | 0.90 | (0.15, 5.44)
Neuro/Movement Disorder/Tardive Dyskinesia | 1 | 0 | 14 | 0 | 15 | NC | NC
Neuro/Sedation | 1 | 3 | 14 | 7 | 15 | 3.08 | (0.50, 24.41)
Psychiatric/Suicide Attempt | 1 | 1 | 14 | 0 | 15 | 0.00 | (0.00, 36.40)

NC = Not Calculated

Table R

Depression/OCD/PD/PTSD studies – Quetiapine with Paraxetine Compared to Paraxetine

Adverse Events | # of studies | Paroxetine | | Quetiapine + Paraxetine | | Pooled OR | 95% CI
Adverse Events | # of studies | # adverse events | sample size | # adverse events | sample size | Pooled OR | 95% CI
Appetite or Weight/Increase | 1 | 1 | 54 | 12 | 58 | 12.22 | (1.66, 545.28)
Psychiatric/Anxiety | 1 | 7 | 54 | 1 | 58 | 0.12 | (0.00, 0.98)
Psychiatric/Sleep | 1 | 17 | 54 | 0 | 58 | 0.00 | (0.00, 0.18)

NC = Not Calculated

Table S

Depression/OCD/PD/PTSD studies – Risperidone with Paraxetine Compared to Paraxetine

Adverse Events | # of studies | Paroxetine | | Risperidone + Paroxetine | | Pooled OR | 95% CI
Adverse Events | # of studies | # adverse events | sample size | # adverse events | sample size | Pooled OR | 95% CI
Appetite or Weight/Decrease | 1 | 1 | 10 | 0 | 10 | 0.00 | (0.00, 39.00)
Appetite or Weight/Increase | 1 | 3 | 10 | 6 | 10 | 3.27 | (0.41, 33.28)
Cardiovascular | 1 | 0 | 10 | 0 | 10 | NC | NC
Dermatologic | 1 | 1 | 10 | 0 | 10 | 0.00 | (0.00, 39.00)
Gastrointestinal | 1 | 7 | 10 | 3 | 10 | 0.20 | (0.02, 1.68)
HEENT/Decreased Salivation | 1 | 3 | 10 | 1 | 10 | 0.28 | (0.00, 4.35)
HEENT/Eye | 1 | 0 | 10 | 1 | 10 | +Inf | (0.03, +Inf)
HEENT/Increased Salivation | 1 | 0 | 10 | 1 | 10 | +Inf | (0.03, +Inf)
Musculoskeletal | 1 | 0 | 10 | 0 | 10 | NC | NC
Neuro | 1 | 1 | 10 | 1 | 10 | 1.00 | (0.01, 87.11)
Neuro/Fatigue | 1 | 2 | 10 | 1 | 10 | 0.46 | (0.01, 10.51)
Neuro/Headache | 1 | 1 | 10 | 0 | 10 | 0.00 | (0.00, 39.00)
Neuro/Movement Disorder | 1 | 0 | 10 | 0 | 10 | NC | NC
Neuro/Movement Disorder/EPS | 1 | 1 | 10 | 1 | 10 | 1.00 | (0.01, 87.11)
Neuro/Sedation | 1 | 2 | 10 | 2 | 10 | 1.00 | (0.06, 17.08)
Neuro/Sensory | 1 | 0 | 10 | 1 | 10 | +Inf | (0.03, +Inf)
Psychiatric/Agitation | 1 | 0 | 10 | 1 | 10 | +Inf | (0.03, +Inf)
Psychiatric/Anxiety | 1 | 0 | 10 | 0 | 10 | NC | NC
Psychiatric/Cognitive | 1 | 1 | 10 | 1 | 10 | 1.00 | (0.01, 87.11)
Psychiatric/Depression | 1 | 0 | 10 | 1 | 10 | +Inf | (0.03, +Inf)
Psychiatric/Sexual/Decreased Function | 1 | 2 | 10 | 3 | 10 | 1.67 | (0.14, 25.60)
Psychiatric/Sleep | 1 | 2 | 10 | 1 | 10 | 0.46 | (0.01, 10.51)
Sweating | 1 | 1 | 10 | 0 | 10 | 0.00 | (0.00, 39.00)
Urinary | 1 | 1 | 10 | 0 | 10 | 0.00 | (0.00, 39.00)

NC = Not Calculated

Table T

Depression/OCD/PD/PTSD studies – Risperidone with SRI Compared to SRI

Adverse Events | # of studies | SRI | | Risperidone vs SRI | | Pooled OR | 95% CI
Adverse Events | # of studies | # adverse events | sample size | # adverse events | sample size | Pooled OR | 95% CI
Appetite or Weight/Increase | 1 | 3 | 16 | 6 | 20 | 1.83 | (0.31, 13.66)
Cardiovascular/Rhythm | 1 | 1 | 16 | 0 | 20 | 0.00 | (0.00, 31.20)
Gastrointestinal | 1 | 1 | 16 | 1 | 20 | 0.79 | (0.01, 66.06)
HEENT/Decreased Salivation | 1 | 5 | 16 | 5 | 20 | 0.74 | (0.13, 4.10)
HEENT/Eye | 1 | 2 | 16 | 0 | 20 | 0.00 | (0.00, 4.19)
Neuro | 1 | 5 | 16 | 3 | 20 | 0.40 | (0.05, 2.54)
Neuro/Headache | 1 | 5 | 16 | 0 | 20 | 0.00 | (0.00, 0.75)
Neuro/Movement Disorder/EPS | 1 | 1 | 16 | 0 | 20 | 0.00 | (0.00, 31.20)
Neuro/Sedation | 1 | 8 | 16 | 17 | 20 | 5.37 | (0.96, 40.18)
Psychiatric/Agitation | 1 | 6 | 16 | 6 | 20 | 0.72 | (0.14, 3.60)
Psychiatric/Sleep | 1 | 1 | 16 | 1 | 20 | 0.79 | (0.01, 66.06)
Sweating | 1 | 4 | 16 | 1 | 20 | 0.17 | (0.00, 1.94)
Urinary | 1 | 0 | 16 | 1 | 20 | +Inf | (0.02, +Inf)

NC = Not Calculated

Table U

Depression/OCD/PD/PTSD studies – Quetiapine with SRI Compared to SRI

Adverse Events | # of studies | SRI | | Quetiapine + SRI | | Pooled OR | 95% CI
Adverse Events | # of studies | # adverse events | sample size | # adverse events | sample size | Pooled OR | 95% CI
Appetite or Weight/Increase | 1 | 0 | 20 | 10 | 20 | +Inf | (3.43, +Inf)
Cardiovascular/Rhythm | 1 | 2 | 20 | 0 | 20 | 0.00 | (0.00, 5.28)
Gastrointestinal | 2 | 2 | 33 | 6 | 34 | 3.36 | (0.52, 38.17)
HEENT/Decreased Salivation | 1 | 8 | 20 | 11 | 20 | 1.81 | (0.44, 7.73)
Neuro | 2 | 0 | 33 | 7 | 34 | +Inf | (1.66, +Inf)
Neuro/Fatigue | 1 | 0 | 20 | 2 | 20 | +Inf | (0.19, +Inf)
Neuro/Headache | 1 | 1 | 13 | 0 | 14 | 0.00 | (0.00, 36.21)
Neuro/Pain | 1 | 0 | 20 | 2 | 20 | +Inf | (0.19, +Inf)
Neuro/Sedation | 2 | 9 | 33 | 22 | 34 | 9.32 | (2.16, 58.89)
Psychiatric | 1 | 3 | 20 | 2 | 20 | 0.64 | (0.05, 6.29)
Psychiatric/Anxiety | 1 | 1 | 13 | 0 | 14 | 0.00 | (0.00, 36.21)
Psychiatric/Cognitive | 1 | 0 | 20 | 3 | 20 | +Inf | (0.43, +Inf)
Psychiatric/Sleep | 1 | 0 | 20 | 2 | 20 | +Inf | (0.19, +Inf)
Sweating | 1 | 6 | 20 | 2 | 20 | 0.27 | (0.02, 1.80)

NC = Not Calculated