# Evidence and Quality Tables

C1_ Evidence Tables

Head to Head Trials

Condition, Drug Author, Year Country, Trial named | Study design Setting Quality (Jadad Score) | Eligibility criteria | Interventions (drug, dose, duration) | Run-in period/ Randomization Method Wash-out period/ Randomization Method | Allowed other medications | Method of outcome assessment Timing of assessment | Age mean/Age range Gender Ethnicity | Screened/ Eligible/ Enrolled | Withdrawn/Lost to FU/Analyzed | Results | Method of adverse events assessment | Adverse events reported | Total withdrawals Withdrawals due to adverse events
Dementia and Agitation Olanzapine & Risperidone (Fontaine CS et al., 2003)^1^ US | Design: RCT Setting: Long-term care Jadad: 3 | Inclusion criteria: Medically stable, Able to comply with oral, non-liquid medication, CGI >= 4, ADCS >= 25 Exclusion criteria: Neuroleptic malignant syndrome, Atypical antipsychotics sensitivity, Major depressive disorder, Schizophrenia, Bipolar disorder, Some antihypertensive drugs, Some antibiotics, Antiparkinsonian drug treatment | Olanzapine-6.65 mg/day average final dose Risperidone-1.47 mg/day average final dose Duration: 0.5 month | None 3 dy of Psychotropics for randomization not described | Lorazepam | Assessed at baseline and 15 day: CGI, NPI, E-BEHAVE-AD, PGDRS, MOSES, QUALID, MMSE. | 83/NR 33% male Caucasian, NOS | NR/47/39 | 4/0/35 | Rejected from meta-analysis because outcomes were measured at less than 6 weeks of followups. | Monitored | Olanzapine vs Risperidone: Asystole: 5.0%(1/20) vs 0.0%(0/19) Brain stem stroke: 5.0%(1/20) vs 0.0%(0/19) Diaphoresis, fainting, & asystole: 5.0%(1/20) vs 0.0%(0/19) Drowsiness: 0.0%(0/20) vs 21.1%(4/19) Dystonia: 0.0%(0/20) vs 5.3%(1/19) Falls: 30.0%(6/20) vs 21.1%(4/19) Mild EPS: 0.0%(0/20) vs 10.5%(2/19) Rash w/elevated BP, pulse, white blood cell count, & temperature: 5.0%(1/20) vs 0.0%(0/19) Unsteady gait, falls: 10.0%(2/20) vs 0.0%(0/19) | Olanzapine vs Risperidone: Withdrawals: 20.0%(4/20) vs 10.5%(2/19) Withdrawals due to adverse events: 20.0%(4/20) vs 0.0%(0/19)
Dementia and Agitation Olanzapine & Risperidone (Herz LR et al., 2002)^2^ US | Design: RCT Setting: Veterans Jadad: 3 | Inclusion criteria: Age > 65 Exclusion criteria: NR | Placebo-dosage not reported Risperidone-0.5–4 mg/day flexible dose Olanzapine-2.5–20 mg/day flexible dose Duration: 1.5 months | None None | NR | Assessed at baseline and 6 weeks: BPRS, CMPNB | NR/NR 100% male NR | NR/29/29 | 1/0/28 | Insufficient statistics for effect-size calculation. | NR | No adverse events reported. | Placebo vs Risperidone vs Olanzapine: Withdrawals: Not reported Withdrawals due to adverse events: Not reported
Dementia and Depression Quetiapine & Risperidone (Mullen J et al., 2001)^3^ US | Design: RCT Setting: Multi-center Jadad: 1 | Inclusion criteria: Age >= 18 Exclusion criteria: Lactating, Medically significant disorders, Clozapine treatment, Clozapine unresponsiveness, Previous drug- induced agranulocytosis, Pregnant, Participation in previous quetiapine trial, Participation in previous clinical trial within 4 months, Risperidone treatment within 4 months | Quetiapine mean dose 253.9 mg/day Risperidone mean dose 4.4 mg/day Duration: 4.0 months | None None | Anticholinergic medications, Antidepressants, Antipsychotics (except olanzapine, sertindole, clozapine), Mood stabilizers, Rescue Medications (haloperidol, benzodiazepines, anti-EPS) | Assessed at baseline and 16 weeks: HAM_D_HDRS, CGI, PANSS | 45/18–87 51% male Caucasian, African-American, Hispanic, Asian, Other | NR/728/728 | 235/NR/NR | Depression_mood-Change in HAM-D at 16 weeks: Quetiapine vs Risperidone-SMD = 0.174(−0.009,0.357) | Monitored | Quetiapine vs Risperidone: At least one adverse event: 72.3%(400/553) vs 61.1%(107/175) Agitation: 6.1%(34/553) vs 1.7%(3/175) Death: 0.7%(4/553) vs 0.0%(0/175) Dizziness: 12.7%(70/553) vs 6.9%(12/175) Dry mouth: 14.5%(80/553) vs 6.9%(12/175) EPS: 29.8%(161/541) vs 40.9%(70/171) Headache: 9.4%(52/553) vs 6.3%(11/175) Insomnia: 11.8%(65/553) vs 9.7%(17/175) Somnolence: 31.3%(173/553) vs 15.4%(27/175) Weight gain: 2.5%(14/553) vs 3.4%(6/175) Weight loss: 0.7%(4/553) vs 0.0%(0/175) | Quetiapine vs Risperidone: Withdrawals: 31.8%(175.854/553) vs 33.7%(58.975/175) Withdrawals due to adverse events: 8.7%(48.111/553) vs 5.1%(8.925/175)
Dementia, Depression and Agitation Olanzapine & Risperidone (Deberdt WG et al., 2005)^4^ US | Design: RCT Setting: Multi-center Jadad: 2 | Inclusion criteria: Age >= 40, NPI or NPI/NH >= 6 sum of hallucinations and delusional items, Assisted Living Facility resident or Nursing home resident Exclusion criteria: Frontotemporal dementia, Lewy body dementia, MMSE > 24, Parkinsons disease, Picks disease | Placebo Olanzapine-5.2 mg mean daily dose Risperidone-1.0 mg mean daily dose Duration: 2.5 months | None 3–14 dy of Placebo for patients who completed the wash-out period | Anticholinergics, Benzodiazepines permitted | Assessed at baseline and 10 weeks: NPI, CGI, NPI- NH, CMAI, BPRS, CSDD, PDS, MMSE | 79/NR 34% male Caucasian, African-American, NOS | NR/494/494 | NR/NR/493 | Dementia_agitation-Change in CMAI-aggression at 10 weeks: Placebo vs Olanzapine-SMD = 0.106(−0.145,0.356) Dementia_agitation-Change in CMAI-aggression at 10 weeks: Placebo vs Risperidone-SMD = −0.021(−0.272,0.23) Dementia_agitation-Change in CMAI-aggression at 10 weeks: Olanzapine vs Risperidone-SMD = −0.127(−0.328,0.074) Dementia_global-Change in NPI-NH total at 10 weeks: Placebo vs Olanzapine-SMD = 0.095(−0.155,0.344) Dementia_global-Change in NPI-NH total at 10 weeks: Placebo vs Risperidone-SMD = 0.016(−0.234,0.266) Dementia_global-Change in NPI-NH total at 10 weeks: Olanzapine vs Risperidone-SMD = −0.079(−0.279,0.122) Dementia_psychosis-Change in NPI-NH Psychosis at 10 weeks: Placebo vs Olanzapine-SMD = 0.201(−0.049,0.45) Dementia_psychosis-Change in NPI-NH Psychosis at 10 weeks: Placebo vs Risperidone-SMD = 0.12(−0.13,0.37) Dementia_psychosis-Change in NPI-NH Psychosis at 10 weeks: Olanzapine vs Risperidone-SMD = −0.08(−0.281,0.12) Dementia_severity-Change in CGI-S at 10 weeks: Placebo vs Olanzapine-WMD = 0(−0.186,0.186) Dementia_severity-Change in CGI-S at 10 weeks: Placebo vs Risperidone-WMD = 0(−0.186,0.186) Dementia_severity-Change in CGI-S at 10 weeks: Olanzapine vs Risperidone-WMD = 0(−0.148,0.148) | Monitored, reported by patient | placebo vs olanzapine vs risperidone: Abnormal gait: 3.2%(3/94) vs 9.9%(20/203) vs 10.7%(21/196) Accidental injury: 10.6%(10/94) vs 13.3%(27/203) vs 8.2%(16/196) Agitation: 13.8%(13/94) vs 18.2%(37/203) vs 15.3%(30/196) Anorexia: 8.5%(8/94) vs 6.4%(13/203) vs 5.6%(11/196) Asthenia: 2.1%(2/94) vs 7.4%(15/203) vs 8.7%(17/196) Confusion: 6.4%(6/94) vs 14.3%(29/203) vs 10.2%(20/196) Delusions: 5.3%(5/94) vs 9.4%(19/203) vs 7.7%(15/196) Dizziness: 4.3%(4/94) vs 6.4%(13/204) vs 5.6%(11/196) Dyspnea: 3.2%(3/94) vs 0.0%(0/203) vs 3.1%(6/196) Flu symptom: 3.2%(3/94) vs 1.0%(2/203) vs 0.0%(0/196) Hallucinations: 5.3%(5/94) vs 12.8%(26/203) vs 8.7%(17/196) Hostility: 1.1%(1/94) vs 6.9%(14/203) vs 6.6%(13/196) Insomnia: 5.3%(5/94) vs 6.9%(14/203) vs 5.6%(11/196) Nervousness: 9.6%(9/94) vs 7.9%(16/203) vs 10.2%(20/196) Peripheral edema: 1.1%(1/94) vs 5.4%(11/203) vs 6.1%(12/196) Somnolence: 8.5%(8/94) vs 23.2%(47/203) vs 18.9%(37/196) Urinary incontinence: 1.1%(1/94) vs 9.4%(19/203) vs 12.8%(25/196) Weight gain: 1.1%(1/94) vs 5.4%(11/203) vs 3.1%(6/196) Weight change in kg: Placebo-90 people (−0.1 kg mean, SD) vs Olanzapine-194 people (1.0 kg mean, SD) vs Risperidone-190 people (0.1 kg mean, SD) | placebo vs olanzapine vs risperidone: Withdrawals: 20.2%(18.988/94) vs 37.7%(76.908/204) vs 31.1%(60.956/196) Withdrawals due to adverse events: 3.2%(3.008/94) vs 16.2%(33.048/204) vs 8.7%(17.052/196)
Depression Olanzapine & Risperidone (Levitt A et al., 2004)^5^ Canada | Design: RCT Setting: Outpatient Jadad: 3 | Inclusion criteria: Treatment-resistant depression, Failed SSRI, 18–65 years, ≥16 on HAM-D, SNRI for at least 4 weeks Exclusion criteria: Suicidal, current Axis 1 DSM IV diagnosis other than anxiety disorder, substance abuse in past 3 months, pregnant, lactating or certain other medications | SRIs or Velanfaxine + Risperidone- mean dose 1.6±0.9 mg/day SRIs or Velanfaxine + Olanzapine- mean dose 9.0±4.6 mg/day Duration: 1.5 months | None None | NR | Assessed at baseline and 6 weeks: HAM_D_HDRS, MADRS, HAM-A, CGI-I | 47.4±11.7 RIS; 43.2±9.2 OLA 46% male RIS; 36% male OLA NR | NR/43/43 | NR/NR/43 | Insufficient statistics for effect-size calculation. | Monitored | No adverse events reported. Weight change in kg: Risperidone-21 people (0.4 kg mean, SD NR) vs Olanzapine-22 people (3.6 kg mean, SD NR) | Risperidone + (SRI or venlafaxine) vs Olanzapine + (SRI or venlafaxine): Withdrawals: Not reported Withdrawals due to adverse events: Not reported
Dementia Olanzapine & Risperidone (Mulsant BH et al., 2004)^6^ US | Design: RCT Setting: Multi-center Jadad: 2 | Inclusion criteria: Age > 65, 1 year duration primary condition, MMSE score of 7–26 and NPI frequency times severity score of ≥4 on delusions, hallucinations or both Exclusion criteria: Psychosis before dementia onset, Delirium, Inability to swallow oral medication or unable to cooperate with study | Risperidone-0.76 mg/day average final dose Olanzapine-5.22 mg/day average final dose Duration: 1.5 months | 7 dy of Placebo for randomization not described 3 dy of ND for randomization not described | Lorazepam, Benzodiazapine, Cholinesterase inhibitors | Assessed at baseline and 6 weeks: NPI, CGI | 84/68–95 23% male Caucasian, African-American, Hispanic | NR/86/86 | NR/NR/85 | Insufficient statistics for effect-size calculation. | Monitored | Risperidone vs Olanzapine: Somnolence: 2.8%(2/71) vs 7.1%(6/84) UKU-based anticholinergic events: 16.9%(12/71) vs 14.3%(12/84) | Risperidone vs Olanzapine: Withdrawals: 17 (19.8%) Withdrawals due to adverse events: 5.6%(4/71) vs 2.4%(2/84)
Depression Olanzapine & Risperidone (Tollefson GD et al., 1999)^7^ Belgium France Switzerland Netherlands South Africa Germany Spain UK US | Design: RCT Setting: Multi-center Jadad: 2 | Inclusion criteria: Schizophrenia, schizophreniform disorder or schizoaffective disorder, ≥18 years old Exclusion criteria: Comorbid or major axis 1 disorder, pregnant or lactating, Failure to show at least minimal clinical response with at least 3 antipsychotics in 3 classes | Olanzapine-17.2 mg/day mean modal dose Risperidone-7.2 mg/day mean modal dose Duration: 7.0 months | None 2–9 days for oral antipsychotic and at least one injection cycle for depot antipsychotics | Anticholinergic medications | Assessed at baseline and 28 weeks: PANSS, PDC, CGI | 36/18–65 65% male Caucasian, NOS | NR/339/339 | NR/NR/254 | Depression_mood-Change in PDC at 8 weeks: Olanzapine vs Risperidone-SMD = 0.254(0.007,0.501) | Monitored | Olanzapine vs Risperidone: Backache: 6.6%(11/167) vs 13.3%(22/165) Blurred vision: 9.6%(16/167) vs 20.6%(34/165) Breathing difficulties: 7.2%(12/167) vs 14.5%(24/165) Delayed ejaculation: 1.8%(3/167) vs 7.3%(12/165) Early waking: 12.0%(20/167) vs 24.2%(40/165) Increased dreams/nightmares: 11.4%(19/167) vs 19.4%(32/165) Dystonic events: 1.7%(3/167) vs 6.0%(10/165) Parkinsonian events: 9.9%(17/167) vs 18.6%(31/165) Pseudoparkinsonism as per Simpson-Angus rating scale: 12.5%(21/167) vs 22.3%(37/165) EPS: 18.6%(31/167) vs 31.1%(51/165) Akathisia (spontaneously reported): 9.9%(17/167) vs 10.8%(18/165) Akathisia as per Barnes Akathisia Scale: 15.9%(27/167) vs 27.3%(37/165) Dyskinetic events (spontaneously reported): 2.3%(4/167) vs 3.0%(5/165) Dyskinetic symptoms at last visit as per categorical analysis of AIMS & diagnositc criteria of Schooler & Kane: 4.6%(7/167) vs 10.7%(45/165) Residual events: 1.7%(3/167) vs 0.6%(1/165) High prolactin concentration at any time: 51.2%(86/167) vs 94.4%(156/165) Low neutrophil concentrations at any time: 4.3%(7/167) vs 0.6%(1/165) Hypersalivation: 6.4%(7/167) vs 16.3%(17/165) Palpitations: 5.5%(6/167) vs 14.4%(15/165) Weight change in kg: Olanzapine – 167 people (mean 4.1, SD 5.9) vs Risperidone – 165 people (mean 2.3, SD 4.8) | Olanzapine vs Risperidone: Withdrawals: 42.4%(73/172) vs 52.7%(88/167) Withdrawals due to adverse events: Not reported
Depression Olanzapine & Ziprasidone (Kinon BJ et al., 2005)^8^ US | Design: RCT Setting: Multi-center Jadad: 2 | Inclusion criteria: MADRS >= 16, MADRS >= 4 on Item 2 Exclusion criteria: Previous sensitivity or unresponsiveness to stuffy drug | Olanzapine-10 mg/day fixed single dose Olanzapine-15 mg/day fixed single dose Olanzapine-20 mg/day fixed single dose Ziprasidone-80 mg/day fixed single dose Ziprasidone-120 mg/day fixed single dose Ziprasidone-160 mg/day fixed single dose Duration: 24.0 months | None None | NR | Assessed at baseline and 24 weeks: MADRS, GAF, CDSS | 42/NR 63% male Caucasian, NOS | NR/394/NR | NR/NR/NR | Depression_mood-Change in MADRS at 24 weeks: Olanzapine vs Ziprasidone-SMD = 1.032(0.822,1.243) | Monitored | Olanzapine vs Ziprasidone: Appetite decrease: 1.0%(2.02/202) vs 5.3%(10.176/192) Appetite increase: 10.4%(21.008/202) vs 4.2%(8.064/192) Bruxism: 0.0%(0/202) vs 2.1%(4.032/192) Dry mouth: 15.8%(31.916/202) vs 10.6%(20.352/192) Headache: 15.8%(31.916/202) vs 10.6%(20.352/192) Influenza: 0.0%(0/202) vs 2.6%(4.992/192) Insomnia: 12.4%(25.048/202) vs 18.0%(34.56/192) Irritability: 1.0%(2.02/202) vs 3.7%(7.104/192) Migraine NOS: 0.0%(0/202) vs 2.6%(4.992/192) Muscle twitching: 2.5%(5.05/202) vs 0.0%(0/192) Nausea: 7.9%(15.958/202) vs 11.1%(21.312/192) Peripheral edema: 3.0%(6.06/202) vs 0.0%(0/192) Psychosis NOS: 2.5%(5.05/202) vs 7.9%(15.168/192) Weight increased: 20.3%(41.006/202) vs 5.8%(11.136/192) Weight change in kg: Olanzapine-202 people (2.53 mean,4.91 SD) vs Ziprasidone-192 people (−1.65 mean,4.16 SD) | Olanzapine vs Ziprasidone: Withdrawals: 55.4% (111.908/202) vs 70.3% (134.976/192) Withdrawals due to adverse events: 16.0%(32.32/202) vs 26.0%(49.92/192)
Depression Olanzapine & Ziprasidone (Simpson GM et al., 2004)^9^ US | Design: RCT Setting: Multi-center Jadad: 4 | Inclusion criteria: CGI >= 4, PANSS with score >= 4 on at least 1 items on positive symptoms subscale Exclusion criteria: Pregnant, Hospitalized >= 2 wks, Abnormal laboratory results, DSM-IV Axis I disorder, not including primary condition studied, Depot neuroleptic within 1 treatment cycle, Resistant to antipsychotic treatment, Suicidal or violent, Olanzapine > 14 days life time exposure or olanzapine daily dose >10 m | Ziprasidone-139.0 mg/day average final dose Olanzapine-13.0 mg/day average final dose Duration: 1.5 months | None 1–3 wk of Antipsychotics for randomization not described | Anti-EPS medications, Lorazepam | Assessed at baseline and 6 weeks: BPRS, PANSS, CGI, CDSS | 38/8–59 65% male Caucasian, African-American, Hispanic, Asian, NOS | 367/269/269 | NR/NR/269 | Depression_severity-Change in CGI-S at 6 weeks: Olanzapine vs Ziprasidone-WMD = −0.05(−0.256,0.156) | Monitored, reported by patient, clinical observation | Ziprasidone vs Olanzapine: At least one adverse event: 84.6%(115/136) vs 71.4%(95/133) Body as a whole: 38.2%(52/136) vs 29.3%(39/133) Cardiovascular: 5.1%(7/136) vs 7.5%(10/133) Digestive: 40.4%(55/136) vs 30.8%(41/133) Endocrine: 0.7%(1/136) vs 0.0%(0/133) Hematic & lymphatic: 2.2%(3/136) vs 3.8%(5/133) Metabolic & nutritional: 3.7%(5/136) vs 10.5%(14/133) Musculoskeletal: 5.9%(8/136) vs 6.0%(8/133) Nervous: 60.3%(82/136) vs 48.1%(64/133) Respiratory: 17.6%(24/136) vs 12.0%(16/133) Skin & appendages: 10.3%(14/136) vs 7.5%(10/133) Special senses: 5.9%(8/136) vs 4.5%(6/133) Urogenital: 6.6%(9/136) vs 3.8%(5/133) Weight change in kg: Ziprasidone-136 people (0.9 mean, SD NR) vs Olanzapine-133 people (3.57 mean, SD NR) | Ziprasidone vs Olanzapine: Withdrawals: 48.5%(66/136) vs 36.8%(49/133) Withdrawals due to adverse events: 7.3%(10/136) vs 3.0%(4/133)

Acronyms in Evidence Table: CCT, Clinical control trial; kg, kilograms; lbs, pounds; ND, Not described; NOS, Not otherwise specified; NR, Not reported; RCT, Randomized control trial; RR, Risk ratio; SMD, Standard mean difference; WMD, Weighted mean difference

Outcomes: ABC, Aberrant Behavior Checklist; ACES, Agitation-Calmness Evaluation Scale; ADAS-cog, Alzheimer’s Disease Assessment Scale; ADHDRS, DuPaul Attention Deficit Hyperactivity Scale; ADL, Activities of Daily Life; AIAQ, Anger, Irritability, and Assault Questionnaire; ASI, Addiction Severity Index; BABS, Brown Assessment of Beliefs Scale; BAI, Beck Anxiety Index; BDHI, Buss-Durkee Hostility Index; BDI, Beck Depression Index; BDS, Blessed Dementia Scale; BEHAVE-AD, Behavioral Pathology in Alzheimer’s Disease Rating Scale; BPRS, Brief Psychiatric Rating Scale; BRMES, Bech-Rafaelsen Melancholia Scale; CAPS, Clinician Administered PTSD Scale; CDSS, Calgary Depression Scale for Schizophrenia; CES-D, Center for Epidemiologic Studies Depression Scale; CGI, Clinical Global Impression Scale; CMAI, Cohen-Mansfield Agitation Inventory; CM-PNB, Cohen-Mansfield Physically Non-Aggressive Behavior; CPRS, Children’s Psychiatric Rating Scale; CSDD, Cornell Scale for Depression in Dementia; CY-BOCS, Children’s Yale-Brown Obsessive-Compulsive Scale; DCM, Dementia Care Mapping; DES, Dissociative Experiences Scale; DTS, Davidson Trauma Scale; E-BEHAVE-AD, Empirical Behavioral Pathology in Alzheimer’s Disease Rating Scale; FAST, Functional Assessment Staging Rating Scale; GAF, Global Assessment of Functioning Scale; HAM-A, Hamilton Rating Scale for Anxiety; HAM-D/HDRS, Hamilton Rating Scale for Depression; IGT, Iowa Gambling Task; MADRS, Montgomery-Asberg Depression Rating Scale; MDRS, Mattis Dementia Rating Scale; MMSE, Mini-Mental State Examination; M-NCAS, Modified Strain in Nursing Care Assessment; MOSES, Multidimentional Observational Scale for Elderly Subjects; MOVES, Motor Tic, Obsessions, and Compulsions, Vocal Tic Evaluation Survey; N-CBRF, Nisonger Child Behavior Rating Scale; NIMH-OC, National Institute of Mental Health Obsessive-Compulsive Scale; NPI, Neuropsychiatric Inventory; NPI/NH, Neuropsychiatric Inventory/Nursing Home; NPI-Q, Neuropsychiatric Inventory Questionnaire; OAS-M, Overt Aggression Scale-Modified; PANSS, Positive and Negative Symptom Scale; PCL-M, Patient Checklist for PTSD--Military Version; PDC, Depression cluster; PDS, Progressive Deterioration Scale; PGDRS, Psychogeriatric Dependency Rating Scale; PGI, Patient Global Impressions; QLDS, Quality of Life in Depression Scale; Q-LES-Q, Quality of Life Enjoyment and Satisfaction Questionnaire; QLS, Quality of Life Scales; QUALID, Quality of Life in Late-Stage Dementia Scale; ROAS, Retrospective Overt Aggression Scale; SANS, Scale for the Assessment of Negative Symptoms; SCL-90, Symptom Checklist-90; SDS, Sheehan Disability Scale; SF-36, Medical Outcomes Study 36-Item Short-Form Health Survey; SIB, Severe Impairment Battery; SIB-Q, Self-injurious Behavior Questionnaire; SIP, Structured Interview for PTSD; SPQ, Schizotypal Personality Questionnaire; SPRINT, Short PTSD Rating Interview; STAS-AX, State-Trait Anger Expression Inventory; STAT-S, Spielberger State-Trait Anger Scale, state version; STAT-T, Spielberger State-Trait Anger Scale, trait version; TOP-8, Treatment Outcome PTSD Scale; TSSS, Tourette’s Syndrome Severity Scale; VAS, Visual Analog Scale; Y-BOCS, Yale-Brown Obsessive-Compulsive Scale; YGTSS, Yale Global Tic Severity Scale; YMRS, Young Mania Rating Scale

1 Fontaine, C. S., Hynan, L. S., Koch, K., Martin-Cook, K., Svetlik, D., and Weiner, M. F. A double-blind comparison of olanzapine versus risperidone in the acute treatment of dementia-related behavioral disturbances in extended care facilities. 2003;64: 6:726–30.

2 Herz, L. R., Volier, L., Frankenburg, F., Colon, S., and Kittur, S. A 6-week, double-blind comparison of olanzapine, risperidone, and placebo for behavioral disturbances in Alzheimer’s disease (abstract). 2002: 63:1065.

3 Mullen, J., Jibson, M. D., and Sweitzer, D. A comparison of the relative safety, efficacy, and tolerability of quetiapine and risperidone in outpatients with schizophrenia and other psychotic disorders: the quetiapine experience with safety and tolerability (QUEST) study. 2001;23: 11:1839–54.

4 Deberdt, W. G., Dysken, M. W., Rappaport, S. A., Feldman, P. D., Young, C. A., Hay, D. P., Lehman, D. L., Dossenbach, M., Degenhardt, E. K., and Breier, A. Comparison of olanzapine and risperidone in the treatment of psychosis and associated behavioral disturbances in patients with dementia. 2005;13: 8:722–30.

5 Levitt, A., Lam, R., Chaput, Y., and et al. Risperidone vs. olanzapine as add-on treatment in treatment resistant depression: a randomized double blind comparison [poster]. 24th Congress of the Collegium Internationale Neuro-Psychopharmacologicum. 2004.

6 Mulsant, B. H., Gharabawi, G. M., Bossie, C. A., and et al. Correlates of anticholinergic activity in patients with demntia and psychosis treated with risperidone or olanzapine. 2004;65:1708–14.

7 Tollefson, G. D., Andersen, S. W., and Tran, P. V. The course of depressive symptoms in predicting relapse in schizophrenia: a double-blind, randomized comparison of olanzapine and risperidone. 99;46: 3:365–73.

8 Kinon, B. J., Lipkovich, I., and Edwards, S. B. Improvement of comorbid depression with olanzapine versus ziprasidone treatment in patients with schizophrenia or schizoaffective disorder. International Congress on Schizophrenia Research (ICOSR). 2005.

9 Simpson, G. M., Glick, I. D., Weiden, P. J., Romano, S. J., and Siu, C. O. Randomized, controlled, double-blind multicenter comparison of the efficacy and tolerability of ziprasidone and olanzapine in acutely ill inpatients with schizophrenia or schizoaffective disorder. 2004;161: 10:1837–47.

C2_ Evidence Tables

Active Control Trials

≥Condition, Drug Author, Year Country, Trial named | Study design Setting Quality (Jadad Score) | Eligibility criteria | Interventions (drug, dose, duration) | Run-in period/Randomization Method Wash-out period/Randomization Method | Allowed other medications | Method of outcome assessment Timing of assessment | Age mean/Age range Gender Ethnicity | Screened/Eligible/Enrolled | Withdrawn/Lost to FU/Analyzed | Results | Method of adverse events assessment | Adverse events reported | Total withdrawals Withdrawals due to adverse events
Autism Olanzapine (Malone RP et al., 2001)^1^ US | Design: RCT Setting: NR Jadad: 3 | Inclusion criteria: Age 5–17, CPRS = moderate impairment ≥ any 2 items Exclusion criteria: Medically significant disorders, Seizure disorder or epilepsy or risk, Neurological disorder, Psychotropic medications, Previous exposure to study drug | Haloperidol-1.4 mg/day average final dose Olanzapine-7.9 mg/day average final dose Duration: 1.5 months | None None | NR | Assessed at baseline and 6 weeks: CGI, CPRS | 8/5–12 67% male Caucasian, African-American, Hispanic | NR/13/12 | 1/0/12 | Autism-Change in CGI-S at 6 weeks: Haloperidol vs Olanzapine-SMD = −0.233(−1.369,0.904) | Monitored | Haloperidol vs Olanzapine: Ataxia: 16.7%(1/6) vs 0.0%(0/6) Behavioral toxicity: 33.3%(2/6) vs 0.0%(0/6) Drowsiness: 33.3%(2/6) vs 83.3%(5/6) Dry mouth: 16.7%(1/6) vs 16.7%(1/6) Dyskinesia: 0.0%(0/6) vs 0.0%(0/6) Enuresis: 16.7%(1/6) vs 16.7%(1/6) Insomnia: 0.0%(0/6) vs 16.7%(1/6) Nausea/vomiting: 0.0%(0/6) vs 33.3%(2/6) Rash: 16.7%(1/6) vs 0.0%(0/6) Rigidity: 16.7%(1/6) vs 0.0%(0/6) Tachycardia: 16.7%(1/6) vs 0.0%(0/6) Transient mild rigidity: 16.7%(1/6) vs 0.0%(0/6) Weight gain: 83.3%(5/6) vs 100.0%(6/6) Weight loss: 16.7%(1/6) vs 0.0%(0/6) Weight change in lbs: Haloperidol-6 people (3.2 mean,4.9 SD) vs Olanzapine-6 people (9 mean,3.5 SD) | Haloperidol vs Olanzapine: Withdrawals: 0.0%(0/6) vs 0.0%(0/6) Withdrawals due to adverse events: 0.0%(0/6) vs 0.0%(0/6)
Dementia and Agitation Olanzapine (Meehan KM et al., 2002) 2 US, Russia | Design: RCT Setting: Multi-center Jadad: 2 | Inclusion criteria: Hospitalized/institutionalized, Nursing home resident, Age ≥ 55, PANSS ≥ 14 on the Excited Component and at least one individual PANSS ≥ 4 item score on scale 1–7, Clinically significant agitation, Exclusion criteria: Anticholinergic medications, Antipsychotic medications, Benzodiazepines, Neurological conditions, excluding Alzheimers or vascular dementia, contributing to psychosis or dementia, Abnormal laboratory results, Suicidal or violent, | Placebo-dosage not reported Lorazepam 1.0 mg/day Olanzapine-2.5–6.25 mg/day flexible dose Olanzapine-5.0–12.5 mg/day flexible dose Duration: 24 hours | None None | NR | Assessed at baseline and 24 hours: PANSS, CMAI, ACES, BPRS, MMSE, CGI | 78/54–97 39% male Caucasian, NOS | 331/272/272 | NR/NR/NR | Rejected from meta-analysis because outcomes were measured at less than 6 weeks of followups. | Monitored, clinical observation and exam | Placebo vs Lorazepam 1.0 mg/d vs Olanzapine 2.5 mg/d vs Olanzapine 5.0 mg/d: Accidental injury: 0.0%(0/67) vs 4.4%(3/68) vs 1.4%(1/71) vs 3.0%(2/66) ECG abnormal: 0.0%(0/67) vs 0.0%(0/68) vs 1.4%(1/71) vs 3.0%(2/66) Headache: 0.0%(0/67) vs 1.5%(1/68) vs 2.8%(2/71) vs 3.0%(2/66) Hypertension: 1.5%(1/67) vs 2.9%(2/68) vs 0.0%(0/71) vs 3.0%(2/66) Sinus bradycardia: 3.0%(2/67) vs 0.0%(0/68) vs 0.0%(0/71) vs 0.0%(0/66) Somnolence: 3.0%(2/67) vs 10.3%(7/68) vs 4.2%(3/71) vs 3.0%(2/66) Vasodilation: 0.0%(0/67) vs 0.0%(0/68) vs 0.0%(0/71) vs 3.0%(2/66) | Placebo vs Lorazepam 1.0 mg/d vs Olanzapine 2.5 mg/d vs Olanzapine 5.0 mg/d: Withdrawals: 13.4%(9/67) vs 17.6%(12/68) vs 11.3%(8/71) vs 10.6%(7/66) Withdrawals due to adverse events: 0.0%(0/67) vs 0.0%(0/68) vs 0.0%(0/71) vs 0.0%(0/66)
Dementia and Agitation Quetiapine (Ballard C et al., 2005)^3^ UK | Design: RCT Setting: Multi-center Jadad: 4 | Inclusion criteria: CMAI ≥ 39, Age ≥ 60, NPI = 4 Exclusion criteria: Antipsychotics treatment ≥ 4 wks, Cholinesterase treatment ≥ 4 wks, Previous sensitivity or unresponsiveness to stuffy drug, Severe internal or neurological disease, Medically significant disorders, | Placebo-dosage not reported Rivastigmine- min 9 mg/day Quetiapine-100 mg/day average final dose Duration: 6.5 months | None None | NR | Assessed at baseline and 26 weeks: CMAI, SIB | 84/NR 20% male NR | 282/93/93 | 20/1/74 | Dementia_agitation-Change in CMAI at 6 weeks: Placebo vs Quetiapine-SMD = 0.276(−0.25, 0.803) Dementia_agitation-Change in CMAI at 6 weeks: Rivastigmine vs Quetiapine-SMD = −0.051(−0.601,0.499) | NR | Placebo vs Rivastigmine vs Quetiapine: Death: 3.2%(1/31) vs 0.0%(0/31) vs 0.0%(0/31) Serious adverse events: 3.2%(1/31) vs 0.0%(0/31) vs 0.0%(0/31) | Placebo vs Rivastigmine vs Quetiapine: Withdrawals: 3.2%(1/31) vs 32.3%(10/31) vs 25.8%(8/31) Withdrawals due to adverse events: Not reported
Dementia and Agitation Risperidone (Chan WC et al., 2001)^4^ China | Design: RCT Setting: Multi-center Jadad: 3 | Inclusion criteria: Age ≥ 55, CMAI of at least 4 in one item and at least 3 in another, BEHAVE-AD ≥ 8 Exclusion criteria: Lewy body dementia, Neurological or medical conditions diminishing cognitive function, Psychosis/psychotic features, Medically significant disorders, Abnormal laboratory results, Allergic or toxic reactions to psychotropic medications, Neuroleptic malignant syndrome | Haloperidol-.90 mg/day average final dose Risperidone-.85 mg/day average final dose Duration: 3.0 months | None 7–14 dy of Psychotropics, Antiparkinsonians for randomization not described | Acetylcholinesterase inhibitors, Benzhexol, Benzodiazepines, Chloral hydrate | Assessed at baseline and 12 weeks: CMAI, BEHAVE-AD, FAST, MMSE | 81/NR 28% male Chinese | NR/58/58 | 3/NR/55 | Dementia_agitation-Change in BEHAVE-AD (aggressiveness) at 12 weeks: Haloperidol vs Risperidone-SMD = 0.057(−0.472,0.585) Dementia_psychosis-Change in BEHAVE-AD (psychosis) at 12 weeks: Haloperidol vs Risperidone-SMD = -0.383(−0.917,0.15) | Monitored, reported by patient | Haloperidol vs Risperidone: Acute retention of urine: 0.0%(0/29) vs 3.4%(1/29) Constipation: 6.9%(2/29) vs 0.0%(0/29) Drug-related day-time sleepiness: 10.3%(3/29) vs 0.0%(0/29) Nausea: 0.0%(0/29) vs 3.4%(1/29) Somnolence: 3.4%(1/29) vs 0.0%(0/29) | Haloperidol vs Risperidone: Withdrawals: 3.4%(1/29) vs 6.9%(2/29) Withdrawals due to adverse events: 3.4%(1/29) vs 0.0%(0/29)
Dementia and Agitation Risperidone (De Deyn PP et al., 1999)^5^ Canada, UK, Europe | Design: RCT Setting: Multi-center Jadad: 4 | Inclusion criteria: Age ≥ 55, Hospitalized/institutionalized, FAST ≥ 4, MMSE ≤ 23, BEHAVE-AD behavior pathology > 1, BEHAVE-AD ge; 8 Exclusion criteria: Neurological or medical conditions diminishing cognitive function, Other psychiatric disorders, Severe internal or neurological disease, Abnormal laboratory results, Depot neuroleptic within 1 treatment cycle, Allergic or toxic reactions to psychotropic medication, Participation in a clinical trial with investigational drugs during the 4 weeks preceding trial | Placebo-dosage not reported Haloperidol-1.2 mg/day average final dose Risperidone-1.1 mg/day average final dose Duration: 3.0 months | None 1 wk of Psychotropics, for patients who completed the wash-out period | NR | Assessed at baseline and 12 weeks: BEHAVE- AD, CMAI, CGI | Median age 81/56–97 44% male Caucasian, African-American, Asian | | | | | Placebo vs Haloperidol vs Risperidone: At least one adverse event: 72.8%(83/114) vs 80.0%(92/115) vs 76.5%(88/115) Somnolence: 4.4%(5/114) vs 18.3%(19/115) vs 12.2%(14/115) | Placebo vs Haloperidol vs Risperidone: Withdrawals: 35.1%(40/114) vs 29.6%(34/115) vs 40.9%(47/115) Withdrawals due to adverse events: Not reported
Dementia and Agitation Risperidone (Suh GH et al., 2004)^6^ Korea | Design: RCT, Crossover Setting: Single center Jadad: 4 | Inclusion criteria: Age ≥ 65, FAST ≥ 4, BEHAVE-D ≥ 8, CMAI ≥ 3 on any 2 items Exclusion criteria: Neurological or medical conditions diminishing cognitive function, Psychotic disorder, Severe internal or neurological disease, Medically significant disorders, Abnormal laboratory results, Allergic or toxic reactions to antipsychotic medications, Neuroleptic malignant syndrome, | Haloperidol-0.83 mg/day average final dose Risperidone-0.80 mg/day average final dose Duration: 2.0 months | None 1 wk of Psychotropics for randomization not described | NR | Assessed at baseline and 15 weeks: BEHAVE- AD, CMAI, CGI | 81/65–97 18% male Korean | | | | | Adverse events not reported. | Haloperidol vs Risperidone: Withdrawals: 1.7%(1/60) vs 3.3%(2/60) Withdrawals due to adverse events: 1.7%(1/60) vs 3.3%(2/60)
Depression Olanzapine (David S JBAKWP, 2002)^7^ NR | Design: RCT Setting: NR Jadad: 2 | Inclusion criteria: NR Exclusion criteria: NR | Placebo-dosage not reported Lorazepam-1.0–3.0 mg/day flexible dose Lorazepam l-2.0–6.0 mg/day flexible dose IM Haloperidal 7.5 mg/d IM Olanzapine 2.5–10.0 mg/d Duration: 24 hours | None None | NR | Assessed at baseline and 999 frequency not reported: Adverse events | NR/NR NR NR | | | | | No adverse events reported. | Data not reported by intervention group.
Depression Olanzapine (McEvoy J et al.,)^8^ US, Canada, UK, Europe HGDH Study | Design: RCT Setting: Multi-center Jadad: 2 | Inclusion criteria: Age 16–40, Psychotic symptoms before age 35, Psychotic symptoms for at least 1 mth, but not > 60 mth, PANSS with score ≥ 4 on at least 2 items on positive symptoms subscale, PANSS ≥5 in 1 psychotic item, CGI ≥ 4, Psychosis/psychotic features, Exclusion criteria: Pregnant, Clozapine treatment, Antipsychotic treatment > 16 wks in a lifetime, Lactating, Medically significant disorders, Previous sensitivity or unresponsiveness to stuffy drug, Alcohol or substance abuse or dependency, Suicidal or violent | Haloperidol-4.8 mg/day average final dose Olanzapine-10.2 mg/day average final dose Duration: 26.0 months | None 12–14 dy of Antipsychotics for randomization not described | Anticholinergic medications, Benzodiazepines | Assessed at baseline and 104 weeks: CGI, MADRS, PANSS | 24/NR 82% male Caucasian, African-American, Hispanic, Asian, NOS | NR/263/263 | NR/14/41 | Depression_mood-Change in MADRS at 12 weeks: Haloperidol vs Olanzapine-SMD = −0.218(−0.46,0.025) Depression_severity-Change in CGI-S at 12 weeks: Haloperidol vs Olanzapine-WMD = −0.15(−0.352,0.052) | Monitored | Haloperidol vs Olanzapine: Akathisia: 30.3%(39.996/132) vs 13.0%(17.03/131) Dystonia: 13.0%(17.16/132) vs 0.0%(0/131) Emotional liability: 5.3%(6.996/132) vs 7.6%(9.956/131) Epistaxis: 0.0%(0/132) vs 4.6%(6.026/131) Extrapyramidal syndrome: 15.2%(20.064/132) vs 4.6%(6.026/131) Increased appetite: 6.1%(8.052/132) vs 16.8%(22.008/131) Joint disorder: 12.1%(15.972/132) vs 3.1%(4.061/131) Nervousness: 38.6%(50.952/132) vs 20.6%(26.986/131) Vomiting: 12.9%(17.028/132) vs 7.6%(9.956/131) Weight gain: 18.9%(24.948/132) vs 43.5%(56.985/131) Weight change in kg: Haloperidol-132 people (4.12 mean, SD NR) vs Olanzapine-131 people (10.47 mean, SD NR) | Haloperidol vs Olanzapine: Withdrawals: 91.1%(119/132) vs 78.6%(103/131) Withdrawals due to adverse events: 13.6%(18/132) vs 5.3%(7/131)
Depression Olanzapine (Shelton RC et al., 2001)^9^, (Tohen M et al., 1999)^10^ US | Design: Trial + open label Setting: NR Jadad: 2 | Inclusion criteria: Resistant to antidepressant therapy, HAM-D ≥ 20 Exclusion criteria: Psychosis/psychotic features, Dysthymic disorder, Bipolar disorder | Fluoxetine- 52 mg/day average final dose Olanzapine-12.5 mg/day average final dose Olanzapine-13.5 mg/day average final dose, Fluoxetine-52 mg/day average final dose Duration: 4.0 months | 6 wk of Fluoxetine for non- responders None | NR | Assessed at baseline and 8 weeks: MADRS, HAM_D_HDRS, CGI | 42/NR 25% male Caucasian, NOS | 34/33/28 | NR/1/22 | Insufficient statistics for effect-size calculation. | NR | No adverse events reported. Weight change in kg: Fluoxetine-10 people (0.88 mean,1.33 SD) vs Olanzapine-8 people (6.07 mean,2.57 SD) vs Olanazpine + Fluoxetine-10 people (6.67 mean,4.54 SD) | Fluoxetine vs Olanzapine vs Olanazpine + Fluoxetine: Withdrawals: 30.0%(3/10) vs 25.0%(2/8) vs 10.0%(1/10) Withdrawals due to adverse events: 0.0%(0/10) vs 12.5%(1/8) vs 0.0%(0/10)
Depression Olanzapine (Street JS et al., 2000)^11^, (Street JS et al., 2000)^12^, (Satterlee WG et al., 1995)^13^ NR | Design: RCT Setting: NR Jadad: 1 | Inclusion criteria: Alzheimers, Psychosis/psychotic features Exclusion criteria: NR | Placebo Olanzapine Duration: 2.0 months | None None | NR | Assessed at baseline and 8 weeks: BEHAVE- AD, Extrapyramidel side effects | 79/64–94 33% male Caucasian | NR/NR/238 | NR/NR/NR | Insufficient statistics for effect-size calculation. | NR | No adverse events reported. | Haloperidol vs Olanzapine: Withdrawals: Not reported Withdrawals due to adverse events: Not reported
Depression Olanzapine (Svestka J SO, 2000)^14^ Czech Republic | Design: RCT Setting: Single center Jadad: 3 | Inclusion criteria: HAM-D ≥ 21 Exclusion criteria: NR | Control-dosage not reported Olanzapine-18.25 mg/day average final dose Duration: 1.0 month | 4.7 dy of Placebo for randomization not described None | Amitriptyline | Assessed at baseline and 4 weeks: HAM_D_HDRS, CGI, MADRS | 50/NR NR NR | NR/40/40 | 0/0/40 | Rejected from meta-analysis because outcomes were measured at less than 6 weeks of followups. | NR | Amitriptyline vs Olanzapine: Hyperprolactinemia: 5.0%(1/20) vs 30.0%(6/20) Tachycardia: 50.0%(10/20) vs 20.0%(4/20) Undesirable effects: 90.0%(18/20) vs 60.0%(12/20) | Amitriptyline vs Olanzapine: Withdrawals: Not reported Withdrawals due to adverse events: Not reported
Depression Olanzapine (Tohen M et al., 2002)^15^ US | Design: RCT Setting: Multi-center Jadad: 3 | Inclusion criteria: YMRS ≥ 20, Age 18–75 Exclusion criteria: Medically significant disorders, Alcohol or substance abuse or dependency, Atypical antipsychotics sensitivity, Sensitivity to mood stabilizer, Treatment with lithium, anticonvulsant, or antipsychotic within 24 hrs, | Divalproex- 1,402 mg/day average final dose Olanzapine-17.4 mg/day average final dose Duration: 0.8 month | None None | Anticholinergic medications, Benzodiazepines | Assessed at baseline and 3 weeks: YMRS, HAM_D_HDRS | 41/18–75 43% male Caucasian, NOS | 330/251/251 | 84/0/251 | Rejected from meta-analysis because outcomes were measured at less than 6 weeks of followups. | Monitored | Divalproex vs Olanzapine: Agitation: 11.1%(14/126) vs 11.2%(14/125) Asthenia: 13.5%(17/126) vs 16.0%(20/125) Constipation: 11.9%(15/126) vs 14.4%(18/125) Decreased platelet count: 8.0%(10.08/126) vs 0.0%(0/125) Diarrhea: 13.5%(17/126) vs 6.4%(8/125) Dizziness: 11.9%(15/126) vs 16.0%(20/125) Dry mouth: 6.3%(8/126) vs 33.6%(42/125) Dyspepsia: 11.1%(14/126) vs 14.4%(18/125) Headache: 23.0%(29/126) vs 22.4%(28/125) Increased ALT/SGPT values: 0.0%(0/126) vs 5.1%(6.375/125) Increased appetite: 2.4%(3/126) vs 12.0%(15/125) Nausea: 28.6%(36/126) vs 10.4%(13/125) Neck rigidity: 1.6%(2/126) vs 7.2%(9/125) Nervousness: 16.7%(21/126) vs 10.4%(13/125) Pain: 14.3%(18/126) vs 13.6%(17/125) Sleep disorder: 0.8%(1/126) vs 5.6%(7/125) Somnolence: 20.6%(26/126) vs 39.2%(49/125) Speech disorder: 0.8%(1/126) vs 8.0%(10/125) Tongue edema: 0.0%(0/126) vs 4.8%(6/125) Tremor: 3.2%(4/126) vs 9.6%(12/125) Vomiting: 14.3%(18/126) vs 8.0%(10/125) Weight gain: 7.9%(10/126) vs 12.0%(15/125) Weight change in kg: Divalproex-126 people (0.9 mean, 2.5 SD) vs Olanzapine-125 people (2.5 mean,2.5 SD) | Divalproex vs Olanzapine: Withdrawals: 22.2%(28/126) vs 23.2%(29/125) Withdrawals due to adverse events: 7.1%(9/126) vs 9.6%(12/125)
Depression Olanzapine (Tohen M et al., 2005)^16^ Canada, Europe, Australia/NZ, South Africa HGHT Study | Design: RCT Setting: Multi-center Jadad: 4 | Inclusion criteria: YMRS ≥ 20, 2 manic or mixed episodes in the preceding 6 years Exclusion criteria: Medically significant disorders, Alcohol or substance abuse or dependency, Depot neuroleptic within 6 weeks, Suicidal or violent, Previous sensitivity or unresponsiveness to stuffy drug | Lithium-1102.7 mg/day average final dose Olanzapine-11.9 mg/day average final dose Duration: 13.0 months | None 6–12 wk of Antipsychotics, Antidepressants, Anticonvulsants for patients in symptomatic remission | Anticholinergic medications, Benzodiazepines | Assessed at baseline and 52 weeks: HAM_D_HDRS, YMRS | 42/NR 47% male Caucasian, NOS | 543/431/431 | 257/3/431 | Depression_mood Follow-up time greater than 48 weeks | Monitored | Lithium vs Olanzapine: Anxiety: 4.7%(10/214) vs 5.5%(12/217) Death: 0.9%(2/214) vs 0.0%(0/217) Depression not otherwise specified: 11.7%(25/214) vs 20.7%(45/217) Headache not otherwise specified: 5.1%(11/214) vs 4.1%(9/217) Hypersomnia: 0.0%(0/214) vs 2.8%(6/217) Insomnia: 22.4%(48/214) vs 7.8%(17/217) Nausea: 3.7%(8/214) vs 0.5%(1/217) Weight decrease: 5.1%(11/214) vs 3.2%(7/217) Weight increase: 4.7%(10/214) vs 6.5%(14/217) Worsening of mania: 20.6%(44/214) vs 7.8%(17/217) Weight change in kg: Lithium-214 people (−1.4 kg mean, SD) vs Olanzapine-217 people (1.8 kg mean, SD) | Lithium vs Olanzapine: Withdrawals: 67.3%(144/214) vs 53.5%(116/217) Withdrawals due to adverse events: 25.7%(55/214) vs 18.9%(41/217)
Depression Olanzapine (Tollefson GD et al., 1997)^17^ US & Europe | Design: RCT Setting: Multi-center Jadad: 5 | Inclusion criteria: Age ≥ 18, BPRS ≥ 18 Exclusion criteria: NR | Haloperidol-11.8 mg/day average final dose Olanzapine-13.2 mg/day average final dose Duration: 1.5 months | None 2–9 dy of Placebo for symptomatic patients | Anti-EPS medications, Benzodiazepines | Assessed at baseline and 6 weeks: BPRS, PANSS, MADRS, CGI | 39/NR 65% male Caucasian, African-American, Hispanic, Asian, NOS | 2223/1996/1996 | 773/26/1996 | Depression_mood-Change in MADRS at 6 weeks: Haloperidol vs Olanzapine-SMD = −0.389(−0.502,−0.275) Depression_severity-Change in CGI-S at 6 weeks: Haloperidol vs Olanzapine-WMD = −0.3(−0.379,−0.221) | Monitored, elicited by investigator, medical record, clinical exam | Haloperidol vs Olanzapine: Acute dyskinesia: 8.0%(51/636) vs 2.8%(37/1306) Akathisia: 35.5%(226/636) vs 14.2%(186/1306) Ataxia: 3.1%(20/636) vs 1.7%(22/1306) Blurred vision: 15.1%(96/636) vs 10.6%(139/1306) Chills: 7.5%(48/636) vs 4.3%(56/1306) Conversion symptoms: 2.4%(15/636) vs 1.0%(13/1306) Decreased appetite: 18.1%(115/636) vs 11.4%(149/1306) Difficulty falling asleep: 28.8%(18.3/636) vs 22.9%(299/1306) Difficulty with micturition: 6.1%(39/636) vs 3.6%(47/1306) Drowsiness: 31.3%(199/636) vs 26.0%(339/1306) Dry mouth: 16.2%(103/636) vs 22.2%(290/1306) Early awakening: 24.1%(153/636) vs 15.9%(208/1306) Excessive appetite: 12.4%(79/636) vs 24.0%(313/1306) Heaviness in extremities: 16.4%(104/636) vs 11.5%(150/1306) Hot flashes: 5.7%(36/636) vs 3.4%(45/1306) Hypersalivation: 19.5%(124/636) vs 8.7%(113/1306) Hypertonia: 21.1%(134/636) vs 8.4%(110/1306) Hypokinesia: 13.5%(86/636) vs 5.1%(67/1306) Hypotonia: 4.6%(29/636) vs 2.7%(35/1306) Increased dreams/nightmares: 17.3%(110/636) vs 13.0%(170/1306) Increased perspiration: 13.2%(84/636) vs 6.8%(89/1306) Interrupted sleep: 30.3%(193/636) vs 19.0%(248/1306) Nausea: 13.7%(87/636) vs 10.1%(132/1306) Palpitations: 9.9%(63/636) vs 6.6%(86/1306) Shortened sleep: 24.8%(158/636) vs 15.1%(197/1306) Tremor: 26.3%(167/636) vs 16.5%(216/1306) Vomiting: 9.0%(57/636) vs 5.1%(67/1306) Weight change in kg: Haloperidol-636 people (0.02 mean,2.79 SD) vs Olanzapine-1306 people (1.88 mean,3.54 SD) | Haloperidol vs Olanzapine:Withdrawals: 53.2%(351/660) vs 33.6%(448/1336) Withdrawals due to adverse events: 7.3%(48/660) vs 4.5%(60/1336)
Dementia Olanzapine & Risperidone (Gareri P et al., 2004)^18^ Western Europe | Design: RCT Setting: NR Jadad: 3 | Inclusion criteria: Age ≥ 65 Exclusion criteria: NR | Promazine-50–100 mg/day flexible dose Risperidone-1–2 mg/day flexible dose Olanzapine-5–10 mg/day flexible dose Duration: 2.0 months | None 10 dy of Placebo for randomization not described | NR | Assessed at baseline and 8 weeks: NPI | 79/NR 45% male NR | NR/60/60 | 0/0/60 | Insufficient statistics for effect-size calculation. | Monitored | Promazine vs Risperidone vs Olanzapine: Abdominal pain: 0.0%(0/20) vs 4.0%(0.8/20) vs 0.0%(0/20) Akathisia: 0.0%(0/20) vs 0.0%(0/20) vs 4.0%(0.8/20) Arterial hypotension: 35.0%(7/20) vs 20.0%(4/20) vs 0.0%(0/20) Asthenia: 0.0%(0/20) vs 8.0%(1.6/20) vs 0.0%(0/20) Confusion: 15.0%(3/20) vs 0.0%(0/20) vs 0.0%(0/20) Constipation: 35.0%(7/20) vs 8.0%(1.6/20) vs 16.0%(3.2/20) Dizziness: 0.0%(0/20) vs 0.0%(0/20) vs 16.0%(3.2/20) Drowsiness: 10.0%(2/20) vs 20.0%(4/20) vs 32.0%(6.4/20) Dyspepsia: 0.0%(0/20) vs 12.0%(2.4/20) vs 0.0%(0/20) EPS: 20.0%(4/20) vs 8.0%(1.6/20) vs 0.0%(0/20) Hyperglycemia (glycemic decompensation): 0.0%(0/20) vs 0.0%(0/20) vs 4.0%(1/20) Increased libido and disinhibition: 0.0%(0/20) vs 4.0%(0.8/20) vs 0.0%(0/20) Insomnia: 0.0%(0/20) vs 4.0%(0.8/20) vs 0.0%(0/20) Nausea (sickness): 5.0%(1/20) vs 0.0%(0/20) vs 0.0%(0/20) Postural hypotension: 0.0%(0/20) vs 0.0%(0/20) vs 8.0%(1.6/20) Sinus tachycardia: 25.0%(5/20) vs 8.0%(1.6/20) vs 0.0%(0/20) Weight gain: 0.0%(0/20) vs 0.0%(0/20) vs 32.0%(6.4/20) Xerostomy: 30.0%(6/20) vs 0.0%(0/20) vs 0.0%(0/20) | Promazine vs Risperidone vs Olanzapine: Withdrawals: Not reported Withdrawals due to adverse events: 0.0%(0/20) vs 5.0%(1/20) vs 0.0%(0/20)
Depression Quetiapine (Altamura AC et al., 2003)^19^ Western Europe | Design: RCT Setting: Single center Jadad: 2 | Inclusion criteria: Previous depressed, manic, or mixed episode, CGI ≥ moderate severity, MMSE ≤ 23, PANSS ≥ 50, Stable on risperidone, PANSS with score ≥ 4 on at least 2 items on positive symptoms subscale, Exclusion criteria: Abnormal laboratory results, HIV dementia | Control-dosage not reported Quetiapine-157.7 mg/day average final dose Duration: 12.0 months | None None | Valproate, Lithium, Gabapentin | Assessed at baseline and 12 months: BPRS, CGI, YMRS, HAM_D_HDRS | 52/NR 43% male NR | NR/28/28 | 0/0/28 | Depression_mood Follow-up time greater than 48 weeks Depression_severity Follow-up time greater than 48 weeks | Monitored | Other mood stabilizers (lithium, valproate, gabapentin) vs Quetiapine: Constipation: 0.0%(0/14) vs 14.3%(2/14) Sedation: 0.0%(0/14) vs 14.3%(2/14) Weight gain: 14.3%(2/14) vs 0.0%(0/14) Weight change in kg: Other mood stabilizers (lithium, valproate, gabapentin)-14 people (1.79 mean, 1.31 SD) vs Quetiapine-14 people (1.08 mean, 1.26 SD) | Other mood stabilizers (lithium, valproate, gabapentin) vs Quetiapine: Withdrawals:.%(0/14) vs.%(0/14) Withdrawals due to adverse events: 0.0%(0/14) vs 0.0%(0/14)
Depression Risperidone (Muller-Siecheneder F et al., 1998)^20^ Western Europe | Design: RCT Setting: Multi-center Jadad: 4 | Inclusion criteria: Age 18–65, PANSS ≥ 60, PANSS with score ≥ 4 on at least 2 items on positive symptoms subscale, BRMS ≥ 15 with ≥3 on its depression item, Coexisting major depressive, paranoid and/or hallucinatory symptoms Exclusion criteria: Suicidal or violent, Severe internal or neurological disease, Abnormal laboratory results, Allergic or toxic reactions to psychotropic medications, Participation in previous clinical trial within 4 weeks, Pregnant, Lactating, | Haloperidol-9.0 mg/day average final dose, Amitriptyline- 180 mg Risperidone-6.9 mg/day average final dose Duration: 1.5 months | None 3 dy of Antipsychotics, Antidepressants for randomization not described | Anti-EPS medications, Benzodiazepines | Assessed at baseline and 6 weeks: PANSS, BPRS, BRMES, CGI | NR/19–63 38% male NR | NR/123/123 | 33/0/90 | Depression_mood-Change in BRMES at 6 weeks: Haloperidol + amitriptyline vs Risperidone-SMD = −0.427(−0.828,−0.026) | Monitored, elicited by investigator | Haloperidol + Amitriptyline vs Risperidone: Abdominal pain: 3.3%(2/61) vs 0.0%(0/62) Abnormal hepatic function: 16.4%(10/61) vs 4.8%(3/62) Agitation: 1.6%(1/61) vs 3.2%(2/62) Akathisia, tremor: 0.0%(0/61) vs 3.2%(2/62) Constipation: 11.5%(7/61) vs 8.1%(5/62) Dizziness: 1.6%(1/61) vs 3.2%(2/62) Dry mouth: 9.8%(6/61) vs 6.5%(4/62) Dysphagia: 0.0%(0/61) vs 3.2%(2/62) Dystonia, abdominal pain, constipation: 3.3%(2/61) vs 0.0%(0/62) Fatigue: 3.3%(2/61) vs 6.5%(4/62) Hyperprolactinemia: 3.3%(2/61) vs 1.6%(1/62) Hypotension: 6.6%(4/61) vs 0.0%(0/62) Nausea and/or vomiting: 3.3%(2/61) vs 6.5%(4/62) Speech disorder: 1.6%(1/61) vs 1.6%(1/62) Suicidal ideations: 3.3%(2/61) vs 1.6%(1/62) Tachycardia: 3.3%(2/61) vs 1.6%(1/62) | Haloperidol + Amitriptyline vs Risperidone: Withdrawals: 21.3%(13/61) vs 32.3%(20/62) Withdrawals due to adverse events: 11.5%(7/61) vs 21.0%(13/62)
Depression Risperidone (Shelton RC et al., 2004)^21^ US | Design: RCT Setting: NR Jadad: 4 | Inclusion criteria: Treatment = lithium, carbamazepine, or valproate at therapeutic level, HAM-D ≥ 18, YMRS ≤ 8, Medically stable Exclusion criteria: Current psychosis, Alcohol or substance abuse or dependency, Other psychotropic herbs, History of non-affective disorder | Paroxetine- 20–40 mg/day Risperidone-2.15 mg/day average final dose Risperidone-1.16 mg/day average final dose, Paroxetine- 20–40 mg/day Duration: 3.0 months | None None | Anticonvulsants, Carbamazepine, Divalproex, Lithium, Topiramate | Assessed at baseline and 12 weeks: HAM_D_HDRS, MADRS, BDI, CGI, YMRS | 36/NR 50% male NR | NR/30/30 | 9/2/30 | Depression_improvement-Change in CGI-I at 12 weeks: Paroxetine + placebo vs Risperidone + placebo-WMD = 0.7(−0.62,2.02) Depression_improvement-Change in CGI-I at 12 weeks: Paroxetine + placebo vs Risperidone + paroxetine-WMD = −0.7 (−1.805,0.405) Depression_mood-Change in MADRS at 12 weeks: Paroxetine + placebo vs Risperidone + placebo-SMD = 0.479(−0.656, 1.614) Depression_mood-Change in MADRS at 12 weeks: Paroxetine + placebo vs Risperidone + paroxetine-SMD = 0.272(−0.792,1.336) | Monitored | Paroxetine + placebo vs Risperidone + placebo vs Risperidone + paroxetine: Agitation: 0.0%(0/10) vs 0.0%(0/10) vs 10.0%(1/10) Anxiety: 0.0%(0/10) vs 10.0%(1/10) vs 0.0%(0/10) Appetite decrease: 10.0%(1/10) vs 0.0%(0/10) vs 0.0%(0/10) Appetite increase: 20.0%(2/10) vs 20.0%(2/10) vs 20.0%(2/10) Blurred vision: 0.0%(0/10) vs 0.0%(0/10) vs 10.0%(1/10) Constipation: 0.0%(0/10) vs 10.0%(1/10) vs 0.0%(0/10) Depression increased: 0.0%(0/10) vs 0.0%(0/10) vs 10.0%(1/10) Dermatitis: 0.0%(0/10) vs 10.0%(1/10) vs 0.0%(0/10) Diaphoresis: 10.0%(1/10) vs 10.0%(1/10) vs 0.0%(0/10) Diarrhea: 30.0%(3/10) vs 20.0%(2/10) vs 10.0%(1/10) Dizziness: 10.0%(1/10) vs 0.0%(0/10) vs 10.0%(1/10) Dreaming increased: 0.0%(0/10) vs 10.0%(1/10) vs 0.0%(0/10) Dry mouth: 30.0%(3/10) vs 10.0%(1/10) vs 10.0%(1/10) Edema: 0.0%(0/10) vs 10.0%(1/10) vs 0.0%(0/10) Fatigue: 20.0%(2/10) vs 20.0%(2/10) vs 10.0%(1/10) GI distress: 20.0%(2/10) vs 20.0%(2/10) vs 20.0%(2/10) Hair loss: 10.0%(1/10) vs 0.0%(0/10) vs 0.0%(0/10) Headache: 10.0%(1/10) vs 10.0%(1/10) vs 0.0%(0/10) Insomnia: 20.0%(2/10) vs 0.0%(0/10) vs 10.0%(1/10) Joint pain: 0.0%(0/10) vs 10.0%(1/10) vs 0.0%(0/10) Memory problems: 0.0%(0/10) vs 0.0%(0/10) vs 10.0%(1/10) Myoclonus: 0.0%(0/10) vs 10.0%(1/10) vs 0.0%(0/10) Nausea: 20.0%(2/10) vs 0.0%(0/10) vs 0.0%(0/10) Paresthesias: 0.0%(0/10) vs 0.0%(0/10) vs 10.0%(1/10) Salivation increased: 0.0%(0/10) vs 0.0%(0/10) vs 10.0%(1/10) Sexual dysfunction: 20.0%(2/10) vs 0.0%(0/10) vs 30.0%(3/10) Somnolence: 20.0%(2/10) vs 50.0%(5/10) vs 20.0%(2/10) Spaciness: 10.0%(1/10) vs 0.0%(0/10) vs 0.0%(0/10) Tremor: 10.0%(1/10) vs 10.0%(1/10) vs 10.0%(1/10) Urinary tract infection: 10.0%(1/10) vs 0.0%(0/10) vs 0.0%(0/10) Weight gain: 10.0%(1/10) vs 10.0%(1/10) vs 40.0%(4/10) | Paroxetine + placebo vs Risperidone + placebo vs Risperidone + paroxetine: Withdrawals: 20.0%(2/10) vs 50.0%(5/10) vs 40.0%(4/10) Withdrawals due to adverse events: 10.0%(1/10) vs 10.0%(1/10) vs 30.0%(3/10)
Dementia Risperidone (Weiser M et al., 2002)^22^ NR The Rivastigmine- Risperidone Study | Design: RCT Setting: Multi-center Jadad: 1 | Inclusion criteria: MMSE = 5–26, NPI/NH ≥ 3 Exclusion criteria: NR | Control-dosage not reported, Rivastigmine- 3 –12 mg/day Risperidone-0.8 mg/day average final dose Risperidone-0.8 mg/day average final dose, Rivastigmine, 3–12 mg/day Risperidone-0.8 mg/day average final dose, Rivastigmine- 3–12 mg/day Duration: 5.0 months | None None | Lorazepam | Assessed at baseline and 20 weeks: NPI, ADAS-cog | 75/NR 50% male NR | NR/90/85 | NR/NR/58 | Dementia_global-Change in NPI-12 at 20 weeks: Rivastigmine vs Risperidone-SMD = −0.918(−1.926,0.089) Dementia_global-Change in NPI-12 at 20 weeks: Rivastigmine vs Rivastigmine + risperidone-SMD = −0.956(−1.752,−0.161) Dementia_global-Change in NPI-12 at 20 weeks: Rivastigmine vs Risperidone + rivastigmine-SMD = −0.798(−1.903,0.308) | Monitored, reported by patient | Rivastigmine vs Risperidone vs Rivastigmine + risperidone vs Risperidone + rivastigmine: At least one adverse event: 79.0%(11.06/14) vs 92.0%(11.96/13) vs 87.0%(40.89/47) vs 94.0%(15.04/16) Abdominal pain: 14.0%(1.96/14) vs 0.0%(0/13) vs 6.0%(2.82/47) vs 6.0%(0.96/16) Anorexia: 0.0%(0/14) vs 0.0%(0/13) vs 9.0%(4.23/47) vs 19.0%(3.04/16) Diarrhea: 21.0%(2.94/14) vs 8.0%(1.04/13) vs 13.0%(6.11/47) vs 0.0%(0/16) General weakness: 14.0%(1.96/14) vs 8.0%(1.04/13) vs 21.0%(9.87/47) vs 44.0%(7.04/16) Nausea: 14.0%(1.96/14) vs 8.0%(1.04/13) vs 17.0%(7.99/47) vs 6.0%(0.96/16) Parkinsonism: 0.0%(0/14) vs 15.0%(1.95/13) vs 6.0%(2.82/47) vs 0.0%(0/16) Restlessness: 7.0%(0.98/14) vs 8.0%(1.04/13) vs 11.0%(5.17/47) vs 13.0%(2.08/16) Somnolence/drowsiness: 0.0%(0/14) vs 31.0%(4.03/13) vs 26.0%(12.22/47) vs 31.0%(4.96/16) Vomiting: 21.0%(2.94/14) vs 0.0%(0/13) vs 21.0%(9.87/47) vs 6.0%(0.96/16) Weight loss: 0.0%(0/14) vs 0.0%(0/13) vs 9.0%(4.23/47) vs 13.0%(2.08/16) | Rivastigmine vs Risperidone vs Rivastigmine + risperidone vs Risperidone + rivastigmine: Withdrawals: 30.0%(4.2/14) vs 30.0%(3.9/13) vs 30.0%(14.1/47) vs 62.0%(9.92/16) Withdrawals due to adverse events: 12.0%(1.68/14) vs 15.0%(1.95/13) vs 13.0%(6.11/47) vs 50.0%(8/16)
Personality Disorder Olanzapine (Zanarini MC et al., 2004)^23^ US | Design: RCT Setting: NR Jadad: 2 | Inclusion criteria: Age 18–40 Exclusion criteria: Fluoxetine successful treatment, Olanzapine successful treatment, Medically significant disorders, Seizure disorder or epilepsy or risk, Psychotropic medications, Alcohol or substance abuse or dependency, Suicidal or violent, Major depressive disorder | Fluoxetine- 15.0 mg/day average final dose Olanzapine-3.3 mg/day average final dose Olanzapine-3.2 mg/day average final dose, Fluoxetine- 12.7 mg/day average final dose Duration: 2.0 months | None None | NR | Assessed at baseline and 8 weeks: OAS-M, MADRS | 23/NR 0% male Caucasian, NOS | NR/45/45 | 2/1/1942 | Personality Disorder-Change in MADRAS at 8 weeks: Fluoxetine vs Olanzapine-SMD = −0.086(−0.818,0.646) Personality Disorder-Change in MADRAS at 8 weeks: Fluoxetine vs Olanzapine + fluoxetine-SMD = −0.286(−1.059,0.487) | Monitored, elicited by investigator | Fluoxetine vs Olanzapine vs Olanzapine + fluoxetine: Dizziness and headaches: 0.0%(0/14) vs 0.0%(0/16) vs 6.7%(1/15) Mild akathisia: 35.7%(5/14) vs 25.0%(4/16) vs 33.3%(5/15) Mild sedation: 21.4%(3/14) vs 75.0%(12/16) vs 46.7%(7/15) Other serious movement disorders: 0.0%(0/14) vs 0.0%(0/16) vs 0.0%(0/15) Suicide attempt: 7.1%(1/14) vs 0.0%(0/16) vs 0.0%(0/15) Tardive dyskinesia: 0.0%(0/14) vs 0.0%(0/16) vs 0.0%(0/15) Weight change in kg: Fluoxetine-14 people (0.4 mean,2.3 SD) vs Olanzapine-16 people (2.9 mean,2.6 SD) vs Olanzapine + Fluoxetine-15 people (1.4 mean,1.1 SD) | Fluoxetine vs Olanzapine vs Olanzapine + fluoxetine: Withdrawals: 7.1%(1/14) vs 0.0%(0/16) vs 13.3%(2/15) Withdrawals due to adverse events: 0.0%(0/14) vs 0.0%(0/16) vs 6.7%(1/15)
Tourettes Risperidone (Bruggeman R et al., 2001)^24^ Western Europe, South Africa | Design: RCT Setting: Multi-center Jadad: 5 | Inclusion criteria: Age 10–65, TSSS ≥ moderate severity, CGI ≥ moderate severity Exclusion criteria: NR | Pimozide-2.9 mg/day average final dose Risperidone-3.8 mg/day average final dose Duration: 3.0 months | None 2 wk for oral antipsychotics and antidepressants, A minimum of 1 treatment cycle for depot medication, At least 5 wks for fluoxetine, for randomization not described | Antiparkinson medication and benzodiazepine use was limited during treatment | Assessed at baseline and 12 weeks: TSSS, CGI, PGI, YBOCS, HAM_A, GAF | NR/11–50 88% male NR | NR/51/51 | 8/1/50 | Tourettes-Change in CGI-I at 12 weeks: Pimozide vs Risperidone-SMD = 0(− 0.555,0.555) | Monitored, reported by patient | Pimozide vs Risperidone: Depression: 25.0%(6/24) vs 30.8%(8/26) EPS-like adverse events: 33.3%(8/24) vs 15.4%(4/26) Fatigue: 37.5%(9/24) vs 38.5%(10/26) Headache: 8.3%(2/24) vs 19.2%(5/26) Hyperkinesia: 20.8%(5/24) vs 7.7%(2/26) Injuries: 25.0%(6/24) vs 3.8%(1/26) Insomnia: 29.2%(7/24) vs 3.8%(1/26) Somnolence: 41.7%(10/24) vs 46.2%(12/26) Weight gain: 83.3%(20/24) vs 84.6%(22/26) Weight gain & <18 years: 29.2%(7/24) vs 38.5%(10/26) Weight gain & ≥ 18 years: 54.2%(13/24) vs 46.2%(12/26) Weight change in kg: Pimozide-24 people (2.9 mean,1.8–4.1 RANGE) vs Risperidone-26 people (3.9 mean,3.0–4.9 RANGE) | Pimozide vs Risperidone: Withdrawals: 16.7%(4/24) vs 19.2%(5/26) Withdrawals due to adverse events: 8.3%(2/24) vs 15.4%(4/26)
Tourettes Risperidone (Gaffney GR et al., 2002)^25^ US | Design: RCT Setting: Single center Jadad: 3 | Inclusion criteria: Children and adolescents aged 7–17 years, Healthy, able to oral medication, able to adhere to required evaluation schedule Exclusion criteria: Epilepsy, Neurological disorder, Pregnant, Abnormal laboratory results | Risperidone-1.5 mg/day average final dose Clonidine-0.175 mg/day average final dose Duration: 2.0 months | 7–14 dy of Placebo/Randomization not described | None | Assessed at baseline and 8 weeks: Yale Global Tic, YBOCS, ADHDRS, CGI, MOVES, HAM_D_HDRS | 11/7–17 90% male NR | 24/21/21 | 1/0/21 | Tourettes-Change in CGI-S at 8 weeks: Clonidine vs Risperidone-SMD = 0(− 0.895,0.895) | Monitored | Clonidine vs Risperidone: At least one clinically significant adverse event: 58.0%(6.96/12) vs 33.0%(2.97/9) Dizziness: 17.0%(2/12) vs 11.0%(1/9) Drug-induced parkinsonism: 0.0%(0/12) vs 0.0%(0/9) Dry mouth: 8.0%(1/12) vs 0.0%(0/9) Sedation: 42.0%(5/12) vs 11.0%(1/9) Stiffness: 8.0%(1/12) vs 22.0%(2/9) Weight change in kg: Clonidine-12 people (Mean 0.1, SD 5.9) vs Risperidone-9 people (2.1 mean, SD 2.3) | Clonidine vs Risperidone: Withdrawals: 8.3%(1/12) vs 0.0%(0/9) Withdrawals due to adverse events: 0.0%(0/12) vs 0.0%(0/9)
Dementia, Depression and Agitation Olanzapine (Kinon BJ et al., 2005)^26^ US | Design: RCT Setting: NR Jadad: 2 | Inclusion criteria: NR Exclusion criteria: Tardive dyskinesia | Typical antipsychotics - dosed per package insert Olanzapine - 5.9 mg/day average final dose Duration: 12.0 months | 6 wk of Olanzapine and typical antipsychotics. Patients who remained without tardive dyskinesia proceed to randomization None | Not reported | Assessed at baseline and 1 years: Adverse events | 79/NR 48% male NR | NR/293/293 | 148/4/141 | No outcomes of interest to calculate effect size. | Monitored | Typical antipsychotics vs Olanzapine: Anemia: 4.2%(6/143) vs 10.7%(16/150) Apathy: 11.2%(16/143) vs 3.3%(5/150) Cardiovascular effects: 4.3%(6/143) vs 3.4%(5/149) Death: 16.1%(23/143) vs 14.8%(22/149) Skin ulcer: 11.9%(17/143) vs 3.3%(5/150) Weight loss: 23.1%(33/143) vs 11.3%(17/150) | Typical antipsychotics vs Olanzapine: Withdrawals: 55.2%(79/143) vs 46.0%(69/150) Withdrawals due to adverse events: 20.0%(29/143) vs 17.0%(26/150)
Depression Aripiprazole (Kasper S et al., 2003)^27^ US, Europe, other countries NOS | Design: RCT Setting: Multi-center Jadad: 2 | Inclusion criteria: Age 18–65, Male or female, Experiencing an acute relapse, PANSS ≥ 60, PANSS with score ≥ 4 on at least 1 items on positive symptoms subscale, Previous response to antipsychotics, Continuous outpatient treatment ≥ 3 month period during previous year Exclusion criteria: Pregnant, Lactating, Resistant to antipsychotic treatment, Suicidal or violent, Alcohol or substance abuse or dependency, Neurological disorder, Investigational drug use ≥ 4 wks, Psychiatric disorder, not including primary conditioned studied | Haloperidol - 8.90 mg/day average final dose Aripiprazole - 29.01 mg/day average final dose Duration: 13.0 months | None ≥ 5 dy of placebo for patients still eligible after washout | Anticholinergic medications, Anti-EPS medications | Assessed at baseline and 52 weeks: PANSS, MADRS, CGI, Extrapyramidel side effects | 37/NR 59% male NR | NR/1294/1294 | NR/NR/1283 | Depression_mood Follow-up time greater than 48 weeks. | Monitored, elicited by investigator, reported by patient, . | Haloperidol vs Aripiprazole: Agitation: 7.0%(30/431) vs 6.0%(53/859) Akathisia: 25.0%(108/431) vs 13.0%(111/859) Anxiety: 12.0%(50/431) vs 13.0%(108/859) Any AE: 87.0%(377/431) vs 78.0%(671/859) Extrapyramidal syndrome: 30.0%(130/431) vs 10.0%(84/859) Headache: 9.0%(38/431) vs 8.0%(65/859) Insomnia: 20.0%(88/431) vs 22.0%(185/859) Psychosis: 16.0%(70/431) vs 18.0%(156/859) Somnolence: 7.0%(32/431) vs 5.0%(43/859) Tremor: 10.0%(41/431) vs 4.0%(34/859) Weight gain: 3.0%(14/431) vs 5.0%(44/859) | Haloperidol vs Aripiprazole: Withdrawals: (NR/431) vs (NR/859) Withdrawals due to adverse events: 32.0%(138/431) vs 24.8%(213/859)
Depression Olanzapine (Corya SA et al., 2005)^28^ NR | Design: RCT Setting: Multi-center Jadad: 3 | Inclusion criteria: MMSE = 14–26, Age ≥ 18, CGI ≥ 4, MADRS ≥ 30% reduction at week 7, At least 1 SSRI treatment failure ≥ 6 weeks at therapeutic dose Exclusion criteria: Bipolar disorder, Psychotic disorder, Schizophrenia, Schizoaffective disorder, PTSD, Major depressive disorder with seasonal pattern, Dissociative disorder | Fluoxetine-37.5 mg/day average final dose Velanfaxine - 275.4 mg/day average final dose Olanzapine - 7.9 mg/day average final dose Olanzapine - 1 mg/day average final dose, Fluoxetine - 5 mg/day average final dose Olanzapine - 7.9 mg/day average final dose, Fluoxetine - 37.5 mg/day average final dose Duration: 3.0 months | 7 wk of Venlafaxine for randomization not described None | Benzodiazepines | Assessed at baseline and 12 weeks: MADRS, CGI, HAM_A, BPRS, Extrapyramidel side effects | 46/NR 28% male Caucasian, NOS | 807/483/483 | NR/10/365 | Insufficient statistics for effect-size calculation. | Monitored | Fluoxetine vs Venlafaxine vs Olanzapine vs Olanzapine/Flouxetine 1/5 vs Olanzapine/Flouxetine: Asthenia: 8.0%(5/60) vs 8.0%(5/59) vs 18.0%(11/62) vs 8.0%(4.7/59) vs 12.0%(29/243) Death: 0.0%(0/60) vs 0.0%(0/59) vs 0.0%(0/62) vs 0.0%(0/59) vs 0.4%(1/243) Dizziness: 10.0%(6/60) vs 5.0%(3/59) vs 10.0%(6.2/62) vs 22.0%(13/59) vs 14.0%(34/243) Dry mouth: 7.0%(4/60) vs 5.0%(3/59) vs 16.0%(10/62) vs 7.0%(4/59) vs 13.0%(32/243) Extrapyramidal symtoms: (NR/60) vs (NR/59) vs (NR/62) vs (NR/59) vs (NR/243) Headache: 17.0%(10/60) vs 17.0%(10/59) vs 10.0%(6/62) vs 24.0%(14/59) vs 10.0%(24/243) Increased appetite: 7.0%(4/60) vs 5.0%(3/59) vs 16.0%(10/62) vs 14.0%(8/59) vs 16.0%(39/243) Peripheral edema: 0.0%(0/60) vs 2.0%(1/59) vs 8.0%(5/62) vs 5.0%(3/59) vs 11.0%(27/243) Somnolence: 5.0%(3/60) vs 8.0%(5/59) vs 18.0%(11/62) vs 8.0%(5/59) vs 22.0%(53/243) Weight gain: 13.0%(8/60) vs 5.0%(3/59) vs 26.0%(16/62) vs 19.0%(11/59) vs 25.0%(61/243) | Fluoxetine vs Venlafaxine vs Olanzapine vs Olanzapine/Flouxetine 1/5 vs Olanzapine/Flouxetine: Withdrawals: 18.3%(11/60) vs 22.0%(13/59) vs 25.8%(16/62) vs 20.3%(12/59) vs 23.0%(56/243) Withdrawals due to adverse events: 5.0%(3/60) vs 1.7%(1/59) vs 8.1%(5/62) vs 3.4%(2/59) vs 11.9%(29/243)
Depression Olanzapine (Dunner DL et al., 2005)^29^ NR | Design: RCT Setting: Multi-center Jadad: 2 | Inclusion criteria: MADRS ≥ 20, CGI ≥ 4, At least 1 manic or mixed episode requiring treatment with mood stabilizer or antipsychotic Exclusion criteria: Suicidal or violent, Alcohol or substance abuse or dependency, Previous exposure to study drug, Previous failure or responded poorly to olanzapine, antidepressants or lamotrigine, Olanzapine + antidepressants treatment, Lamotrigine treatment, YMRS ≥ 15 | Lamotrigine - 150–200 mg/day flexible dos Olanzapine - 6–12 mg/day flexible dose, Fluoxetine - 25–50 mg/day flexible dose Duration: 6.3 months | None None | Not reported | Assessed at baseline and 25 weeks: CGI, MADRS, YMRS, BSI | 37/NR 40% male Caucasian, NOS | NR/410/410 | 189/84/393 | Depression_mood and Depression_severity not a comparison of interest. | Monitored | Lamotrigine vs Olanzapine/Flouxetine: Anxiety: 6.9%(14/205) vs 7.3%(15/205) Arthralgia: 5.9%(12/205) vs 1.5%(3/205) Back pain: 5.9%(12/205) vs 5.4%(11/205) Constipation: 3.9%(8/205) vs 5.4%(11/205) Death: 0.5%(1/205) vs 0.0%(0/205) Diarrhea: 5.9%(12/205) vs 5.9%(12/205) Disturbance in attention: 1.0%(2/205) vs 5.4%(11/205) Dizziness: 9.3%(19/205) vs 14.6%(30/205) Dry mouth: 5.9%(12/205) vs 17.1%(35/205) Fatigue: 6.9%(14/205) vs 9.3%(19/205) Headache: 10.8%(22/205) vs 12.7%(26/205) Increased appetite: 9.3%(19/205) vs 19.5%(40/205) Insomnia: 14.7%(30/205) vs 5.9%(12/205) Irritability: 7.4%(15/205) vs 2.9%(5.9/205) Lethargy: 1.5%(3/205) vs 5.9%(12/205) Nausea: 11.3%(23/205) vs 7.8%(16/205) Peripheral edema: 0.0%(0/205) vs 5.4%(11/205) Rash: 8.8%(18/205) vs 5.4%(11/205) Sedation: 2.9%(6/205) vs 14.1%(29/205) Somnolence: 9.3%(19/205) vs 21.0%(43/205) Tremor: 1.5%(3/205) vs 10.7%(22/205) Upper respiratory infection: 3.4%(7/205) vs 5.4%(11/205) Weight gain: 2.9%(6/205) vs 22.4%(46/205) | Lamotrigine vs Olanzapine/Flouxetine: Withdrawals: 41.4%(85/205) vs 50.7%(104/205) Withdrawals due to adverse events: 13.7%(28/205) vs 18.0%(37/205)
Depression Olanzapine (Shelton RC et al., 2005)^30^ US & Canada | Design: RCT Setting: Multi-center Jadad: 3 | Inclusion criteria: At least 1 SSRI treatment failure > 4 weeks at therapeutic dose, Nortriptyline treatment failure after week 7, MADRS ≥ 20 Exclusion criteria: BPRS positive item score ≥ 3, Pregnant, Lactating, ECT treatment history or requiring during study | Fluoxetine - 35.8 mg/day average final dose Nortriptyline - 103.5 mg/day average final dose Olanzapine - 8.3 mg/day average final dose Olanzapine - 8.5 mg/day average final dose, Fluoxetine - 36.5 mg/day average final dose Duration: 2.0 months | 7 wk of Nortriptyline for patients resistant to nortriptyline treatment 2–7 dy of ND for randomization not described | Lorazepam as long as it was not within 8 hours of psychiatric evaluation | Assessed at baseline and 8 weeks: MADRS, CGI, HAM_A, BPRS, Extrapyramidel side effects | 42/NR 32% male Caucasian, NOS | 946/500/500 | NR/17/500 | Depression_severity-Change in CGI-S at 8 weeks: Fluoxetine vs Olanzapine-WMD = 0.1(− 0.146,0.346) Depression_severity-Change in CGI-S at 8 weeks: Nortriptlyline vs Olanzapine-WMD = 0(− 0.306,0.306) | Monitored | Fluoxetine vs Nortriptyline vs Olanzapine vs Olanzapine/Fluxetine: Akathisia: (NR/142) vs (NR/68) vs (NR/144) vs (NR/146) Asthenia: (NR/142) vs (NR/68) vs (NR/144) vs (NR/146) Cardiovascular effects: (NR/142) vs (NR/68) vs (NR/144) vs (NR/146) Dyskinesia: (NR/142) vs (NR/68) vs (NR/144) vs (NR/146) Headache: (NR/142) vs (NR/68) vs (NR/144) vs (NR/146) Increased appetite: (NR/142) vs (NR/68) vs (NR/144) vs (NR/146) Insomnia: (NR/142) vs (NR/68) vs (NR/144) vs (NR/146) Nausea: (NR/142) vs (NR/68) vs (NR/144) vs (NR/146) Nervousness: (NR/142) vs (NR/68) vs (NR/144) vs (NR/146) Parkinsonian symptoms: (NR/142) vs (NR/68) vs (NR/144) vs (NR/146) Somnolence: (NR/142) vs (NR/68) vs (NR/144) vs (NR/146) Tremor: 2.1%(3/142) vs (NR/68) vs 4.9%(7/144) vs 11.6%(17/146) Weight gain: 0.0%(0/142) vs 0.0%(0/68) vs 4.3%(6/144) vs 7.8%(11/146) | Fluoxetine vs Nortriptyline vs Olanzapine vs Olanzapine/Fluxetine: Withdrawals: (NR/142) vs (NR/68) vs (NR/144) vs (NR/146) Withdrawals due to adverse events: 2.8%(4/142) vs 2.9%(2/68) vs 9.7%(14/144) vs 6.8%(10/146)
Tourettes Risperidone (Gilbert DL et al., 2004)^31^ US | Design: CCT, Crossover Setting: Multi-center Jadad: 5 | Inclusion criteria: Age 7–17, CGI ≥ 4 of tic severity score Exclusion criteria: Psychotic disorder, Alcohol or substance abuse or dependency, Pervasive developmental disorder, Eating disorders, Transient tic disorder, Medically significant disorders, Abnormal laboratory results, Sexually active females of child bearing age not using an effective contraceptive method | Pimozide - 4 mg/day average final dose Risperidone - 2 mg/day average final dose Duration: 3.0 months | 2 wk of placebo, randomization not described 2 wk of placebo after cross- over | Not reported | Assessed at baseline and 4 weeks: Yale Global Tic, CGI, TSSR, Extrapyramidel side effects | 11/7–17 79% male Caucasian, African-American | NR/19/19 | 1/1/2017 | Tourettes Crossover study. | Monitored | Adverse events not reported before crossover. | Pimozide vs Pimozide vs Risperidone vs Risperidone: Withdrawals: 0.0%(0/7) vs 0.0%(0/7) vs 8.3%(1/12) vs 8.3%(1/12) Withdrawals due to adverse events: 0.0%(0/7) vs 0.0%(0/7) vs 0.0%(0/12) vs 0.0%(0/12)

Acronyms in Evidence Table: CCT, Clinical control trial; kg, kilograms; lbs, pounds; ND, Not described; NOS, Not otherwise specified; NR, Not reported; RCT, Randomized control trial; RR, Risk ratio; SMD, Standard mean difference; WMD, Weighted mean difference

Outcomes: ABC, Aberrant Behavior Checklist; ACES, Agitation-Calmness Evaluation Scale; ADAS-cog, Alzheimer’s Disease Assessment Scale; ADHDRS, DuPaul Attention Deficit Hyperactivity Scale; ADL, Activities of Daily Life; AIAQ, Anger, Irritability, and Assault Questionnaire; ASI, Addiction Severity Index; BABS, Brown Assessment of Beliefs Scale; BAI, Beck Anxiety Index; BDHI, Buss-Durkee Hostility Index; BDI, Beck Depression Index; BDS, Blessed Dementia Scale; BEHAVE-AD, Behavioral Pathology in Alzheimer’s Disease Rating Scale; BPRS, Brief Psychiatric Rating Scale; BRMES, Bech-Rafaelsen Melancholia Scale; CAPS, Clinician Administered PTSD Scale; CDSS, Calgary Depression Scale for Schizophrenia; CES-D, Center for Epidemiologic Studies Depression Scale; CGI, Clinical Global Impression Scale; CMAI, Cohen-Mansfield Agitation Inventory; CM-PNB, Cohen-Mansfield Physically Non-Aggressive Behavior; CPRS, Children’s Psychiatric Rating Scale; CSDD, Cornell Scale for Depression in Dementia; CY-BOCS, Children’s Yale-Brown Obsessive-Compulsive Scale; DCM, Dementia Care Mapping; DES, Dissociative Experiences Scale; DTS, Davidson Trauma Scale; E-BEHAVE-AD, Empirical Behavioral Pathology in Alzheimer’s Disease Rating Scale; FAST, Functional Assessment Staging Rating Scale; GAF, Global Assessment of Functioning Scale; HAM-A, Hamilton Rating Scale for Anxiety; HAM-D/HDRS, Hamilton Rating Scale for Depression; IGT, Iowa Gambling Task; MADRS, Montgomery-Asberg Depression Rating Scale; MDRS, Mattis Dementia Rating Scale; MMSE, Mini-Mental State Examination; M-NCAS, Modified Strain in Nursing Care Assessment; MOSES, Multidimentional Observational Scale for Elderly Subjects; MOVES, Motor Tic, Obsessions, and Compulsions, Vocal Tic Evaluation Survey; N-CBRF, Nisonger Child Behavior Rating Scale; NIMH-OC, National Institute of Mental Health Obsessive-Compulsive Scale; NPI, Neuropsychiatric Inventory; NPI/NH, Neuropsychiatric Inventory/Nursing Home; NPI-Q, Neuropsychiatric Inventory Questionnaire; OAS-M, Overt Aggression Scale-Modified; PANSS, Positive and Negative Symptom Scale; PCL-M, Patient Checklist for PTSD--Military Version; PDC, Depression cluster; PDS, Progressive Deterioration Scale; PGDRS, Psychogeriatric Dependency Rating Scale; PGI, Patient Global Impressions; QLDS, Quality of Life in Depression Scale; Q-LES-Q, Quality of Life Enjoyment and Satisfaction Questionnaire; QLS, Quality of Life Scales; QUALID, Quality of Life in Late-Stage Dementia Scale; ROAS, Retrospective Overt Aggression Scale; SANS, Scale for the Assessment of Negative Symptoms; SCL-90, Symptom Checklist-90; SDS, Sheehan Disability Scale; SF-36, Medical Outcomes Study 36-Item Short-Form Health Survey; SIB, Severe Impairment Battery; SIB-Q, Self-injurious Behavior Questionnaire; SIP, Structured Interview for PTSD; SPQ, Schizotypal Personality Questionnaire; SPRINT, Short PTSD Rating Interview; STAS-AX, State-Trait Anger Expression Inventory; STAT-S, Spielberger State-Trait Anger Scale, state version; STAT-T, Spielberger State-Trait Anger Scale, trait version; TOP-8, Treatment Outcome PTSD Scale; TSSS, Tourette’s Syndrome Severity Scale; VAS, Visual Analog Scale; Y-BOCS, Yale-Brown Obsessive-Compulsive Scale; YGTSS, Yale Global Tic Severity Scale; YMRS, Young Mania Rating Scale

1 Malone, R. P., Cater, J., Sheikh, R. M., Choudhury, M. S., and Delaney, M. A. Olanzapine versus haloperidol in children with autistic disorder: an open pilot study. 2001;40: 8:887–94.

2 Meehan, K. M., Wang, H., David, S. R., Nisivoccia, J. R., Jones, B., Beasley, C. M. Jr, Feldman, P. D., Mintzer, J. E., Beckett, L. M., and Breier, A. Comparison of rapidly acting intramuscular olanzapine, lorazepam, and placebo: a double-blind, randomized study in acutely agitated patients with dementia. 2002;26: 4:494–504.

3 Ballard, C., Margallo-Lana, M., Juszczak, E., Douglas, S., Swann, A., Thomas, A., O’Brien, J., Everratt, A., Sadler, S., Maddison, C., Lee, L., Bannister, C., Elvish, R., and Jacoby, R. Quetiapine and rivastigmine and cognitive decline in Alzheimer’s disease: randomised double blind placebo controlled trial. 2005;330: 7496:874.

4 Chan, W. C., Lam, L. C., Choy, C. N., Leung, V. P., Li, S. W., and Chiu, H. F. A double-blind randomised comparison of risperidone and haloperidol in the treatment of behavioural and psychological symptoms in Chinese dementia patients. 2001;16: 12:1156–62.

5 De Deyn, P. P., Rabheru, K., Rasmussen, A., Bocksberger, J. P., Dautzenberg, P. L., Eriksson, S., and Lawlor, B. A. A randomized trial of risperidone, placebo, and haloperidol for behavioral symptoms of dementia. 99;53: 5:946–55.

6 Suh, G. H., Son, H. G., Ju, Y. S., Jcho, K. H., Yeon, B. K., Shin, Y. M., Kee, B. S., and Choi, S. K. A randomized, double-blind, crossover comparison of risperidone and haloperidol in Korean dementia patients with behavioral disturbances. 2004;12: 5:509–16.

7 David S, Jones B Alaka K Wright P. Intramuscular olanzapine demonstrates safety in acutely agitated patients with schizophrenia, bipolar mania, and dementia. 2002;5: Suppl 1:S83.

8 McEvoy, J., Lieberman, J., Green, A. I., Perkins, D., Hamer, R. M., Sharma, T., Zipursky, R., Kahn, R., Gur, R., Centorrino, F., Glick, I., Nemeroff, C., Rothchild, A., Strakowski, S., Tohen, M., Tollefson, G., and HGDH Study Group. Long-term efficacy and safety of atypical and conventional antipsychotic drugs in first episode schizophrenia: comparison of treatment with olanzapine and haloperidol.

9 Shelton, R. C., Tollefson, G. D., Tohen, M., Stahl, S., Gannon, K. S., Jacobs, T. G., Buras, W. R., Bymaster, F. P., Zhang, W., Spencer, K. A., Feldman, P. D., and Meltzer, H. Y. A novel augmentation strategy for treating resistant major depression. 2001;158: 1:131–4.

10 Tohen, M., Shelton, R., Tollefson, G. D., Stahl, S., Jacobs, T., and Gannon, K. S. Olanzapine plus fluoxetine: double-blind and open-label results in treatment-resistant major depressive disorder. 99;9: Suppl 5:S246.

11 Street JS, Tollefson GD, Tohen M, and et al. Olanzapine for psychotic conditions in the elderly. 2000;30:191–196.

12 Street, J. S., Kinon, F., and Stauffer, V. Olanzapine in dementia. In: Tran PV, ed. Olanzapine (Zyprexa): A Novel Antipsychotic. Philadelphia, PA: Lippincott Wiliams & Wilkins; 2000:416–426.

13 Satterlee, W. G., Reams, S. G., and Burns, P. R. et al. A clinical update on olanzapine treatment in schizophrenia and in elderly Alzheimer’s disease patients. 95;31:534.

14 Svestka J, Synek O. Does olanzapine have antidepressant effect? A double-blind, amitriptyline-controlled study. 2000;3: Suppl 1:S251.

15 Tohen, M., Baker, R. W., Altshuler, L. L., Zarate, C. A., Suppes, T., Ketter, T. A., Milton, D. R., Risser, R., Gilmore, J. A., Breier, A., and Tollefson, G. A. Olanzapine versus divalproex in the treatment of acute mania. 2002;159: 6:1011–7.

16 Tohen, M., Greil, W., Calabrese, J. R., Sachs, G. S., Yatham, L. N., Oerlinghausen, B. M., Koukopoulos, A., Cassano, G. B., Grunze, H., Licht, R. W., Dell’Osso, L., Evans, A. R., Risser, R., Baker, R. W., Crane, H., Dossenbach, M. R., and Bowden, C. L. Olanzapine versus lithium in the maintenance treatment of bipolar disorder: a 12-month, randomized, double-blind, controlled clinical trial. 2005;162: 7:1281–90.

17 Tollefson, G. D., Beasley, C. M. Jr., Tran, P. V., Street, J. S., and et al. Olanzapine versus haloperidol in the treatment of schizophrenia and schizoaffective and schizophreniform disorders: results of an international collaborative trial. 97;154: 4: 457–465.

18 Gareri, P., Cotroneo, A., Lacava, R., Seminara, G., Marigliano, N., Loiacono, A., and De Sarro, G. Comparison of the efficacy of new and conventional antipsychotic drugs in the treatment of behavioral and psychological symptoms of dementia (BPSD). 2004: 9:207–15.

19 Altamura, A. C., Salvadori, D., Madaro, D., Santini, A., and Mundo, E. Efficacy and tolerability of quetiapine in the treatment of bipolar disorder: preliminary evidence from a 12-month open-label study. 2003;76: 1–3:267–71.

20 Muller-Siecheneder, F., Muller, M. J., Hillert, A., Szegedi, A., Wetzel, H., and Benkert, O. Risperidone versus haloperidol and amitriptyline in the treatment of patients with a combined psychotic and depressive syndrome. 98;18: 2:111–20.

21 Shelton, R. C. and Stahl, S. M. Risperidone and paroxetine given singly and in combination for bipolar depression. 2004;65: 12:1715–9.

22 Weiser, M., Rotmensch, H. H., Korczyn, A. D., Hartman, R., Cicin-Sain, A., and Anand, R. A pilot, randomized, open-label trial assessing safety and pharmakokinetic parameters of co-administration of rivastigmine with risperidone in dementia patients with behavioral disturbances. 2002;17: 4:343–6.

23 Zanarini, M. C., Frankenburg, F. R., and Parachini, E. A. A preliminary, randomized trial of fluoxetine, olanzapine, and the olanzapine-fluoxetine combination in women with borderline personality disorder. 2004;65: 7:903–7.

24 Bruggeman, R., van der Linden, C., Buitelaar, J. K., Gericke, G. S., Hawkridge, S. M., and Temlett, J. A. Risperidone versus pimozide in Tourette’s disorder: a comparative double-blind parallel-group study. 2001;62: 1:50–6.

25 Gaffney, Gary R., Perry, Paul J., Lund, Brian C., Bever-Stille, Kristine A., Arndt, Stephan, and Kuperman, Samuel. Risperidone versus clonidine in the treatment of children and adolescents with tourette’s syndrome. 2002;41: 3: 330–336.

26 Kinon BJ, Stauffer VL, Kaiser CJ, Hay DP, and Kollack-Walker S. Incidence of presumptive tardive dyskinesia in elderly patients treated with olanzapine or conventional antipsychotics. International Congress of Parkinson’s Disease and Movement Disorders. 2005.

27 Kasper, S., Lerman, M. N., McQuade, R. D., Saha, A., Carson, W. H., Ali, M., Archibald, D., Ingenito, G., Marcus, R., and Pigott, T. Efficacy and safety of aripiprazole vs. haloperidol for long-term maintenance treatment following acute relapse of schizophrenia. 2003;6: 4:325–37.

28 Corya SA, Williamson D, Sanger TM, Briggs SD, Case M, and Tollefson G. A randomized, double-blind comparison of olanzapine/fluoxetine combination, olanzapine, fluoxetine and venlafaxine in treatment-resistant depression. 2005:1–9.

29 Dunner, D. L., Brown, E., Adams, D. H., Degenhardt, E., Tohen, M., and Houston, J. P. Olanzapine/fluoxetine combination versus lamotrigine in the long-term treatment of bipolar I depression. American College of Neuropsychopharmacology. 2005.

30 Shelton, R. C., Williamson, D. J., Corya, S. A., Sanger, T. M., Van Campen, L. E., Case, M., Briggs, S. D., and Tollefson, G. D. Olanzapine/fluoxetine combination for treatment-resistant depression: a controlled study of SSRI and nortriptyline resistance. 2005;66: 10:1289–97.

31 Gilbert, D. L., Batterson, J. R., Sethuraman, G., and Sallee, F. R. Tic reduction with risperidone versus pimozide in a randomized, double-blind, crossover trial. 2004;43: 2:206–14.

C3_ Evidence Tables

Placebo Control Trials

Condition, Drug Author, Year Country, Trial named | Study design Setting Quality (Jadad Score) | Eligibility criteria | Interventions (drug, dose, duration) | Run-in period/Randomization Method Wash-out period/Randomization Method | Allowed other medications | Method of outcome assessment Timing of assessment | Age mean/Age range Gender Ethnicity | Screened/Eligible/Enrolled | Withdrawn/Lost to FU/Analyzed | Results | Method of adverse events assessment | Adverse events reported | Total withdrawals Withdrawals due to adverse events
Autism Risperidone (McCracken JT et al., 2002)^1^ US RUPP Autism Study | Design: RCT Setting: Multi-center Jadad: 4 | Inclusion criteria: Age 5–17, Weight ≥ 15 kg, Mental age ≥ 18 mos, Behavioral disturbances, CGI ≥ moderate severity, ABC Irritability subscale ≥ 18, Exclusion criteria: Medically significant disorders, DSM-IV Axis I disorder, not including primary condition studied, Psychotropic medication for behavioral disturbances | Placebo-2.4 mg/day average final dose Risperidone-1.8 mg/day average final dose Duration: 2.0 months | None 2–4 week washout period for all psychotropics | Anticonvulsant agent for seizure control if no dose change in 4 wks and no seizures for at least 6 mos. | Assessed at baseline and 8 weeks: ABC, CGI | 9/5–17 81% male Caucasian, African-American, Hispanic, Asian, NOS | 270/101/101 | 18/3/101 | Autism-Change in ABC-I at 8 weeks: Placebo vs Risperidone-SMD = −1.24(−1.667, −0.814) | Monitored, elicited by investigator | Placebo vs Risperidone: Anxiety: 20%(10/51) vs 24%(12/49) Constipation: 12%(6/51) vs 29%(14/49) Decreased appetite: 10%(5/52) vs 6%(3/49) Diarrhea: 22%(11/51) vs 18%(9/49) Dizziness: 4%(2/51) vs 16%(8/49) Drooling: 6%(3/51) vs 27%(13/49) Drowsiness: 12%(6/51) vs 49%(24/49) Dry mouth: 10%(5/51) vs 18%(9/49) Dyskinesia: 6%(3/51) vs 12%(6/49) Earache: 8%(4/51) vs 4%(2/49) Elevated serum glutamic-pyruvic transaminase level: 2%(1/51) vs 0%(0/49) Enuresis: 29%(15/51) vs 31%(15/49) Fatigue: 27%(14/51) vs 59%(29/49) Fever in association with a documented, time-limited illness: 20%(10/51) vs 16%(8/49) Headache: 12%(6/51) vs 18%(9/49) Increased appetite (mild): 25%(13/51) vs 49%(24/49) Increased appetite (moderate): 4%(2/51) vs 24%(12/49) Increased thirst: 10%(5/51) vs 12%(6/49) Insomnia: 29%(15/51) vs 14%(7/49) Muscle rigidity: 2%(1/51) vs 10%(5/49) Nasal congestion: 39%(20/51) vs 51%(25/49) Nausea: 10%(5/51) vs 8%(4/49) Nonspecific, clinically insignificant change in cardiac conduction: 2%(1/51) vs 0%(0/49) Restlessness: 6%(3/51) vs 6%(3/49) Serum glutamic-oxaloacetic transaminase more than twice upper limit of normal range at 8 wks: 2%(1/51) vs 2%(1/49) Skin irritation: 14%(7/51) vs 22%(11/49) Sleep problems: 18%(9/51) vs 22%(11/49) Sore throat: 2%(1/51) vs 10%(5/49) Stomachache: 18%(9/51) vs 10%(5/49) Tachycardia: 2%(1/51) vs 12%(6/49) Tremor: 2%(1/51) vs 14%(7/49) Upper respiratory tract infection: 4%(2/51) vs 10%(5/49) Vomiting: 24%(12/51) vs 33%(16/49) Weight change in kg: Placebo-51 people (0.8 mean,2.2 SD) vs Risperidone-49 people (2.7 mean,2.9 SD) | Placebo vs Risperidone: Withdrawals: 35.3%(18/51) vs 6.1%(3/49) Withdrawals due to adverse events: 2.0%(1/51) vs 0.0%(0/49)
Autism Risperidone (Shea S et al., 2004)^2^ Canada RIS-CAN-23 Study | Design: RCT Setting: Multi-center Jadad: 5 | Inclusion criteria: Healthy, Age 5–12, CARS ≥ 30 with or without mental retardation, DSM-IV Axis I diagnosis of PDD Exclusion criteria: Psychotic disorder, Medically significant disorders, Abnormal laboratory results, Seizure disorder, Allergic or toxic reactions to antipsychotic medications, Tardive dyskinesia, Neuroleptic malignant syndrome, Alcohol or substance abuse, Schizophrenia or other psychotic disorders, HIV, Risperidone used in last 3 mos, Previously unresponsive or intolerant to Risperidone | Placebo-dosage not reported Risperidone-1.48 mg/day average final dose Duration: 2.0 months | None None | Anticholinergic medications, Anti-asthmatics, A single anticonvulsant and medications for sleep or anxiety if doses of each had been stable for at least 30 days | Assessed at baseline and 8 weeks: ABC, N-CBRF, CGI, VAS | 7.5 77% male Caucasian, African-American, NOS | NR/80/79 | 7/0/79 | Autism-Change in ABC-I at 8 weeks: Placebo vs Risperidone-SMD = −0.932(−1.403, −0.461) | Monitored | Placebo vs Risperidone: At least one adverse event: 79.5%(31/39) vs 100.0%(40/40) Abdominal pain: 7.7%(3/39) vs 20.0%(8/40) Abnormal gait: 2.6%(1/39) vs 0.0%(0/40) Accidental overdose: 2.6%(1/39) vs 2.5%(1/40) Aggressive reaction with impaired concentration (severe): 0.0%(0/39) vs 2.5%(1/40) Anorexia: 2.6%(1/39) vs 10.0%(4/40) Apathy: 0.0%(0/39) vs 12.5%(5/40) Ataxia: 2.6%(1/39) vs 0.0%(0/40) Constipation: 2.6%(1/39) vs 12.5%(5/40) Coughing: 10.3%(4/39) vs 15.0%(6/40) Diarrhea: 15.4%(6.006/39) vs 0.0%(0/40) Dyskinesia: 2.6%(1/39) vs 0.0%(0/40) EPS: 12.8%(5/39) vs 27.5%(11/40) Emotional liability: 15.4%(6.006/39) vs 0.0%(0/40) Extrapyramidal disorder: 0.0%(0/39) vs 5.0%(2/40) Extrapyramidal disorder due to accidental overdose (severe): 0.0%(0/39) vs 2.5%(1/40) Fatigue: 2.6%(1/39) vs 10.0%(4/40) Fever: 17.9%(7/39) vs 20.0%(8/40) Headache: 5.1%(2/39) vs 12.5%(5/40) Hyperkinesia and somnolence (severe): 0.0%(0/39) vs 2.5%(1/40) Hypertonia: 2.6%(1/39) vs 0.0%(0/40) Hypokinesia: 5.0%(2/39) vs 0.0%(0/40) Increased appetite: 10.3%(4/39) vs 22.5%(9/40) Influenza-like symptoms: 5.1%(2/39) vs 10.0%(4/40) Insomnia: 15.4%(6/39) vs 15.0%(6/40) Insomnia & sunken eyes (severe): 2.6%(1/39) vs 0.0%(0/40) Involuntary muscle contractions: 2.6%(1/39) vs 0.0%(0/40) Rhinitis: 10.3%(4/39) vs 27.5%(11/40) Saliva increased: 2.6%(1/39) vs 10.0%(4/40) Somnolence: 7.7%(3/39) vs 72.5%(29/40) Somnolence (severe): 0.0%(0/39) vs 2.5%(1/40) Tachycardia: 0.0%(0/39) vs 12.5%(5/40) Tardive dyskinesia: 2.6%(1/39) vs 0.0%(0/40) Tremor: 0.0%(0/39) vs 10%(4/40) Upper respiratory tract infection: 15.4%(6/39) vs 37.5%(15/40) Vomiting: 15.4%(6/39) vs 15.0%(6/40) Weight increase: 2.6%(1/39) vs 10.0%(4/40) Weight increase (severe): 0.0%(0/39) vs 2.5%(1/40) Weight change in kg: Placebo-39 people (1.0 mean,1.6 SD) vs Risperidone-40 people (2.7 mean,2.0 SD) | Placebo vs Risperidone: Withdrawals: 12.8%(5/39) vs 5.0%(2/40) Withdrawals due to adverse events: 2.6%(1/39) vs 2.5%(1/40)
Dementia and Agitation Olanzapine (De Deyn PP et al., 2004)^3^ Europe, Australia/NZ, South Africa F1D-MC-HGIV Study | Design: RCT Setting: Multi-center Jadad: 2 | Inclusion criteria: Age ≥ 40, Hospitalized/institutionalized, Psychosis/psychotic features, MMSE = 5–26 Exclusion criteria: DSM-IV Axis I disorder, not including primary condition studied | Placebo-dosage not reported Olanzapine-1.0 mg/day fixed single dose Olanzapine-2.5 mg/day fixed single dose Olanzapine-5.0 mg/day fixed titration schedule Olanzapine-7.5 mg/day fixed titration schedule Duration: 2.5 months | 14 wk of Placebo for randomization not described None | Benzodiazepines, Sedative/hypnotics | Assessed at baseline and 10 weeks: NPI-NH, CGI, BPRS, MMSE, SIB | 77/NR 25% male Caucasian, NOS | NR/652/NR | NR/NR/NR | Dementia_agitation-Change in NPI-NH (agitation) at 10 weeks: Placebo vs Olanzapine 1 mg/d-SMD = −0.142(−0.387,0.103) Dementia_agitation-Change in NPI-NH (agitation) at 10 weeks: Placebo vs Olanzapine 2.5 mg/d-SMD = −0.114 (−0.356,0.128) Dementia_agitation-Change in NPI-NH (agitation) at 10 weeks: Placebo vs Olanzapine 5 mg/d-SMD = −0.114(−0.361,0.134) Dementia_agitation-Change in NPI-NH (agitation) at 10 weeks: Placebo vs Olanzapine 7.5mg/d-SMD = −0.142(−0.387,0.103) Dementia_global-Change in NPI-NH (total) at 10 weeks: Placebo vs Olanzapine 1 mg/d-SMD = 0.042(−0.203,0.287) Dementia_global-Change in NPI-NH (total) at 10 weeks: Placebo vs Olanzapine 2.5 mg/d-SMD = −0.047 (−0.289,0.194) Dementia_global-Change in NPI-NH (total) at 10 weeks: Placebo vs Olanzapine 5 mg/d-SMD = −0.053(−0.3,0.194) Dementia_global-Change in NPI-NH (total) at 10 weeks: Placebo vs Olanzapine 7.5mg/d-SMD = −0.1(−0.345,0.145) Dementia_psychosis-Change in NPI-NH (psychosis) at 10 weeks: Placebo vs Olanzapine 1 mg/d-SMD = −0.12(−0.365,0.124) Dementia_psychosis-Change in NPI-NH (psychosis) at 10 weeks: Placebo vs Olanzapine 2.5 mg/d-SMD = −0.281(−0.524, −0.038) Dementia_psychosis-Change in NPI-NH (psychosis) at 10 weeks: Placebo vs Olanzapine 5 mg/d-SMD = −0.12(−0.368,0.127) Dementia_psychosis-Change in NPI-NH (psychosis) at 10 weeks: Placebo vs Olanzapine 7.5mg/d-SMD = −0.261(−0.506, −0.015) | Monitored, reported by patient | Data not reported by intervention group. | Placebo vs Olanzapine 1 mg/d vs Olanzapine 2.5 mg/d vs Olanzapine 5 mg/d vs Olanzapine 7.5mg/d: Withdrawals: 29.5%(38/129) vs 34.1%(44/129) vs 24.6%(33/134) vs 24.8%(31/125) vs 28.8%(38/132) Withdrawals due to adverse events: 3.9%(5/129) vs 9.3%(12/129) vs 6.7%(9/134) vs 7.2%(9/125) vs 9.8%(13/132)
Dementia and Agitation Olanzapine (Street JS et al., 2000)^4^ US HGEU Study | Design: RCT Setting: Multi-center Jadad: 5 | Inclusion criteria: NPI/NH ≥ 3 Exclusion criteria: DSM-IV Axis I disorder, not including primary condition studied, Neurological conditions, excluding Alzheimers or vascular dementia, contributing to psychosis or dementia, MMSE > 24, Bedridden, Anticholinergic medications, Mood stabilizers, Antipsychotics other than the ones studied, Tricyclic antid | Placebo-dosage not reported Olanzapine-5 mg/day fixed single dose Olanzapine-10 mg/day fixed titration schedule Olanzapine-15 mg/day fixed titration schedule Duration: 1.5 months | 3–14 dy of Placebo for non-placebo responders None | Benzodiazepines | Assessed at baseline and 6 weeks: NPI-NH, BPRS, MMSE | 83/61–97 39% male Caucasian, African-American, Hispanic, NOS | 288/206/206 | 54/0/152 | Dementia_agitation-Change in NPI-NH (agitation) at 6 weeks: Placebo vs Olanzapine 5 mg/d-SMD = − 0.284(− 0.68,0.112) Dementia_agitation-Change in NPI-NH (agitation) at 6 weeks: Placebo vs Olanzapine 10 mg/d-SMD = − 0.227(− 0.633,0.179) Dementia_agitation-Change in NPI-NH (agitation) at 6 weeks: Placebo vs Olanzapine 15 mg/d-SMD = − 0.142(− 0.542,0.258) Dementia_global-Change in NPI-NH (total) at 6 weeks: Placebo vs Olanzapine 5 mg/d-SMD = − 0.463(− 0.862, − 0.063) Dementia_global-Change in NPI-NH (total) at 6 weeks: Placebo vs Olanzapine 10 mg/d-SMD = − 0.447(− 0.857, − 0.037) Dementia_global-Change in NPI-NH (total) at 6 weeks: Placebo vs Olanzapine 15 mg/d-SMD = − 0.131(− 0.531,0.268) Dementia_psychosis-Change in NPI-NH (psychosis) at 6 weeks: Placebo vs Olanzapine 5 mg/d-SMD = − 0.642(− 1.046, − 0.238) Dementia_psychosis-Change in NPI-NH (psychosis) at 6 weeks: Placebo vs Olanzapine 10 mg/d-SMD = − 0.441(− 0.851, − 0.032) Dementia_psychosis-Change in NPI-NH (psychosis) at 6 weeks: Placebo vs Olanzapine 15 mg/d-SMD = − 0.301(− 0.702,0.1) | Monitored | Placebo vs Olanzapine 5 mg/d vs Olanzapine 10 mg/d vs Olanzapine 15 mg/d: Abnormal gait: 2.1%(1/47) vs 19.6%(11/56) vs 14.0%(7/50) vs 17.0%(9/53) Accidental injury: 27.7%(13/47) vs 25.0%(14/56) vs 24.0%(12/50) vs 37.7%(20/53) Agitation: 8.5%(4/47) vs 8.9%(5/56) vs 12.0%(6/50) vs 11.3%(6/53) Anorexia: 8.5%(4/47) vs 1.8%(1/56) vs 4.0%(2/50) vs 15.1%(8/53) Cough increased: 6.4%(3/47) vs 12.5%(7/56) vs 10.0%(5/50) vs 7.5%(4/53) Ecchymosis: 14.9%(7/47) vs 8.9%(5/56) vs 12.0%(6/50) vs 15.1%(8/53) Fever: 2.1%(1/47) vs 8.9%(5/56) vs 14.0%(7/50) vs 13.2%(7/53) Nervousness: 4.3%(2/47) vs 7.1%(4/56) vs 12.0%(6/50) vs 1.9%(1/53) Pain: 10.6%(5/47) vs 14.3%(8/56) vs 12.0%(6/50) vs 24.5%(13/53) Peripheral edema: 6.4%(3/47) vs 3.6%(2/56) vs 12.0%(6/50) vs 7.5%(4/53) Somnolence: 6.4%(3/47) vs 25.0%(14/56) vs 26.0%(13/50) vs 35.8%(19/53) Weight loss: 6.4%(3/47) vs 0.0%(0/56) vs 4.0%(2/50) vs 11.3%(6/53) | Placebo vs Olanzapine 5 mg/d vs Olanzapine 10 mg/d vs Olanzapine 15 mg/d: Withdrawals: 23.4%(11/47) vs 19.6%(11/56) vs 28.0%(14/50) vs 34.0%(18/53) Withdrawals due to adverse events: 4.3%(2/47) vs 10.7%(6/56) vs 8.0%(4/50) vs 17.0%(9/53)
Dementia and Agitation Olanzapine & Risperidone (Ruths S et al., 2004)^5^ Western Europe | Design: RCT Setting: Single center Jadad: 4 | Inclusion criteria: Nursing home resident, Age ≥ 65, Risperidone, olanzapine or haloperidol treatment ≥ 3 months, Resident ≥ 3 months before enrollment Exclusion criteria: Psychotic disorder, Mental retardation, Terminal illness, Recent major changes in health status | Continued tx w/risperidone, olanzapine, or halperidol Withdrawal from risperidone, olanzapine, or halperidol Duration: 1.0 month | 3–44 mo of Haloperidol, Risperidone, Olanzapine for patients who met study criteria None | Antidepressants, sedative/Hypnotic, Anxiolytics, Anticholinergic medications, Narcotic analgesics | Assessed at baseline and 4 weeks: NPI-Q, Sleep disorders | 83/NR 20% male NR | 51/30/30 | 0/0/30 | Rejected from meta-analysis because outcomes were measured at less than 6 weeks of follow-ups. | Monitored | Data not reported by intervention group. | Placebo vs Haloperidol, Risperidone, or Olanzapine: Withdrawals: Not reported Withdrawals due to adverse events: Not reported
Dementia and Agitation Quetiapine (Zhong X et al., 2004)^6^ US | Design: RCT Setting: Multi-center Jadad: 2 | Inclusion criteria: NR Exclusion criteria: NR | Placebo-dosage not reported Quetiapine-100 mg/day fixed titration schedule Quetiapine-200 mg/day fixed titration schedule Duration: 2.5 months | None None | NR | Assessed at baseline and 10 weeks: PANSS, CGI | 83/NR NR NR | NR/333/NR | NR/NR/NR | Insufficient statistics for effect-size calculation. | Monitored | Placebo vs Quetiapine 200 mg/d vs Quetiapine 100 mg/d: Death: 1.1%(0.913/83) vs 1.7%(2.125/125) vs 0.6%(0.75/125) | Placebo vs Quetiapine 200 mg/d vs Quetiapine 100 mg/d: Withdrawals: Not reported Withdrawals due to adverse events: Not reported
Dementia and Agitation Risperidone (Ballard CG et al., 2004)^7^ UK | Design: RCT Setting: Multi-center Jadad: 3 | Inclusion criteria: Neuroleptics ≥ 3 months (median prescription time > 1 yr), Age >65, Clinical Dementia Rating Scale ≥ 1 Exclusion criteria: NPI > 7 | Placebo-dosage not reported Active tx (risperidone, thioridazine, haloperidol, chlorpromazine, or trifluoperazine Duration: 3.0 months | None None | NR | Assessed at baseline and 3 months: NPI, DCM | 83/NR 19% male NR | NR/100/100 | 28/0/NR | Not a comparison of interest for statistical analysis. | Monitored, elicited by investigator | Placebo vs Active treatment (risperidone, thioridazine, haloperidol, trifluoperazine, chlorpromazine): Death: 7.0%(3/46) vs 6.0%(3/54) | Placebo vs Active treatment (risperidone, thioridazine, haloperidol, trifluoperazine, chlorpromazine): Withdrawals: 30.0%(14/46) vs 26.0%(14/54) Withdrawals due to adverse events: Not reported
Dementia and Agitation Risperidone (Brodaty H et al., 2003)^8^ Australia/New Zealand | Design: RCT Setting: Multi-center Jadad: 3 | Inclusion criteria: Age ≥ 55, FAST ≥ 4, MMSE ≤ 23, CMAI score of ≥ 4 on at least 1 aggressive item or a score of 3 on at least 2 aggressive items, or a score of 2 on at least 3 aggressive items, or 2 aggressive items occurring at a frequency of 2 and 1 at a frequency of 3, Nursing home resident, Resident ≥ 1 month prior to enrollment Exclusion criteria: Neurological or medical conditions diminishing cognitive function, Dementia other than primary condition, Major depressive disorder, Psychotic disorder, Tardive dyskinesia, Medically significant disorders, Abnormal laboratory results, Depot neuroleptic within 2 treatment cycles | Placebo-1.06 mg/day average final dose Risperidone-0.95 mg/day average final dose Duration: 3.0 months | None 7 dy of Psychotropics, Placebo for patients who completed the wash-out period | Anti-EPS medications, Benzodiazepines, Tricyclic antidepressants, anticholinergic medications, short-acting sedative/hypnotic agents, and narcotic analgesics | Assessed at baseline and 12 weeks: CMAI, BEHAVE-AD, FAST, MMSE, CGI | 83/NR 28% male NR | 384/345/345 | 101/0/236 | Dementia_agitation-Change in BEHAVE-AD (aggressiveness) at 12 weeks: Placebo vs Risperidone-SMD = −0.538(−0.768, −0.308) Dementia_global-Change in BEHAVE-AD (total) at 12 weeks: Placebo vs Risperidone-SMD = −0.421(−0.682, −0.160) | Monitored, reported by patient, clinical examination | Placebo vs Risperidone: Aggressive reaction: 10.6%(18/170) vs 5.4%(9/167) Agitation: 24.7%(42/170) vs 19.8%(33/167) Cerebrovascular adverse event: 1.8%(3/170) vs 9.0%(15/167) Conjunctivitis: 10.6%(18/170) vs 12.0%(20/167) Constipation: 15.3%(26/170) vs 11.4%(19/167) Coughing: 2.9%(5/170) vs 5.4%(9/167) Death: 2.4%(4/170) vs 3.6%(6/167) Diarrhea: 12.9%(22/170) vs 3.0%(5/167) Dyskinesia: 5.3%(9/170) vs 0.6%(1/167) Edema peripheral: 3.5%(6/170) vs 7.8%(13/167) Extrapyramidal disorder: 2.9%(5/170) vs 6.0%(10/167) Falls: 27.1%(46/170) vs 25.1%(42/167) Fever: 2.4%(4/170) vs 5.4%(9/167) Gait abnormal: 1.2%(2/170) vs 6.0%(10/167) Headache: 6.5%(11/170) vs 4.8%(8/167) Infection: 7.1%(12/170) vs 3.6%(6/167) Injury: 37.1%(63/170) vs 35.9%(60/167) Life-threatening, requiring hospitalization or resulting in significant disability or incapacity.: 8.8%(15/170) vs 16.8%(28/167) Purpura: 15.9%(27/170) vs 18.0%(30/167) Rash: 5.3%(9/170) vs 7.8%(13/167) Skin disorder: 9.4%(16/170) vs 10.8%(18/167) Skin ulceration: 6.5%(11/170) vs 7.2%(12/167) Somnolence: 25.3%(43/170) vs 36.5%(61/167) Stroke: 0.0%(0/170) vs 3.0%(5/167) TIA: 0.0%(0/170) vs 0.6%(1/167) Total patients with adverse events: 92.4%(157/170) vs 94.0%(157/167) Tremor: 1.8%(3/170) vs 6.0%(10/167) Upper respiratory tract infection: 8.8%(15/170) vs 7.8%(13/167) Urinary tract infection: 14.7%(25/170) vs 23.4%(39/167) Vomiting: 7.6%(13/170) vs 8.4%(14/167) | Placebo vs Risperidone: Withdrawals: 32.9%(56/170) vs 26.9%(45/167) Withdrawals due to adverse events: 8.2%(13.94/170) vs 13.2% (22.044/167)
Dementia and Agitation Risperidone (Katz IR et al., 1999)^9^ US The Risperidone Study | Design: RCT Setting: Multi-center Jadad: 4 | Inclusion criteria: Age ≥ 55, FAST ≥ 4, MMSE ≤ 23, BEHAVE-AD ≥ 8, BEHAVE-AD global rating ≥ 1 Exclusion criteria: Untreated reversible causes of dementia, Neurological or medical conditions diminishing cognitive function, HIV dementia, Substance induced dementia, Delirium, Amnestic disorder, Psychiatric diagnosis for psychotic disturbances | Placebo-dosage not reported Risperidone-0.5 mg/day in divided doses, Risperidone-1 mg/day fixed titration schedule in divided doses Risperidone-2 mg/day fixed titration schedule in divided doses Duration: 3.0 months | None 3–7 dy of Placebo for randomization not described | Benztropine, lorzepam, chloral hydrate | Assessed at baseline and 12 weeks: BEHAVE-AD, CMAI, CGI, MMSE | 83/NR 32% male Caucasian, NOS | 729/625/625 | 190/0/435 | Dementia_agitation-Change in BEHAVE-AD (aggressiveness) at 12 weeks: Placebo vs Risperidone 0.5mg/d-SMD = −0.351(−0.609, −0.093) Dementia_agitation-Change in BEHAVE-AD (aggressiveness) at 12 weeks: Placebo vs Risperidone 1 mg/d-SMD = −0.602(−0.872, −0.331) Dementia_agitation-Change in BEHAVE-AD (aggressiveness) at 12 weeks: Placebo vs Risperidone 2 mg/d-SMD = −0.752(−1.029, −0.475) Dementia_global-Change in BEHAVE-AD (total) at 12 weeks: Placebo vs Risperidone 0.5mg/d-SMD = −0.19(−0.446,0.066) Dementia_global-Change in BEHAVE-AD (total) at 12 weeks: Placebo vs Risperidone 1 mg/d-SMD = −0.332(−0.599, −0.065) Dementia_global-Change in BEHAVE-AD (total) at 12 weeks: Placebo vs Risperidone 2 mg/d-SMD = −0.601(−0.875, −0.327) Dementia_psychosis-Change in BEHAVE-AD (psychosis) at 12 weeks: Placebo vs Risperidone 0.5mg/d-SMD = −0.051(−0.307, 0.204) Dementia_psychosis-Change in BEHAVE-AD (psychosis) at 12 weeks: Placebo vs Risperidone 1 mg/d-SMD = −0.154(−0.419,0.111) Dementia_psychosis-Change in BEHAVE-AD (psychosis) at 12 weeks: Placebo vs Risperidone 2 mg/d-SMD = −0.385(−0.656, −0.115) Dementia_severity-Change in CGI-S at 12 weeks: Placebo vs Risperidone 1 mg/d-WMD = −0.4(−0.596, −0.204) Dementia_severity-Change in CGI-S at 12 weeks: Placebo vs Risperidone 2 mg/d-WMD = −0.5(−0.698, −0.302) | Monitored, reported by patient | Placebo vs Risperidone 0.5mg/d vs Risperidone 1 mg/d vs Risperidone 2 mg/d: Experienced 1 or more serious adverse events during the trial or in the subsequent 30 days.: 12.9%(21/163) vs 10.7%(16/149) vs 16.2%(24/148) vs 17.6%(29/165) At least one adverse event: 84.7%(138/163) vs 83.9%(125/149) vs 81.8%(121/148) vs 88.5%(146/165) Agitation: 10.4%(17/163) vs 7.4%(11/149) vs 5.4%(8/148) vs 8.5%(14/165) Coughing: 8.0%(13/163) vs 10.7%(16/149) vs 5.4%(8/148) vs 8.5%(14/165) Death: 3.1%(5/163) vs 4.0%(6/149) vs 8.8%(13/148) vs 3.6%(6/165) Extrapyramidal disorder: 7.4%(12/163) vs 6.7%(10/149) vs 12.8%(19/148) vs 21.2%(35/165) Falls: 20.2%(33/163) vs 16.1%(24/149) vs 12.8%(19/148) vs 24.8%(41/165) Fever: 7.4%(12/163) vs 10.1%(15/149) vs 7.4%(11/148) vs 14.5%(24/165) Injury: 37.4%(61/163) vs 32.9%(49/149) vs 28.4%(42/148) vs 31.5%(52/165) Pain: 8.0%(13/163) vs 8.1%(12/149) vs 2.7%(4/148) vs 10.3%(17/165) Peripheral edema: 5.5%(9/163) vs 16.1%(24/149) vs 12.8%(19/148) vs 18.2%(30/165) Purpura: 11.7%(19/163) vs 16.8%(25/149) vs 12.2%(18/148) vs 10.3%(17/165) Rhinitis: 5.5%(9/163) vs 4.7%(7/149) vs 6.1%(9/148) vs 10.3%(17/165) Somnolence: 8.0%(13/163) vs 10.1%(15/149) vs 16.9%(25/148) vs 27.9%(46/165) Tardive dyskinesia: 0.6%(1/163) vs 0.0%(0/149) vs 0.0%(0/148) vs 0.0%(0/165) Upper respiratory tract infection: 3.7%(6/163) vs 10.1%(15/149) vs 7.4%(11/148) vs 5.5%(9/165) Urinary tract infection: 12.9%(21/163) vs 16.1%(24/149) vs 12.8%(19/148) vs 21.2%(35/165) | Placebo vs Risperidone 0.5mg/d vs Risperidone 1 mg/d vs Risperidone 2 mg/d: Withdrawals: 27.0%(44/163) vs 21.5%(32/149) vs 30.4%(45/148) vs 41.8%(69/165) Withdrawals due to adverse events: 12.3%(20/163) vs 8.1%(12/149) vs 16.2%(24/148) vs 24.2%(40/165)
Dementia and Agitation Risperidone (Meguro K et al., 2004)^10^ Japan | Design: RCT Setting: Single center Jadad: 1 | Inclusion criteria: Wandering behavior or aggressiveness > 4 in 7 consecutive days Exclusion criteria: Cerebrovascular disease, Parkinsons disease | Placebo-dosage not reported Risperidone-1 mg/day fixed single dose Duration: 1.0 month | None None | Acetyl-cholinesterase inhibitors | Assessed at baseline and 1 months: Sleep disorders, Wandering behavior | 78/68–90 21% male NR | NR/34/34 | NR/NR/NR | Rejected from meta-analysis because outcomes were measured at less than 6 weeks of followups. | Monitored | No adverse events reported. | Non-risperidone (no treatment) vs Risperidone: Withdrawals: Not reported Withdrawals due to adverse events: Not reported
Dementia and Agitation Risperidone (Mertens C, 1993)^11^ Western Europe | Design: CCT Setting: NR Jadad: 3 | Inclusion criteria: Male or female, Age > 65, CDR = 1, 2, or 3 Exclusion criteria: Neurological or medical conditions diminishing cognitive function, Neurologic disorder, not including primary conditioned studied, Psychiatric disorder, not including primary conditioned studied | Placebo Risperidone-2 mg/day average final dose Duration: 0.9 month | 1 wk of Placebo for randomization not described None | NR | Assessed at baseline and 4 weeks: BEHAVE-AD, CGI, MMSE, VAS, ADL | NR/65–88 31% male NR | NR/39/39 | 8/0/39 | Rejected from meta-analysis because outcomes were measured at less than 6 weeks of follow-ups. | Monitored | Placebo vs Risperidone: At least one adverse event: 42.1%(8/19) vs 55.0%(11/20) At least one serious adverse event: 0.0%(0/19) vs 5.0%(1/20) Abnormal ECG values: 31.6%(6/19) vs 35.0%(7/20) Death: 0.0%(0/19) vs 5.0%(1/20) No. of pts with code 4: .%(16/19) vs .%(9/20) | Placebo vs Risperidone: Withdrawals: 21.1%(4/19) vs 20.0%(4/20) Withdrawals due to adverse events: 0.0%(0/19) vs 10.0%(2/20)
Depression Olanzapine (Howanitz E et al., 2001)^12^ NR | Design: RCT Setting: NR Jadad: 2 | Inclusion criteria: NR Exclusion criteria: NR | Placebo-dosage not reported Olanzapine-6.25 mg/day average final dose Duration: 1.5 months | None None | NR | Assessed at baseline and 6 weeks: NPI, BPRS, ADAS-cog | 73/NR NR NR | NR/16/16 | 2/0/14 | Insufficient statistics for effect-size calculation. | Monitored | Olanzapine vs Placebo: Occurance of one adverse event: 0.0%(0/8) vs 12.5%(1/8) | Olanzapine vs Placebo: Withdrawals: 12.5%(1/8) vs 12.5%(1/8) Withdrawals due to adverse events: Not reported
Depression Olanzapine (Kinrys G et al., 2002)^13^ US | Design: RCT Setting: NR Jadad: 3 | Inclusion criteria: HAM-A = 50% reduction, CGI ≥ 4 Exclusion criteria: NR | Placebo-dosage not reported Olanzapine-9.4 mg/day average final dose Duration: 1.5 months | 6 wk of Fluoxetine for symptomatic patients None | Fluoxetine | Assessed at baseline and 6 weeks: HAM_D_HDRS, HAM_A, CGI | NR/NR NR NR | NR/14/14 | 3/0/11 | Insufficient statistics for effect-size calculation. | NR | Adverse events not reported. | Placebo vs Olanzapine: Withdrawals: 0.0%(0/5) vs 33.3%(3/9) Withdrawals due to adverse events: 0.0%(0/5) vs 0.0%(0/9)
Depression Olanzapine (Rothschild AJ et al., 2004)^14^ (Corya S et al., 2002)^15^ US The HGGA Study | Design: RCT Setting: Multi-center Jadad: 2 | Inclusion criteria: Age ≥ 18, HAM-D ≥ 20 Exclusion criteria: Psychotic disorder, Pregnant, Lactating | Placebo-dosage not reported Olanzapine-11.9 mg/day average final dose Olanzapine-12.4 mg/day average final dose, Fluoxetine-23.5 mg/day average final dose Duration: 2.0 months | None None | NR | Assessed at baseline and 8 weeks: HAM_D_HDRS, HAM_A, BPRS, CGI | 41/NR 48% male Caucasian, NOS | NR/124/124 | NR/NR/116 | Depression_mood-Change in HAM-D24 at 8 weeks: Placebo vs Olanzapine-SMD = −0.282(−0.573, 0.008) Depression_mood Comparison of interest not reported. Depression_severity-Change in CGI-S at 8 weeks: Placebo vs Olanzapine-WMD = −0.2(−0.441, 0.041) Depression_severity Comparison of interest not reported. | Monitored, reported by patient | Placebo vs Olanzapine vs Olanzapine + fluoxetine: At least one adverse event: 83.3%(83.3/100) vs 79.2%(79.992/101) vs 81.0%(38.88/48) Ambylopia (blurred vision): 5.0%(5/100) vs 1.0%(1.01/101) vs 10.4%(4.992/48) Dry mouth: 8.0%(8/100) vs 24.8%(25.048/101) vs 10.4%(4.992/48) GGT increase: 0.0%(0/100) vs 0.0%(0/101) vs 4.2%(2.016/48) Insomnia: 20.0%(20/100) vs 7.9%(7.979/101) vs 10.4%(4.992/48) Peripheral edema: 0.0%(0/100) vs 6.9%(6.969/101) vs 10.4%(4.992/48) Somnolence: 5.0%(5/100) vs 18.8%(18.988/101) vs 25.0%(12/48) Vomiting: 10.0%(10/100) vs 3.0%(3.03/101) vs 2.1%(1.008/48) Weight gain: 2.0%(2/100) vs 10.9%(11.009/101) vs 4.2%(2.016/48) | Placebo vs Olanzapine vs Olanzapine + fluoxetine: Withdrawals: 59.0%(59/100) vs 55.4%(56/101) vs 50.0%(24/48) Withdrawals due to adverse events: 6.0%(6/100) vs 8.9%(9/101) vs 18.8%(9/48)
Depression Olanzapine (Shi L et al., 2004)^16^ US, Australia/NZ, Europe, Colombia | Design: RCT Setting: Multi-center Jadad: 3 | Inclusion criteria: Age ≥ 18, MADRS ≥ 20, At least 1 manic or mixed episode requiring treatment with mood stabilizer or antipsychotic Exclusion criteria: Alcohol or substance abuse or dependency, Suicidal or violent, Medically significant disorders | Placebo-dosage not reported Olanzapine-9.7 mg/day average final dose Olanzapine-7.4 mg/day average final dose, Fluoxetine-25 or 50 mg Duration: 2.0 months | None 2–14 dy of Psychotropics, except benzodiazepines or anticholinergics for patients who completed the wash-out period | Benzodiazepines | Assessed at baseline and 8 weeks: SF-36, QLDS | 40/NR 35% male Caucasian, NOS | 1072/833/833 | 397/57/573 | Depression_qol-Change in SF-36 at 8 weeks: Placebo vs Olanzapine-SMD = 0.234(0.061,0.407) | NR | No adverse events reported. | Placebo vs Olanzapine vs Olanzapine + Fluoxetine: Withdrawals: 51.6%(191/370) vs 61.5%(232/377) vs 36.0%(31/86) Withdrawals due to adverse events: Not reported
Depression Olanzapine (Tohen M et al., 2003)^17^ US, Australia/NZ, Europe, Colombia | Design: RCT Setting: Multi-center Jadad: 4 | Inclusion criteria: Age ≥ 18, MADRS ≥ 20, At least 1 manic or mixed episode requiring treatment with mood stabilizer or antipsychotic Exclusion criteria: Alcohol or substance abuse or dependency, Suicidal or violent, Medically significant disorders | Placebo-dosage not reported Olanzapine-9.7 mg/day average final dose Olanzapine-7.4 mg/day average final dose, Fluoxetine-39.3 mg/day average final dose Duration: 2.0 months | None 2–14 dy of Psychotropics, except benzodiazepines or anticholinergics for patients who completed the wash-out period | Benzodiazepines | Assessed at baseline and 8 weeks: MADRS, HAM_A, CGI, YMRS | 42/NR 37% male Caucasian, NOS | 1072/833/833 | 397/57/788 | Depression_mood-Change in MADRS at 8 weeks: Placebo vs Olanzapine-SMD = −0.233(−0.381, −0.085) Depression_severity-Change in CGI-S at 8 weeks: Placebo vs Olanzapine-WMD = −0.3(−0.423, −0.177) | Monitored | Placebo vs Olanzapine vs Olanzapine + fluoxetine: 7% or greater weight gain: 0.3%(1.131/377) vs 18.7%(69.19/370) vs 19.5%(16.77/86) Asthenia: 3.2%(12.064/377) vs 9.7%(35.89/370) vs 12.8%(11.008/86) Diarrhea: 6.6%(24.882/377) vs 6.5%(24.05/370) vs 18.6%(15.996/86) Dry mouth: 6.1%(22.997/377) vs 11.1%(41.07/370) vs 16.3%(14.018/86) Headache: 18.6%(70.122/377) vs 12.4%(45.88/370) vs 14.0%(12.04/86) Increase in high supine systolic blood pressure: 1.7%(6.409/377) vs 0.6%(2.22/370) vs 4.9%(4.214/86) Increased appetite: 5.0%(18.85/377) vs 13.5%(49.95/370) vs 12.8%(11.008/86) Insomnia: 15.1%(56.927/377) vs 8.4%(31.08/370) vs 9.3%(7.998/86) Nausea: 8.8%(33.176/377) vs 4.3%(15.91/370) vs 11.6%(9.976/86) Nervousness: 8.0%(30.16/377) vs 10.5%(38.85/370) vs 9.3%(7.998/86) Orthostatic hypotension: 1.4%(5.278/377) vs 1.4%(5.18/370) vs 7.3%(6.278/86) Somnolence: 12.5%(47.125/377) vs 28.1%(103.97/370) vs 20.9%(17.974/86) Treatment-emergent QTc intervals of 470 milliseconds or greater: 0.3%(1/377) vs 0.3%(1/370) vs 0.0%(0/86) Treatment-emergent glucose elevation of 200 mg/dL or greater: 0.3%(1.131/377) vs 1.4%(5.18/370) vs 1.5%(1.29/86) Weight gain: 2.7%(10.179/377) vs 17.3%(64.01/370) vs 17.4%(14.964/86) Weight change in kg: Placebo-377 people (−0.47 mean,2.62 SD) vs Olanzapine-370 people (2.59 mean,3.24 SD) vs Olanzapine + Fluoxetine-86 people (2.79 mean,3.23 SD) | Placebo vs Olanzapine vs Olanzapine + fluoxetine: Withdrawals: 5.0%(19/377) vs 9.2%(34/370) vs 2.3%(2/86) Withdrawals due to adverse events: 61.5%(232/377) vs 51.6%(191/370) vs 36.0%(31/86)
Depression Olanzapine (Tohen M et al., 2000)^18^ US The Olanzapine HGGW Study | Design: RCT Setting: Multi-center Jadad: 4 | Inclusion criteria: YMRS ≥ 20 Exclusion criteria: Medically significant disorders, Alcohol or substance abuse or dependency, Suicidal or violent | Placebo-dosage not reported Olanzapine-16.4 mg/day average final dose Duration: 1.0 month | None 997 dy of Psychotropics for randomization not described | Benzodiazepines | Assessed at baseline and 4 weeks: YMRS, HAM_D_HDRS, CGI, PANSS | 39/NR 50% male Caucasian, NOS | NR/115/115 | 52/4/115 | Rejected from meta-analysis because outcomes were measured at less than 6 weeks of followups. | Monitored, reported by patient | Placebo vs Olanzapine: Agitation: 25.0%(15/60) vs 9.1%(5/55) Anxiety: 15.0%(9/60) vs 3.6%(2/55) Asthenia: 5.0%(3/60) vs 10.9%(6/55) Constipation: 8.3%(5/60) vs 10.9%(6/55) Dizziness: 6.7%(4/60) vs 12.7%(7/55) Dry mouth: 5.0%(3/60) vs 16.4%(9/55) Dyspepsia: 5.0%(3/60) vs 12.7%(7/55) Headache: 21.7%(13/60) vs 18.2%(10/55) Hostility: 10.0%(6/60) vs 1.8%(1/55) Nervousness: 20.0%(12/60) vs 9.1%(5/55) Personality disorder: 11.7%(7/60) vs 1.8%(1/55) Somnolence: 8.3%(5/60) vs 38.2%(21/55) Weight change in kg: Placebo-60 people (0.45 mean,2.31 SD) vs Olanzapine-55 people (2.11 mean,2.83 SD) | Placebo vs Olanzapine: Withdrawals: 58.3%(35/60) vs 38.2%(21/55) Withdrawals due to adverse events: 1.7%(1/60) vs 3.6%(2/55)
Depression Olanzapine (Tohen M et al., 1999)^19^ US The Olanzapine HGEH Study | Design: RCT Setting: Multi-center Jadad: 3 | Inclusion criteria: Age 18–65, YMRS ≥ 20 Exclusion criteria: Medically significant disorders, Alcohol or substance abuse or dependency, Suicidal or violent | Placebo-dosage not reported Olanzapine-14.9 mg/day average final dose Duration: 0.8 month | None 2–4 dy of All medications except benzodiazepines for randomization not described | Anticholinergic medications, Benzodiazepines | Assessed at baseline and 3 weeks: YMRS, HAM_D_HDRS, PANSS, CGI, SF-36 | 40/NR 52% male Caucasian, NOS | NR/139/139 | NR/NR/139 | Rejected from meta-analysis because outcomes were measured at less than 6 weeks of followups. | Monitored | Placebo vs Olanzapine: Agitation: 23.2%(16/69) vs 18.6%(13/70) Anxiety: 10.1%(7/69) vs 14.3%(10/70) Asthenia: 7.2%(5/69) vs 18.6%(13/70) Constipation: 2.9%(2/69) vs 11.4%(8/70) Depression: 11.6%(8/69) vs 12.9%(9/70) Dizziness: 5.8%(4/69) vs 22.9%(16/70) Dry mouth: 8.7%(6/69) vs 25.7%(18/70) Headache: 15.9%(11/69) vs 17.1%(12/70) Hostility: 11.6%(8/69) vs 8.6%(6/70) Increased ALT/SGPT values: 0.0%(0/69) vs 17.6%(12.32/70) Nervousness: 13.0%(9/69) vs 8.6%(6/70) Pain: 4.3%(3/69) vs 11.4%(8/70) Personality disorder: 11.6%(8/69) vs 7.1%(5/70) Somnolence: 17.4%(12/69) vs 32.9%(23/70) Weight gain: 1.4%(1/69) vs 11.4%(8/70) Weight change in kg: Placebo-69 people (−0.44 mean, 2.35 SD) vs Olanzapine-70 people (1.65 mean,2.54 SD) | Placebo vs Olanzapine: Withdrawals: 65.2%(45/69) vs 38.6%(27/70) Withdrawals due to adverse events: 2.9%(2/69) vs 0.0%(0/70)
Depression Olanzapine (Tohen M et al., 2003)^20^ US | Design: RCT Setting: NR Jadad: 2 | Inclusion criteria: YMRS ≥ 12, HAM-21 ≤ 8 Exclusion criteria: NR | Placebo-dosage not reported Olanzapine-5–20 mg/day’ Duration: 13.0 months | None None | NR | Assessed at baseline and 52 weeks: HAM_D_HDRS, YMRS | NR/NR NR NR | NR/361/361 | NR/NR/66 | Insufficient statistics for effect-size calculation. | NR | No adverse events reported. | Placebo vs Olanzapine: Withdrawals: 90.4%(122.944/136) vs 76.4% (171.9/225) Withdrawals due to adverse events: Not reported
Depression Olanzapine (Tollefson GD et al., 1999)^21^ US Collaborative Crossover Study | Design: RCT Setting: Multi-center Jadad: 3 | Inclusion criteria: Age ≥ 18, Clozapine treatment within 4 wks Exclusion criteria: Alcohol or substance abuse or dependency, Suicidal or violent, Previous exposure to study drug, Medically significant disorders | Placebo-dosage not reported Olanzapine-10 mg/day fixed single dose Duration: 0.2 month | None None | Anti-EPS medications, Benzodiazepines, Clozapine | Assessed at baseline and 997 day: CGI, PANSS, BPRS, MADRS, MMSE | 39/NR 71% male Caucasian, African-American, Hispanic | 115/106/106 | 11/0/95 | Rejected from meta-analysis because outcomes were measured at less than 6 weeks of followups. | Monitored, reported by patient | Placebo vs Olanzapine: Delusions: 22.6%(10.17/45) vs 7.5%(3.75/50) | Placebo vs Olanzapine: Withdrawals: 26.7%(12/45) vs 32.0%(16/50) Withdrawals due to adverse events: 6.7%(3/45) vs 14.0%(7/50)
Dementia-Agitation Olanzapine & Risperidone (van Reekum R et al., 2002)^22^ Canada | Design: RCT Setting: Multi-center Jadad: 5 | Inclusion criteria: Hospitalized/institutionalized, Antipsychotic treatment ≥ 6 months Exclusion criteria: Schizophrenia, Delirium, Resistant to antipsychotic treatment, Antipsychotic use for nausea, BEHAVE-AD ≥ 3 at screening, 1 week before study, or within 2 weeks pretrial period | Withdrawal from risperidone, olanzapine, halperidol, thiroidazine, or loxapine Continued tx w/risperidone, olanzapine, halperidol, thiroidazine, or loxapine Duration: 6.0 months | 1.5–1.8 yr of Risperidone, Olanzapine, Haloperidol, Anticonvulsants for patients who met study criteria None | Lorazepam if needed | Assessed at baseline and 6 months: BEHAVE-AD, NPI, ROAS, MMSE, MDRS, BDS, CGI | 84/NR 50% male NR | NR/34/34 | 16/0/33 | Dementia_global Not a comparison of interest for statistical analysis. | Monitored | Data not reported by interventions. | Placebo vs Anti-psychotics (risperidone, thioridazine, loxapine, perphenazine, olanzapine, haloperidol, nozinan): Withdrawals: 58.8%(10/17) vs 41.2%(7/17) Withdrawals due to adverse events: 58.8%(10/17) vs 41.2%(7/17)
Depression Quetiapine (Calabrese J et al., 2004)^23^ US | Design: RCT Setting: NR Jadad: 2 | Inclusion criteria: HAM-D ≥ 20, YMRS ≤ 12 Exclusion criteria: DSM-IV Axis I disorder, not including primary condition studied | Placebo-dosage not reported Quetiapine-300 mg/day fixed titration schedule Quetiapine-600 mg/day fixed titration schedule Duration: 2.0 months | None None | NR | Assessed at baseline and 8 weeks: HAM_D_HDRS, MADRS, Q-LES-Q, CGI, Sleep disorders | 37/NR 43% male NR | 832/542/542 | NR/NR/511 | Depression_mood-Change in MADRS at 8 weeks: Placebo vs Quetiapine 300 mg/d-SMD = −0.829(−1.05, −0.608) Depression_mood-Change in MADRS at 8 weeks: Placebo vs Quetiapine 600 mg/d-SMD = −0.868(−1.091, −0.645) | Monitored, reported by patient | Placebo vs Quetiapine 300 mg/d vs Quetiapine 600 mg/d: Constipation: 4.4%(8/181) vs 11.7%(21/181) vs 11.1%(20/180) Dizziness: 8.3%(15/181) vs 16.8%(30/181) vs 22.8%(41/180) Dry mouth: 7.8%(14/181) vs 44.1%(79/181) vs 40.6%(73/180) Mania: 4.0%(7.24/181) vs 3.0%(5.43/181) vs 2.0%(3.6/180) Sedation: 6.1%(11/181) vs 29.6%(53/181) vs 32.2%(58/180) Somnolence: 8.3%(15/181) vs 27.4%(49/181) vs 24.2%(44/180) Weight change in kg: Placebo-181 people (0.1 mean, SD NR) vs Quetiapine 300 mg/d-181 people (0.4 mean, SD NR) vs Quetiapine 600 mg/d-180 people (1.6 mean, SD NR) | Placebo vs Quetiapine 300 mg/d vs Quetiapine 600 mg/d: Withdrawals: 6.6%(12/181) vs 5.0%(9/181) vs 5.6%(10/180) Withdrawals due to adverse events: Not reported
Dementia and Agitation Risperidone (Mintzer J et al., 2004)^24^ US | Design: RCT Setting: Multi-center Jadad: 2 | Inclusion criteria: MMSE = 5–23, Age ≥ 55, BEHAVE-AD Psychosis Subscale ≥ 2, Able to ambulate, walk with assistance or use wheelchair independently Exclusion criteria: Medically significant disorders, Abnormal laboratory results, Epilepsy, Neurological or medical conditions diminishing cognitive function or that cause psychosis, Cancer, except for non-melanoma of the skin, Recent depot neuroleptic injections, Change in medications in preceding 30 dys | Placebo-53.1 mg mean modal dose Risperidone-1.2 mg mean modal dose Duration: 2.0 months | None 7 dys of Psychotropics for randomization not described | Lorazepam permitted | Assessed at baseline and 8 weeks: BEHAVE-AD, CGI | 83/NR 23% male Caucasian, African-American, Hispanic, Asian, NOS | NR/473/473 | NR/NR/355 | Dementia_psychosis-Change in BEHAVE-AD (psychosis) at 8 weeks: Placebo vs Risperidone-SMD = −0.308(−0.502, −0.114) Dementia_agitation-Change in BEHAVE-AD (aggressiveness) at 8 weeks: Placebo vs Risperidone-SMD = −0.228(−0.422, −0.035) Dementia_global-Change in BEHAVE-AD (total) at 8 weeks: Placebo vs Risperidone-SMD= −0.153(−0.346, 0.040) | Monitored | Placebo vs Risperidone: Agitation: 6.7%(16/238) vs 8.1%(19/235) Cerebrovascular disorder: 0.4%(1/238) vs 1.7%(4/235) Death: 2.5%(6/238) vs 3.8%(9/235) EPS-related AEs: 3.4%(8/238) vs 8.5%(20/235) Edema-related AEs: 4.6%(11/238) vs 5.1%(12/235) Fall: 12.6%(30/238) vs 11.1%(26/235) Glucose-related AEs: 2.1%(5/238) vs 1.7%(4/235) Hematoma: 5.0%(12/238) vs 3.4%(8/235) Injury: 10.5%(25/238) vs 9.4%(22/235) Insomnia: 5.9%(14/238) vs 5.5%(13/235) Prolactin-related AEs: 0.0%(0/238) vs 0.0%(0/235) Somnolence: 4.6%(11/238) vs 16.2%(38/235) Stroke: 0.4%(1/238) vs 0.4%(1/235) Urinary tract infection: 10.1%(24/238) vs 9.4%(22/235) | Placebo vs Risperidone: Withdrawals: 24.8%(59/238) vs 25.1%(59/235) Withdrawals due to adverse events: 10.1% (24.038/238) vs 10.6% (24.91/235)
Depression Risperidone (Gharabawi GM et al., 2004)^25^ International ARISe-RD Study | Design: RCT Setting: Multi-center Jadad: 4 | Inclusion criteria: Age 18–85, HAM-D ≤ 7, CGI score = 1 or 2, Achieved symptomatic remission following ≥ wks of RIS augmentation Exclusion criteria: Pregnant, lactating, psychiatric history, DSM-IV diagnosis confounded by various things, including being medically unstable, testing positive on urine drug screen, impaired hepatic or renal function, history failure of citalopram or any antidepressant with risperidone augmentation, etc. | Citalopram-mean modal dose 53.1 mg/day + Placebo Citalopram-53.1 mg/day + Risperidone-1.2 mg/day mean modal dose Duration: 6.0 months | 4–6 wk of Citalopram monotherapy, then Risperidone augmentation 4–6 wk in citalopram non-responders None | Zolpidem, lorazepam, zopiclone, zaleplon, benztropine | Assessed at baseline and 24 weeks: CGI, HAM_D_HDRS | 48/NR 36% male Caucasian, NOS | 489/241/241 | 17/8/48 | Insufficient statistics for effect-size calculation. | Monitored | Placebo vs Risperidone + citalopram: Dizziness: 2.5%(3/119) vs 5.7%(7/122) Fatigue: 7.6%(9/119) vs 4.9%(6/122) Headache: 5.9%(7/119) vs 11.5%(14/122) Insomnia: 5.9%(7/119) vs 3.3%(4/122) Weight Increase: 4.2%(5/119) vs 7.4%(9/122) Weight change in kg: Placebo-119 people (−0.6 kg mean, SD NR) vs Risperidone-122 people (1.2 kg mean, SD NR) | Placebo vs Risperidone + citalopram: Withdrawals: 9.3% (11.067/119) vs 11.5% (14.03/122) Withdrawals due to adverse events: 2.5%(2.975/119) vs 4.1%(5.002/122)
Depression Ziprasidone (Daniels DG et al., 1999)^26^ US & Canada The Ziprasidone Study | Design: RCT Setting: Multi-center Jadad: 3 | Inclusion criteria: Age ≥ 18, Hospitalized/institutionalized, PANSS ≥ 60, PANSS with score ≥ 4 on at least 2 items on positive symptoms subscale, CGI ≥ 3, Exclusion criteria: Resistant to antipsychotic treatment, Hospitalized > 4 weeks, Alcohol or substance abuse or dependency, Mental retardation, Organic mental disorder, Brief reactive psychosis, Depot neuroleptic within 4 weeks, Suicidal or violent | Placebo-dosage not reported Ziprasidone-80 mg/day fixed single dose Ziprasidone-160 mg/day fixed titration schedule Duration: 1.5 months | None 3 dy of Neuroleptics, Antidepressants, Sedatives, Anxiolytics, Hypnotics, Anticholinergics, Beta-adrenoceptor antagonists for patients who completed the wash-out period | Lorazepam | Assessed at baseline and 6 weeks: PANSS, CGI, BPRS, MADRS | 37/18–67 71% male Caucasian, African-American, Asian, NOS | 440/302/302 | NR/NR/302 | Depression_mood-Change in MADRS at 6 weeks: Placebo vs Ziprasidone 80 mg/d-SMD = −0.117 (−0.402,0.169) Depression_mood-Change in MADRS at 6 weeks: Placebo vs Ziprasidone 160 mg/d-SMD = −0.298(−0.585, −0.011) Depression_severity-Change in CGI-S at 6 weeks: Placebo vs Ziprasidone 80 mg/d-WMD = −0.3 (−0.534, −0.066) Depression_severity-Change in CGI-S at 6 weeks: Placebo vs Ziprasidone 160 mg/d-WMD = −0.6 (−0.835, −0.365) | Monitored, reported by patient, clinical observation | Placebo vs Ziprasidone 80 mg/d vs Ziprasidone 160 mg/d: At least one adverse event: 86.0%(79/92) vs 87.0%(92/106) vs 89.0%(93/104) Abdominal pain: 5.0%(5/92) vs 3.0%(3/106) vs 10.0%(10/104) Agitation: 11.0%(10/92) vs 10.0%(10/106) vs 9.0%(9/104) Akathisia: 7.0%(6/92) vs 14.0%(15/106) vs 13.0%(13/104) Constipation: 14.0%(13/92) vs 7.0%(7/106) vs 14.0%(14/104) Dizziness: 9.0%(8/92) vs 9.0%(10/106) vs 17.0%(18/104) Dry mouth: 4.0%(4/92) vs 4.0%(4/106) vs 13.0%(13/104) Dyspepsia: 9.0%(8/92) vs 9.0%(10/106) vs 14.0%(14/104) Dystonia: 2.2%(2.024/92) vs 0.0%(0/106) vs 3.8%(3.952/104) Extrapyramidal syndrome: 1.0%(0.92/92) vs 2.0%(2.12/106) vs 7.0%(7.28/104) Headache: 33.0%(30/92) vs 17.0%(18/106) vs 31.0%(32/104) Impotence: 0.0%(0/92) vs 0.0%(0/106) vs 1.0%(1/104) Increased appetite: 0.0%(0/92) vs 1.9%(2/106) vs 0.0%(0/104) Insomnia: 14.0%(13/92) vs 12.0%(13/106) vs 12.0%(12/104) Male sexual dysfunction: 0.0%(0/92) vs 0.0%(0/106) vs 1.0%(1/104) Nausea: 9.0%(8/92) vs 14.0%(15/106) vs 7.0%(7/104) Pain: 9.0%(8/92) vs 6.0%(6/106) vs 10.0%(10/104) Seizure: 0.0%(0/92) vs 0.0%(0/106) vs 0.0%(0/104) Severe EPS: 0.0%(0/92) vs 0.0%(0/106) vs 1.0%(1/104) Severe adverse evens: 11.0%(10/92) vs 8.0%(8/106) vs 8.0%(8/104) Somnolence: 5.0%(5/92) vs 19.0%(20/106) vs 19.0%(20/104) Tachycardia & orthostatic hypotension: 0.0%(0/92) vs 2.0%(2.12/106) vs 1.0%(1.04/104) Vomiting: 15.0%(14/92) vs 11.0%(12/106) vs 6.0%(6/104) Weight change in kg: Placebo-92 people (0.0 mean, SD NR) vs Ziprasidone 80 mg/day-106 people (1.0 mean, SD NR) vs Ziprasidone 160 mg/day-104 people (0.0 mean, SD NR) | Placebo vs Ziprasidone 80 mg/d vs Ziprasidone 160 mg/d: Withdrawals: 50.0%(46/92) vs 48.0% (50.88/106) vs 28.0% (29.12/104) Withdrawals due to adverse events: 1.1%(1/92) vs 1.8%(2/106) vs 7.7%(8/104)
Depression Ziprasidone (Keck P Jr et al., 1998)^27^ US The Ziprasidone Study | Design: RCT Setting: Multi-center Jadad: 2 | Inclusion criteria: Age 18–64, Hospitalized/institutionalized, 1 year duration primary condition, BPRS ≥ 37, BPRS ≥ 4 on 2 or more of core items, Exclusion criteria: Nursing home/residential center resident, Resistant to antipsychotic treatment, Alcohol or substance abuse or dependency, Residual schizophrenia, Mental retardation, Organic mental disorder, Brief reactive psychosis, Suicidal or violent | Placebo-dosage not reported Ziprasidone-40 mg/day fixed single dose Ziprasidone-120 mg/day fixed single dose Duration: 1.0 month | None 4–7 dy of Placebo, Antidepressants, Anticholinergics, Thymoleptics, Anxiolytics, Hypnotics for patients who completed the wash-out period | Anti-EPS medications, Beta-blockers, Lorazepam | Assessed at baseline and 4 weeks: BPRS, CGI, SANS | 39/19–76 79% male Caucasian, African-American, Asian, NOS | 203/139/139 | 62/1/139 | Rejected from meta-analysis because outcomes were measured at less than 6 weeks of followups. | Monitored, reported by patient, clinical observation | Placebo vs Ziprasidone 40 mg/d vs Ziprasidone 120 mg/d: At least one adverse event: 75.0%(36/48) vs 75.0%(33/44) vs 81.0%(36/47) Abdominal pain: 8.3%(4/48) vs 11.4%(5/44) vs 2.1%(1/47) Abnormal laboratory test (elevated hepatic transaminase): 0.0%(0/48) vs 0.0%(0/44) vs 2.1%(1/47) Agitation: 12.5%(6/48) vs 0.0%(0/44) vs 6.4%(3/47) Akathisia: 6.3%(3/48) vs 6.8%(3/44) vs 2.1%(1/47) Asthenia: 0.0%(0/48) vs 2.3%(1/44) vs 4.3%(2/47) Asthma: 2.1%(1/48) vs 4.5%(2/44) vs 2.1%(1/47) Back pain: 0.0%(0/48) vs 4.5%(2/44) vs 4.3%(2/47) Cogwheel rigidity: 0.0%(0/48) vs 0.0%(0/44) vs 4.3%(2/47) Constipation: 4.2%(2/48) vs 6.8%(3/44) vs 10.6%(5/47) Diarrhea: 0.0%(0/48) vs 0.0%(0/44) vs 4.3%(2/47) Dizziness: 2.1%(1/48) vs 4.5%(2/44) vs 2.1%(1/47) Dyspepsia: 6.3%(3/48) vs 11.4%(5/44) vs 6.4%(3/47) EPS: 2.1%(1/48) vs 2.3%(1/44) vs 6.4%(3/47) Headache: 20.8%(10/48) vs 18.2%(8/44) vs 21.3%(10/47) Hypertonia: 2.1%(1/48) vs 2.3%(1/44) vs 4.3%(2/47) Insomnia: 4.2%(2/48) vs 2.3%(1/44) vs 0.0%(0/47) Nausea: 4.2%(2/48) vs 6.8%(3/44) vs 6.4%(3/47) Pain: 8.3%(4/48) vs 9.1%(4/44) vs 4.3%(2/47) Peripheral edema: 0.0%(0/48) vs 0.0%(0/44) vs 4.3%(2/47) Pharyngitis: 2.1%(1/48) vs 4.5%(2/44) vs 4.3%(2/47) Rash: 0.0%(0/48) vs 6.8%(3/44) vs 2.1%(1/47) Respiratory disorder: 2.1%(1/48) vs 6.8%(3/44) vs 4.3%(2/47) Serious adverse events: 0.0%(0/48) vs 11.4%(5/44) vs 6.4%(3/47) Skin hypertrophy: 0.0%(0/48) vs 4.5%(2/44) vs 2.1%(1/47) Somnolence: 8.3%(4/48) vs 6.8%(3/44) vs 8.5%(4/47) Tremor: 0.0%(0/48) vs 0.0%(0/44) vs 6.4%(3/47) Vomiting: 4.2%(2/48) vs 4.5%(2/44) vs 2.1%(1/47) | Placebo vs Ziprasidone 40 mg/d vs Ziprasidone 120 mg/d: Withdrawals: 50.0%(24/48) vs 36.0%(16/44) vs 49.0%(23/47) Withdrawals due to adverse events: 0.0%(0/48) vs 2.0%(1/44) vs 9.0%(4/47)
Depression and PTSD Risperidone (Bartzokis G et al., 2004) US | Design: RCT Setting: Single center Jadad: 3 | Inclusion criteria: Proof of military service, CAPS ≥ 65 Exclusion criteria: Alcohol or substance abuse or dependency, Suicidal or violent, Medically significant disorders, Neurological or medical conditions diminishing cognitive function, Antipsychotic medications, Seizure disorder or epilepsy or risk, Change in antidepressant regimen within 6 wks prior to study entry | Placebo-dosage not reported Risperidone-3 mg/day average final dose Duration: 4.0 months | None None | Antidepressants, Anxiolytics, Sedative/hypnotics | Assessed at baseline and 16 weeks: HAM_D_HDRS, HAM_A, PANSS, CAPS | 52/38–63 100% male Caucasian, African-American, Asian, Native American | 73/65/65 | 17/8/1948 | Depression_mood-Change in HAM-D at 16 weeks: Placebo vs Risperidone-SMD = −0.447(−1.072, 0.178) PTSD_depression-Change in CAPS-TOTAL at 6 weeks: Placebo vs Risperidone-SMD = −0.441(−1.022, 0.139) | Monitored, reported by patient,. | No adverse events reported. | Placebo vs Risperidone: Withdrawals: 18.8%(6/32) vs 33.3%(11/33) Withdrawals due to adverse events: 6.3%(2/32) vs 9.1%(3/33)
PTSD Risperidone (Padala PR et al., 2005)^28^ US | Design: RCT Setting: NR Jadad: 2 | Inclusion criteria: Level of understanding to perform all tests and examinations Exclusion criteria: Bipolar disorder, Schizophrenia, Medically significant disorders, Abnormal laboratory results, Suicidal or violent, Alcohol or substance abuse or dependency, Previous exposure to study drug, Antipsychotics other than the ones studied, Previous exposure to risperidone, Pregnancy/nursing, Use of psychotropics | Placebo-dosage not reported Risperidone-2.62 mg/day average final dose Duration: 3.0 months | None 2 wk of Psychotropics for randomization not described | Diphenhydramine 25–50 mg/dy PRN | Assessed at baseline and 10 weeks: TOP8, HAM_A, CAPS, CGI, HAM_D_HDRS | 41/NR 0% male Caucasian, African-American, NOS | NR/20/20 | NR/NR/15 | PTSD_depression-Change in CAPS-TOTAL at 10 weeks: Placebo vs Risperidone-SMD = −1.809(−3.054, −0.564) | Monitored | No adverse events reported. | Placebo vs Risperidone: Withdrawals: Not reported Withdrawals due to adverse events: Not reported
PTSD Risperidone (Reich DB et al., 2004)^29^ US | Design: RCT Setting: Single Center Jadad: 2 | Inclusion criteria: Understand English, Able to give informed consent, Level of understanding to perform all tests and examinations, CAPS-1 ≥ 50, PTSD related to childhood physical, sexual, emotional or verbal abuse, Exclusion criteria: Medically significant disorders, Alcohol or substance abuse or dependency, Psychotic disorder, Organic mental disorder, Antipsychotics other than the ones studied, Mood stabilizers, Risperidone treatment of 1 week or more, Suicidal or violent, Pregnancy/nursing, Entry into individual psychotherapy within 3 mos of study, and entry into group therapy within 1 mo of study | Placebo-dosage not reported Risperidone-1.41 mg/day average final dose Duration: 2.0 months | None None | Antidepressants, Benzodiazepines permitted | Assessed at baseline and 8 weeks: CAPS | 27/NR 0% male Caucasian, African-American, Asian | NR/21/21 | NR/NR/21 | PTSD-Change in CAPS-2 TOTAL at 8 weeks: Placebo vs Risperidone-SMD = −0.519(−1.398,0.361) | Monitored | Placebo vs Risperidone: At least one adverse event: 11.1%(1/9) vs 33.3%(4/12) Weight change in kg: Placebo-9people (1.4 kg mean, SD) vs Risperidone-12 people (1.1 kg mean, SD) | Placebo vs Risperidone: Withdrawals: 22.2%(2/9) vs 25.0%(3/12) Withdrawals due to adverse events: 0.0%(0/9) vs 8.3%(1/12)
OCD Olanzapine (Bystritsky A et al., 2004)^30^ US | Design: RCT Setting: Single center Jadad: 3 | Inclusion criteria: Age 18–65 Exclusion criteria: DSM-IV Axis I disorder, not including primary condition studied, DSM-IV Axis II disorder, not including primary condition studied, Neurological conditions, excluding Alzheimers or vascular dementia, contributing to psychosis or dementia, Pregnant, Medically significant disorders, HAM-D > 20, Bizarre psychosis | Placebo-16.9 mg/day average final dose Olanzapine-11.2 mg/day average final dose Duration: 1.5 months | None None | SRIs | Assessed at baseline and 6 weeks: YBOCS, HAM_D_HDRS, HAM_A, CGI | 41/18–65 50% male NR | NR/26/26 | 8/0/18 | OCD-Change in Y-BOCS at 6 weeks: Placebo vs Olanzapine-WMD = −5.7(−10.7, −0.7) OCD-Change in Number of Responders at 6 weeks: Placebo vs Olanzapine-RR = 13(0.8,209.4) | Monitored | No adverse events reported. | Placebo vs Olanzapine: Withdrawals: 46.2%(6/13) vs 15.4%(2/13) Withdrawals due to adverse events: 0.0%(0/13) vs 15.4%(2/13)
OCD Risperidone (Buchsbaum MS, 2003)^31^ NR | Design: CCT Setting: NR Jadad: 1 | Inclusion criteria: Refractory to SRI therapy Exclusion criteria: NR | Placebo-dosage not reported Risperidone-dosage not reported Duration: 2.0 months | None None | NR | Assessed at baseline and 8 weeks: CGI. | NR/NR NR NR | NR/16/16 | NR/NR/15 | Insufficient statistics for effect-size calculation. | NR | Sample size not reported by group | Placebo vs Risperidone: Withdrawals: Not reported Withdrawals due to adverse events: Not reported
OCD Risperidone (Erzegovesi S et al., 2005)^32^ Western Europe | Design: RCT Setting: Single center Jadad: 4 | Inclusion criteria: Age 18–65, 1 year duration primary condition, Drug-free within 3 weeks, Drug-free for at least 3 wks prior to study entry Exclusion criteria: Antiobsessional medications, Psychiatric disorders except for panic disorder and tic disorders, Pregnant, Lactating, Seizure disorder or epilepsy or risk, Medical conditions contraindicating use of fluvoxamine, Contraindication to risperidone | Placebo-dosage not reported Risperidone-0.5 mg/day fixed single dose Duration: 1.5 months | 12 wk of Fluvoxamine for responders separated from non-responders None | Fluvoxamine, Previously established benzodiazepines used as hypnotics | Assessed at baseline and 6 weeks: YBOCS, NIMH-OC, HAM_D_HDRS, CGI | 37/NR 53% male NR | NR/45/45 | 1/0/39 | OCD-Change in Y-BOCS at 6 weeks: Placebo vs Risperidone-WMD = 0.89 (−2.5,4.3) OCD-Change in Number of Responders at 6 weeks: Placebo vs Risperidone-RR = 2.5(0.6,9.9) | NR | Placebo vs Risperidone: Mild increasing of appetite: 0.0%(0/19) vs 15.0%(3/20) Transient sedation: 0.0%(0/19) vs 35.0%(7/20) | Placebo vs Risperidone: Withdrawals: Not reported Withdrawals due to adverse events: not broken down by group
OCD Risperidone (Hollander E et al., 2003)^33^ US | Design: RCT Setting: NR Jadad: 4 | Inclusion criteria: CGI ≥ 3, SRI therapy ≥ 12 weeks, ≥2 SRI trials of adequate dose and duration Exclusion criteria: Medically significant disorders, Schizophrenia and schizoaffective disorder, Bipolar disorder | Placebo-2.75 mg/day average final dose Risperidone-2.25 mg/day average final dose Duration: 2.0 months | None None | SRIs | Assessed at baseline and 8 weeks: YBOCS, HAM_D_HDRS, CGI | 39/NR 56% male NR | NR/16/16 | 3/0/16 | OCD-Change in Y-BOCS at 8 weeks: Placebo vs Risperidone-WMD = −4.9 (−13.9,4.096) OCD-Change in Number of Responders at 8 weeks: Placebo vs Risperidone-RR = 5.7(0.4,90.8) | Monitored, elicited by investigator | Placebo vs Risperidone: At least one adverse event: 33.3%(2/6) vs 40.0%(4/10) Dizziness: 0.0%(0/6) vs 10.0%(1/10) Dry mouth: 16.7%(1/6) vs 20.0%(2/10) Sedation: 0.0%(0/6) vs 30.0%(3/10) Sexual dysfunction: 16.7%(1/6) vs 0.0%(0/10) | Placebo vs Risperidone: Withdrawals: 33.3%(2/6) vs 10.0%(1/10) Withdrawals due to adverse events: 0.0%(0/6) vs 0.0%(0/10)
PTSD Olanzapine (Butterfield MI et al., 2001)^34^ US | Design: RCT Setting: NR Jadad: 3 | Inclusion criteria: Age 18–70, Understand English, Able to give informed consent Exclusion criteria: Bipolar disorder, Psychotic disorder, Mental retardation, Alcohol or substance abuse or dependency, Suicidal or violent | Placebo-13.9 mg/day average final dose Olanzapine-14.1 mg/day average final dose Duration: 2.5 months | None None | NR | Assessed at baseline and 10 weeks: SIP, SPRINT, TOP8, DTS, SDS, CGI | 43/26–73 7% male Caucasian, African-American | NR/15/15 | 4/0/11 | PTSD-Change in SIP at 10 weeks: Placebo vs Olanzapine-SMD = 0.182 (−0.894,1.257) | Reported by patient | No adverse events reported. Weight change in lbs: Placebo-5 people (0.9 mean,0.06 SD) vs Olanzapine-10 people (11.5 mean,4.43 SD) | Placebo vs Olanzapine: Withdrawals: Not reported Withdrawals due to adverse events: Not reported
PTSD Olanzapine (Stein MB et al., 2002)^35^ US | Design: RCT Setting: VA Healthcare S Jadad: 3 | Inclusion criteria: Refractory to SRI therapy Exclusion criteria: NR | Placebo-20.00 mg/day average final dose Olanzapine-15.00 mg/day average final dose Duration: 2.0 months | Variable weeks of SSRIs for patients minimally responsive to SSRIs None | SRIs | Assessed at baseline and 8 weeks: CAPS, CES-D, Pittsburg Sleep, CGI | 53/34–69 100% male NR | NR/21/19 | 5/2/2014 | Olanzapine was associated with a greater reduction than placebo in depressive symptoms as measured by the CES-D. SMD = −.726 (−1.659, .207). | NR | Placebo vs Olanzepine: Somnolence: 0.0%(0/9) vs 20.0%(2/10) Weight change in lbs: Placebo-9 people (Mean NR, SD NR) vs Olanzapine-10 people (13 mean, SD) | Placebo vs Olanzepine: Withdrawals: 22.2%(2/9) vs 30.0%(3/10) Withdrawals due to adverse events: 0.0%(0/9) vs 20.0%(2/10)
PTSD Risperidone (Hamner MB et al., 2003)^36^ US | Design: RCT Setting: Single center Jadad: 4 | Inclusion criteria: Age ≥ 18, Psychosis/psychotic features, PANSS ≥ 60, PANSS with score ≥ 4 on at least 1 item on positive symptoms subscale, Exclusion criteria: Toxic reactions to antipsychotic medications, Medically significant disorders, Alcohol or substance abuse or dependency, Schizophrenia, Bipolar disorder, Suicidal or violent, Risperidone hypersensitivity | Placebo-dosage not reported Risperidone-2.5 mg/day average final dose Duration: 1.3 months | 1 wk of Placebo for non-placebo responders Prior to run-in antipsychotics or thymoleptics (carbamazepine, valproic acid and lithium) had medications reduced or discontinued | Antidepressants, Benzodiazepines, Chloral hydrate, Mood stabilizers | Assessed at baseline and 5 weeks: PANSS, CAPS | 52/47–68 100% male Caucasian, African-American | NR/40/40 | 15/0/37 | Rejected from meta-analysis because outcomes were measured at less than 6 weeks of followups. | Elicited by investigator | Placebo vs Risperidone: Mild akathisia: 0.0%(0/18) vs 5.3%(1/19) Mild nausea and diarrhea: 0.0%(0/18) vs 5.3%(1/19) | Placebo vs Risperidone: Withdrawals: 33.3%(6/18) vs 47.4%(9/19) Withdrawals due to adverse events: 0.0%(0/18) vs 0.0%(0/19)
PTSD Risperidone (Monnelly EP et al., 2003)^37^ US | Design: RCT Setting: Single center Jadad: 4 | Inclusion criteria: PCL-M ≥ 20 on cluster D subscale Exclusion criteria: Schizophrenia, Bipolar disorder with psychotic features, Organic mental disorder, Antipsychotic medications, Alcohol/substance dependency in remission | Placebo-0.62 mg/day average final dose Risperidone-0.57 mg/day average final dose Duration: 1.5 months | None None | Antidepressants, Benzodiazepines, Buspirone, Mood stabilizers | Assessed at baseline and 6 weeks: OAS-M, PCL-M, BDHI, STAT-T, STAS-AX, BDI, BAI, DES, STAT-S | 51/NR 100% male Caucasian, African-American, Hispanic | NR/16/16 | 1/0/15 | Outcome of interest for statistical analysis not reported. | NR | Placebo vs Risperidone: Mild adverse events: 25.0%(2/8) vs 50.0%(4/8) Moderate adverse events: 12.5%(1/8) vs 0.0%(0/8) Urinary retention: 0.0%(0/8) vs 12.5%(1/8) | Placebo vs Risperidone: Withdrawals: 0.0%(0/8) vs 12.5%(1/8) Withdrawals due to adverse events: 0.0%(0/8) vs 12.5%(1/8)
Personality Disorder Olanzapine (Bogenschutz MP et al., 2004)^38^ US | Design: RCT Setting: Single center Jadad: 3 | Inclusion criteria: Age 18–60 Exclusion criteria: Psychotropic medications, Pregnant, Bipolar disorder, Psychotic disorder, Major depressive disorder, Alcohol or substance abuse or dependency, Suicidal or violent, Neurological disorder | Placebo-10.2 mg/day average final dose Olanzapine-6.9 mg/day average final dose Duration: 3.0 months | None None | NR | Assessed at baseline and 12 weeks: CGI, OAS-M, AIAQ, HAM_D_HDRS, HAM_A, SCL_90, ASI | 33/18–54 38% male Caucasian, Hispanic, Asian, NOS | NR/40/40 | 8/7/1935 | Personality Disorder-Change in CGI-BPD at 12 weeks: Placebo vs Olanzapine-SMD = −0.667 (−1.351,0.018) | Monitored | Olanzapine vs Placebo: Sedation: 10.0%(2/20) vs 0.0%(0/20) Weight gain: 10.0%(2/20) vs 0.0%(0/20) Weight change in kg: Placebo-20 people (0.08 mean,4.8 SD) vs Olanzapine-20 people (3.71 mean,3.4 SD) | Olanzapine vs Placebo: Withdrawals: 50.0%(10/20) vs 35.0%(7/20) Withdrawals due to adverse events: 20.0%(4/20) vs 0.0%(0/20)
Personality Disorder Olanzapine (Zanarini MC et al., 2001)^39^ US | Design: RCT Setting: NR Jadad: 5 | Inclusion criteria: Age 18–40 Exclusion criteria: Previous exposure to study drug, Medically significant disorders, Seizure disorder or epilepsy or risk, Psychotropic medications, Alcohol or substance abuse or dependency, Suicidal or violent, Pregnant, Lactating | Placebo-dosage not reported Olanzapine-5.33 mg/day average final dose Duration: 6.0 months | None None | NR | Assessed at baseline and 24 weeks: SCL_90, HAM_D_HDRS, DES, PANSS, GAF | 27/NR 0% male Caucasian, NOS | 30/28/28 | 8/11/2028 | Personality Disorder-Change in SCL90-ANXIETY at 24 weeks: Placebo vs Olanzapine-SMD = −0.32 (−1.118,0.478) | Monitored, elicited by investigator | Placebo vs Olanzapine: Constipation: 0.0%(0/9) vs 31.6%(6/19) Mild rigidity: 0.0%(0/9) vs 5.3%(1/19) Perceived weight gain: 0.0%(0/9) vs 47.4%(9/19) Sedation: 33.3%(3/9) vs 42.1%(8/19) Self mutilative acts: 0.0%(0/9) vs 0.0%(0/19) Serious movement disorders: 0.0%(0/9) vs 0.0%(0/19) Suicidal acts: 0.0%(0/9) vs 0.0%(0/19) Tardive dyskinesia: 0.0%(0/9) vs 0.0%(0/19) Weight change in kg: Placebo-9 people (−0.78 mean,2.59 SD) vs Olanzapine-19 people (1.29 mean,2.56 SD) | Placebo vs Olanzapine: Withdrawals: 88.9%(8/9) vs 57.9%(11/19) Withdrawals due to adverse events: 0.0%(0/9) vs 31.6%(6/19)
Personality Disorder Risperidone (Koenigsberg HW et al., 2003)^40^ US | Design: RCT Setting: Multi-center Jadad: 4 | Inclusion criteria: Healthy, Age 18–60 Exclusion criteria: Alcohol or substance abuse or dependency, Use psychotropic medications within 2 wks | Placebo-dosage not reported Risperidone-0.25–2 mg/day flexible dose Duration: 2.3 months | 2 wk of Placebo for randomization not described None | NR | Assessed at baseline and 9 weeks: PANSS, HAM_D_HDRS, CGI, SPQ | 41/NR 83% male Caucasian, African-American, Hispanic | NR/25/25 | 10/1/23 | Personality Disorder-Change in PANSS-TOTAL at 9 weeks: Placebo vs Risperidone-SMD = −1.624(−2.595, −0.653) | NR | Placebo vs Risperidone: At least one adverse event: 50.0%(5/10) vs 46.7%(7/15) | Placebo vs Risperidone: Withdrawals: 30.0%(3/10) vs 46.7%(7/15) Withdrawals due to adverse events: 10.0%(1/10) vs 33.3%(5/15)
Tourettes Ziprasidone (Sallee FR et al., 2000)^41^ US | Design: RCT Setting: Multi-center Jadad: 3 | Inclusion criteria: Age 7–17, Severe tic symptoms requiring medication treatment, Healthy, Free of psychotropic medications within 4 weeks Exclusion criteria: Abnormal laboratory results, Neuroleptic malignant syndrome, Atypical antipsychotics sensitivity, Major depressive disorder, Pervasive developmental disorder, Autism, Mental retardation, Eating disorders | Placebo-dosage not reported Ziprasidone-28.2 mg/day average final dose Duration: 1.8 months | None None | NR | Assessed at baseline and 56 day: Yale Global Tic, CGI, Goetz Videotaping Scale, CY-BOCS | 12/7–16 79% male NR | 29/28/28 | 4/0/28 | Tourettes-Change in YALE GLOBAL Tic at 8 weeks: Placebo vs Ziprasidone-SMD = −0.563(−1.346, 0.22) | Monitored, reported by patient, clinical observation | Placebo vs Ziprasidone: At least one adverse event: 58.3%(7/12) vs 100.0%(16/16) Akathisia: 0.0%(0/12) vs 6.3%(1/16) Increase in sedation score above baseline values on at least one visit: 45.0%(5/12) vs 69.0%(11/16) Increases in serum prolacin concentrations greater than 1.1 times the upper limit of normal: 0.0%(0/12) vs 31.3%(5/16) Mild gynecomastia: 0.0%(0/12) vs 6.3%(1/16) Somnolence: 0.0%(0/12) vs 6.3%(1/16) Weight change in kg: Placebo-12 people (0.8 mean,2.3 SD) vs Ziprasidone-16 people (0.7 mean,1.5 SD) | Placebo vs Ziprasidone: Withdrawals: 25.0%(3/12) vs 6.3%(1/16) Withdrawals due to adverse events: 0.0%(0/12) vs 6.3%(1/16)
Dementia and Agitation Aripiprazole (Breder C et al., 2004)^42^ NR | Design: RCT Setting: Multi-center Jadad: 1 | Inclusion criteria: Psychosis/psychotic features, Nursing home resident, NPI or NPI/NH ≥ 6 sum of hallucinations and delusional items, Age 55–95, MMSE = 6–22 Exclusion criteria: NR | Placebo - dosage not reported Aripiprazole - 2 mg/day fixed single dose Aripiprazole - 5 mg/day fixed single dose Aripiprazole - 10 mg/day fixed titration schedule Duration: 2.5 months | None ≥ 7 dy of psychotropics for patients who completed the wash-out period | Antidepressants, Cognition enhancers at stable doses, zolpidem, lorazepam as long as it was not within 12 hours of baseline and double-blind study evaluations | Assessed at baseline and 10 weeks: BPRS, NPI-NH, CGI, CMAI, Extrapyramidel side effects | 83/56–97 21% male NR | NR/487/487 | NR/NR/274 | Insufficient statistics for effect-size calculation. | NR | Placebo vs Aripiprazole vs Aripiprazole vs Aripiprazole: Accidental injury: 18.0%(22/121) vs 30.0%(35/118) vs 24.0%(29/122) vs 23.0%(29/126) Agitation: 16.0%(19/121) vs 12.0%(14/118) vs 7.0%(9/122) vs 11.0%(14/126) Anorexia: 11.0%(13/121) vs 8.0%(9/118) vs 5.0%(6/122) vs 6.0%(8/126) Asthenia: 4.0%(5/121) vs 6.0%(7/118) vs 9.0%(11/122) vs 6.0%(8/126) Death: 3.0%(4/121) vs (NR/118) vs (NR/122) vs (NR/126) EPS-related AEs: 6.0%(7/121) vs 8.0%(9/118) vs 7.0%(9/122) vs 7.0%(9/126) Ecchymosis: 10.0%(12/121) vs 9.0%(11/118) vs 5.0%(6/122) vs 8.0%(10/126) Edema peripheral: 8.0%(10/121) vs 10.0%(12/118) vs 6.0%(7/122) vs 10.0%(13/126) Extremity pain: 6.0%(7/121) vs 7.0%(8/118) vs 9.0%(11/122) vs 10.0%(13/126) Skin ulcer: 7.0%(9/121) vs 10.0%(12/118) vs 12.0%(15/122) vs 11.0%(14/126) Somnolence: 3.0%(4/121) vs 3.0%(4/118) vs 10.0%(12/122) vs 9.0%(11/126) Urinary incontinence: 2.0%(2/121) vs 2.0%(2/118) vs 10.0%(12/122) vs 6.0%(8/126) Urinary tract infection: 14.0%(17/121) vs 15.0%(18/118) vs 17.0%(21/122) vs 22.0%(28/126) Vomiting: 7.0%(9/121) vs 11.0%(13/118) vs 8.0%(10/122) vs 7.0%(9/126) | Placebo vs Aripiprazole vs Aripiprazole vs Aripiprazole: Withdrawals: (NR/121) vs (NR/118) vs (NR/122) vs (NR/126) Withdrawals due to adverse events: 3.0%(16/121) vs 8.0%(9/118) vs 18.0%(22/122) vs 25.0%(31/126)
Dementia and Agitation Aripiprazole (De Deyn P et al., 2005)^43^ NR | Design: RCT Setting: Multi-center Jadad: 3 | Inclusion criteria: NPI or NPI/NH ≥ 6 sum of hallucinations and delusional items, Age 55–95, Noninstitutionalized, Delusions or hallucinations ≥ 1 month, MMSE = 6–24 Exclusion criteria: Bipolar disorder, Schizophrenia, Delirium, Amnestic disorder, Schizoaffective disorder, Mood disorders with psychotic features, Psychotic features accounted better by disease other than the one studied or by effects of a substance, Refractory to neuroleptics | Placebo - dosage not reported Aripiprazole - 10 mg/day average final dose Duration: 2.5 months | None 7 wk of psychotropics for patients who completed the wash-out period | Sedative/hypnotics, Acetylcholinesterase inhibitors, Rivastigmine, Tacrine, Antidepressants, Benztropine | Assessed at baseline and 10 weeks: NPI, BPRS, CGI, MMSE, Extrapyramidel side effects | 82/NR 28% male Caucasian, NOS | NR/208/208 | 36/0/203 | Dementia_global-Change in NPI-Total at 10 weeks: Placebo vs Aripiprazole-SMD = 0.847(0.56,1.135) Dementia_psychosis-Change in NPI-Psychosis at 10 weeks: Placebo vs Aripiprazole-SMD = 0.424(0.146,0.702) Dementia_severity-Change in CGI-S at 10 weeks: Placebo vs Aripiprazole-SMD = −1.034(−1.327, −0.74) | Monitored | Placebo vs Aripiprazole: Bronchitis: 3.0%(3.1/102) vs 6.0%(6.4/106) Death: 0.0%(0/102) vs 3.8%(4/106) EPS-related AEs: 3.9%(4/102) vs 4.7%(5/106) Fractures: 2.0%(2/102) vs 4.7%(5/106) Hypertension: 5.0%(5/102) vs 4.0%(4/106) Increased QTc Interval: 1.0%(1/102) vs 1.9%(2/106) Increased lactate dehydrogenase: 1.0%(1/102) vs 0.0%(0/106) Mild transient cerebral ischemia: 1.0%(1/102) vs 0.9%(1/106) Somnolence: 1.0%(1/102) vs 8.0%(9/106) Urinary tract infection: 12.0%(12/102) vs 8.0%(9/106) Weight gain: 3.0%(3/102) vs 5.0%(5/106) | Placebo vs Aripiprazole: Withdrawals: 17.6%(18/102) vs 17.0%(18/106) Withdrawals due to adverse events: 6.9%(7/102) vs 9.4%(10/106)
Dementia and Agitation Aripiprazole (Streim JE et al., 2004)^44^ US | Design: RCT Setting: Multi-center Jadad: 2 | Inclusion criteria: Delusions or hallucinations ≥ 1 month, Nursing home resident, Age 55–95, MMSE = 6–22, NPI or NPI/NH ≥ 6 sum of hallucinations and delusional items Exclusion criteria: NR | Placebo - dosage not reported Aripiprazole - 8.6 mg/day average final dose Duration: 2.5 months | None None | Antidepressants, Cognition enhancers at stable doses, zolpidem, lorazepam | Assessed at baseline and 10 weeks: BPRS, CGI, NPI-NH, CMAI, CSDD, Extrapyramidel side effects | 83/59–96 24% male NR | NR/256/256 | NR/NR/249 | Insufficient statistics for effect-size calculation. | NR | Placebo vs Aripiprazole: Accidental injury: 30.0%(38/125) vs 21.0%(28/131) Asthenia: 7.0%(9/125) vs 12.0%(16/131) Death: 2.4%(3/125) vs 2.3%(3/131) ECG abnormalities: (NR/125) vs (NR/131) EPS-related AEs: 4.0%(5/125) vs 5.0%(7/131) Ecchymosis: 13.0%(16/125) vs 12.0%(16/131) Hypotension and syncope: 5.0%(6/125) vs 3.0%(4/131) Rash: 12.0%(15/125) vs 10.0%(13/131) Somnolence: 4.0%(5/125) vs 14.0%(18/131) Urinary tract infection: 11.0%(14/125) vs 14.0%(18/131) Vomiting: 8.0%(10/125) vs 10.0%(13/131) | Placebo vs Aripiprazole: Withdrawals: (NR/125) vs (NR/131) Withdrawals due to adverse events: 9.0%(11/125) vs 12.0%(16/131)
Depression Aripiprazole (McQuade R et al., 2004)^45^ NR | Design: RCT Setting: NR Jadad: 2 | Inclusion criteria: Recent manic episode, but did not participate in a trial of study drug, Recently completed trial of study drug, YMRS ≤ 10, MADRS ≤ 13 Exclusion criteria: NR | Placebo - dosage not reported Aripiprazole - 24.3 mg/day average final dose Duration: 6.5 months | 6–18 wk of Aripiprazole for randomization not described None | Not reported | Assessed at baseline and 26 weeks: YMRS, MADRS, Extrapyramidel side effects | NR/NR NR NR | 567/161/161 | NR/NR/67 | Depression_mood-Change in MADRS at 26 weeks: Placebo vs Aripiprazole-SMD = −0.298(−0.612,0.016) | Monitored | Placebo vs Aripiprazole: Agitation: 11.0%(9/83) vs 7.0%(6/78) Akathisia: 1.2%(1/83) vs 6.5%(5/78) Anxiety: 16.0%(13/83) vs 18.0%(14/78) Depression: 14.0%(12/83) vs 11.0%(9/78) EPS: 1.2%(1/83) vs 0.0%(0/78) Headache: 17.0%(14/83) vs 8.0%(6/78) Insomnia: 20.0%(17/83) vs 16.0%(12/78) Nervousness: 5.0%(4/83) vs 10.0%(8/78) Reaction Manic: 13.0%(11/83) vs 6.0%(5/78) Somnolence: 7.2%(6/83) vs 5.2%(4/78) | Placebo vs Aripiprazole: Withdrawals: (NR/83) vs (NR/78) Withdrawals due to adverse events: 1.0%(1/83) vs 6.0%(5/78)
Depression Olanzapine (Kennedy J et al., 2005)^46^ US | Design: RCT Setting: Multi-center Jadad: 3 | Inclusion criteria: Age ≥ 40 Exclusion criteria: DSM-IV Axis I disorder, not including primary condition studied, Neurologic disorder, not including primary conditioned studied, NPI > 1 on delusions, hallucinations, agitation/aggression or dysphoria items, Score ≥ 1 on cholinesterase inhibitor use, antioxidant or herbal supplement items ≤ 4 week | Placebo - dosage not reported Olanzapine - 2.5–7.5 mg/day flexible dose Duration: 6.5 months | None 10–18 dy of medications to treat Alzheimers for randomization not described | Benzodiazepines, Hypnotics | Assessed at baseline and 26 weeks: NPI, MMSE, ADAS-cog, Extrapyramidel side effects, CIBIC | 78/NR 44% male Caucasian, NOS | 446/268/268 | 92/3/173 | Dementia_cognition-Change in ADAS-Cog at 26 weeks: Placebo vs Olanzapine-SMD = 0.145(−0.109,0.398) Dementia_psychosis-Change in NPI-Psychosis at 26 weeks: Placebo vs Olanzapine-SMD = −0.015(−0.269,0.239) | Monitored, reported by patient | Placebo vs Olanzapine: Abnormal gait: 3.3%(3/90) vs 6.7%(12/178) Accidental injury: 6.7%(6/90) vs 11.8%(21/178) Agitation: 5.7%(5/90) vs 8.4%(15/178) Amnesia: 2.2%(2/90) vs 5.6%(10/178) Anxiety: 5.7%(5/90) vs 5.6%(10/178) Asthenia: 5.7%(5/90) vs 10.1%(18/178) Cerebrovascular adverse events: 1.1%(1/90) vs 1.7%(3/178) Confusion: 2.2%(2/90) vs 6.2%(11/178) Constipation: 1.1%(1/90) vs 6.2%(11/178) Death: 1.1%(1/90) vs 0.6%(1/178) Delusions: 1.1%(1/90) vs 5.6%(10/178) Depression: 2.2%(2/90) vs 6.7%(12/178) Diarrhea: 5.7%(5/90) vs 7.3%(13/178) Dizziness: 7.8%(7/90) vs 8.4%(15/178) Extrapyramidal symptoms: (NR/90) vs (NR/178) Flu syndrome: 1.1%(1/90) vs 9.6%(17/178) Insomnia: 3.3%(3/90) vs 6.2%(11/178) Osteoporosis: 3.3%(3/90) vs 0.0%(0/178) Pain: 5.7%(5/90) vs 5.1%(9/178) Peripheral edema: 1.1%(1/90) vs 7.3%(13/178) Somnolence: 4.4%(4/90) vs 16.9%(30/178) Surgical procedure: 5.7%(5/90) vs 9.0%(16/178) Treatment-emergent central anticholinergic-like events: 10.0%(9/90) vs 22.5%(40/178) Treatment-emergent peripheral anticholinergic-like events: 3.3%(3/90) vs 11.2%(20/178) Urinary tract infection: 5.7%(5/90) vs 5.6%(10/178) Weight gain: 1.1%(1/90) vs 7.3%(13/178) | Placebo vs Olanzapine: Withdrawals: 26.7%(24/90) vs 38.2%(68/178) Withdrawals due to adverse events: 4.4%(4/90) vs 12.4%(22/178)
Depression and Personality Disorder Olanzapine (Soler J et al., 2005)^47^ Western Europe | Design: RCT Setting: Single center Jadad: 2 | Inclusion criteria: CGI ≥ 4, Age 18–45 Exclusion criteria: DSM-IV Axis I disorder, not including primary condition studied, Psychotherapy, Sexually active females of child bearing age not using an effective contraceptive method | Placebo - dosage not reported Olanzapine - 883 mg/day average final dose Duration: 3.0 months | None None | Antidepressants, Mood stabilizers, Benzodiazepines | Assessed at baseline and 12 weeks: HAM_D_HDRS, HAM_A, CGI, Dysfunctional behaviors | 27/NR 13% male NR | 125/60/60 | NR/NR/60 | Depression_mood-Change in HAM-D at 12 weeks: Placebo vs Olanzapine-SMD = −2.438(1.765,3.111) Depression_severity-Change in CGI-S at 12 weeks: Placebo vs Olanzapine-WMD = −11.87(−14.226, −9.514) | Monitored | 1625 Placebo vs Olanzapine: Increased cholesterol: (NR/30) vs (NR/30) Movement disorders: (NR/30) vs (NR/30) Secondary effects: (NR/30) vs (NR/30) Weight gain: (NR/30) vs (NR/30) | Placebo vs Placebo vs Olanzapine vs Olanzapine: Withdrawals: (NR/30) vs (NR/30) vs (NR/30) vs (NR/30)
Tourettes Risperidone (Scahill L et al., 2003)^48^ US | Design: RCT Setting: Single center Jadad: 3 | Inclusion criteria: Age 7–65 Exclusion criteria: Major depressive disorder, Psychosis/psychotic features, Anxiety disorder, Wechsler Intelligence Scale age approximate IQ < 70, Previous adequate trial of risperidone, Medically significant disorders, Y-BOCS or CY-BOCS > 15, Psychotropic medications | Placebo - 3.3 mg/day fixed titration schedule Risperidone - 2.5 mg/day fixed titration schedule Duration: 2.0 months | None 7–14 wk of placebo for patients who completed the wash-out period | Not reported | Assessed at baseline and 8 weeks: Yale Global Tic, TSSR, CGI, Extrapyramidel side effects | 20/6–62 88% male NR | 49/34/34 | 2/0/34 | Tourettes-Change in YALE GLOBAL Tic at 8 weeks: Placebo vs Risperidone-SMD = −1.09(−1.814, −0.365) | Monitored | Placebo vs Risperidone: Blurred vision: 0.0%(0/18) vs 12.5%(2/16) Constipation: 5.5%(1/18) vs 0.0%(0/16) Decreased appetite: 5.5%(1/18) vs 6.5%(1/16) Erectle difficulties: 0.0%(0/18) vs 13.0%(2/16) Fatigue: 5.5%(1/18) vs 37.5%(6/16) Foggy thinking: 0.0%(0/18) vs 12.5%(2/16) Headache: 17.0%(3/18) vs 0.0%(0/16) Increased appetite: 0.0%(0/18) vs 44.0%(7/16) Insomnia: 5.5%(1/18) vs 6.5%(1/16) Nausea/Vomiting: 0.0%(0/18) vs 6.5%(1/16) Sedation: 5.5%(1/18) vs 19.0%(3/16) Social phobia: 0.0%(0/18) vs 13.0%(2/16) | Placebo vs Risperidone: Withdrawals: 5.6%(1/18) vs 6.3%(1/16) Withdrawals due to adverse events: (NR/18) vs (NR/16)

Acronyms in Evidence Table: CCT, Clinical control trial; kg, kilograms; lbs, pounds; ND, Not described; NOS, Not otherwise specified; NR, Not reported; RCT, Randomized control trial; RR, Risk ratio; SMD, Standard mean difference; WMD, Weighted mean difference

Outcomes: ABC, Aberrant Behavior Checklist; ACES, Agitation-Calmness Evaluation Scale; ADAS-cog, Alzheimer’s Disease Assessment Scale; ADHDRS, DuPaul Attention Deficit Hyperactivity Scale; ADL, Activities of Daily Life; AIAQ, Anger, Irritability, and Assault Questionnaire; ASI, Addiction Severity Index; BABS, Brown Assessment of Beliefs Scale; BAI, Beck Anxiety Index; BDHI, Buss-Durkee Hostility Index; BDI, Beck Depression Index; BDS, Blessed Dementia Scale; BEHAVE-AD, Behavioral Pathology in Alzheimer’s Disease Rating Scale; BPRS, Brief Psychiatric Rating Scale; BRMES, Bech-Rafaelsen Melancholia Scale; CAPS, Clinician Administered PTSD Scale; CDSS, Calgary Depression Scale for Schizophrenia; CES-D, Center for Epidemiologic Studies Depression Scale; CGI, Clinical Global Impression Scale; CMAI, Cohen-Mansfield Agitation Inventory; CM-PNB, Cohen-Mansfield Physically Non-Aggressive Behavior; CPRS, Children’s Psychiatric Rating Scale; CSDD, Cornell Scale for Depression in Dementia; CY-BOCS, Children’s Yale-Brown Obsessive-Compulsive Scale; DCM, Dementia Care Mapping; DES, Dissociative Experiences Scale; DTS, Davidson Trauma Scale; E-BEHAVE-AD, Empirical Behavioral Pathology in Alzheimer’s Disease Rating Scale; FAST, Functional Assessment Staging Rating Scale; GAF, Global Assessment of Functioning Scale; HAM-A, Hamilton Rating Scale for Anxiety; HAM-D/HDRS, Hamilton Rating Scale for Depression; IGT, Iowa Gambling Task; MADRS, Montgomery-Asberg Depression Rating Scale; MDRS, Mattis Dementia Rating Scale; MMSE, Mini-Mental State Examination; M-NCAS, Modified Strain in Nursing Care Assessment; MOSES, Multidimentional Observational Scale for Elderly Subjects; MOVES, Motor Tic, Obsessions, and Compulsions, Vocal Tic Evaluation Survey; N-CBRF, Nisonger Child Behavior Rating Scale; NIMH-OC, National Institute of Mental Health Obsessive-Compulsive Scale; NPI, Neuropsychiatric Inventory; NPI/NH, Neuropsychiatric Inventory/Nursing Home; NPI-Q, Neuropsychiatric Inventory Questionnaire; OAS-M, Overt Aggression Scale-Modified; PANSS, Positive and Negative Symptom Scale; PCL-M, Patient Checklist for PTSD--Military Version; PDC, Depression cluster; PDS, Progressive Deterioration Scale; PGDRS, Psychogeriatric Dependency Rating Scale; PGI, Patient Global Impressions; QLDS, Quality of Life in Depression Scale; Q-LES-Q, Quality of Life Enjoyment and Satisfaction Questionnaire; QLS, Quality of Life Scales; QUALID, Quality of Life in Late-Stage Dementia Scale; ROAS, Retrospective Overt Aggression Scale; SANS, Scale for the Assessment of Negative Symptoms; SCL-90, Symptom Checklist-90; SDS, Sheehan Disability Scale; SF-36, Medical Outcomes Study 36-Item Short-Form Health Survey; SIB, Severe Impairment Battery; SIB-Q, Self-injurious Behavior Questionnaire; SIP, Structured Interview for PTSD; SPQ, Schizotypal Personality Questionnaire; SPRINT, Short PTSD Rating Interview; STAS-AX, State-Trait Anger Expression Inventory; STAT-S, Spielberger State-Trait Anger Scale, state version; STAT-T, Spielberger State-Trait Anger Scale, trait version; TOP-8, Treatment Outcome PTSD Scale; TSSS, Tourette’s Syndrome Severity Scale; VAS, Visual Analog Scale ]; Y-BOCS, Yale-Brown Obsessive-Compulsive Scale; YGTSS, Yale Global Tic Severity Scale; YMRS, Young Mania Rating Scale

1 McCracken, J. T., McGough, J., Shah, B., Cronin, P., Hong, D., Aman, M. G., Arnold, L. E., Lindsay, R., Nash, P., Hollway, J., McDougle, C. J., Posey, D., Swiezy, N., Kohn, A., Scahill, L., Martin, A., Koenig, K., Volkmar, F., Carroll, D., Lancor, A., Tierney, E., Ghuman, J., Gonzalez, N. M., Grados, M., Vitiello, B., Ritz, L., Davies, M., Robinson, J., and McMahon, D. Risperidone in children with autism and serious behavioral problems. 2002;347: 5:314–21.

2 Shea, S., Turgay, A., Carroll, A., Schulz, M., Orlik, H., Smith, I., and Dunbar, F. Risperidone in the treatment of disruptive behavioral symptoms in children with autistic and other pervasive developmental disorders. 2004;114: 5:e634–41.

3 De Deyn, P. P., Carrasco, M. M., and Deberdt, W. et al. Olanzapine versus placebo in the treatment of psychosis with or without associated behavioral disturbances in patients with Alzheimer’s disease. 2004;19: 2:115–126.

4 Street, J. S., Clark, W. S., Gannon, K. S., Cummings, J. L., Bymaster, F. P., Tamura, R. N., Mitan, S. J., Kadam, D. L., Sanger, T. M., Feldman, P. D., Tollefson, G. D., and Breier, A. Olanzapine treatment of psychotic and behavioral symptoms in patients with Alzheimer disease in nursing care facilities: a double-blind, randomized, placebo-controlled trial. The HGEU Study Group. 2000;57: 10:968–76.

5 Ruths, S., Straand, J., Nygaard, H. A., Bjorvatn, B., and Pallesen, S. Effect of antipsychotic withdrawal on behavior and sleep/wake activity in nursing home residents with dementia: a randomized, placebo-controlled, double-blinded study. The Bergen District Nursing Home Study. 2004;52: 10:1737–43.

6 Zhong, X., Tariot, P., Minkwitz, M. C., Devine, N. A., and Mintzer, J. Quetiapine for the treatment of agitation in elderly institutionalized patients with dementia: a randomized, double-blind trial. 56th Institute in Psychiatric Services (IPS). 2004.

7 Ballard, C. G., Thomas, A., Fossey, J., Lee, L., Jacoby, R., Lana, M. M., Bannister, C., McShane, R., Swann, A., Juszczak, E., and O’Brien, J. T. A 3-month, randomized, placebo-controlled, neuroleptic discontinuation study in 100 people with dementia: the neuropsychiatric inventory median cutoff is a predictor of clinical outcome. 2004;65: 1:114–9.

8 Brodaty, H., Ames, D., Snowdon, J., Woodward, M., Kirwan, J., Clarnette, R., Lee, E., Lyons, B., and Grossman, F. A randomized placebo-controlled trial of risperidone for the treatment of aggression, agitation, and psychosis of dementia. 2003;64: 2:134–43.

9 Katz, I. R., Jeste, D. V., Mintzer, J. E., Clyde, C., Napolitano, J., and Brecher, M. Comparison of risperidone and placebo for psychosis and behavioral disturbances associated with dementia: a randomized, double-blind trial. Risperidone Study Group. 99;60: 2:107–15.

10 Meguro, K., Meguro, M., Tanaka, Y., Akanuma, K., Yamaguchi, K., and Itoh, M. Risperidone is effective for wandering and disturbed sleep/wake patterns in Alzheimer’s disease. 2004;17: 2:61–7.

11 Mertens, C. Risperidone in the treatment of behavioural disturbances in patients with Alzheimer’s dementia: a double-blind placebo-controlled trial. Beerse: Janssen Research Foundation; 93.

12 Howanitz, E. and Wisotzek, I. Olanzapine versus placebo in the treatment of behavioral disturbances associated with vascular dementia. 2001.

13 Kinrys, G., Nicolaou, C., Simon, N., Worthington, J., and Pollack, M. Adjunctive olanzapine for treatment refractory generalized anxiety disorder: an interim analysis. 2002;5: Suppl 1.

14 Rothschild, A. J., Williamson, D. J., Tohen, M. F., Schatzberg, A., Andersen, S. W., Van Campen, L. E., Sanger, T. M., and Tollefson, G. D. A double-blind, randomized study of olanzapine and olanzapine/fluoxetine combination for major depression with psychotic features. 2004;24: 4:365–73.

15 Corya, S., Dube, S., and Andersen, T. M. et al. Olanzapine-fluoxetine combination for psychotic major depression. Int. J. Neuropsychopharmacol. 2002;5: Suppl. 1:S144.

16 Shi, L., Namjoshi, M. A., Swindle, R., Yu, X., Risser, R., Baker, R. W., and Tohen, M. Effects of olanzapine alone and olanzapine/fluoxetine combination on health-related quality of life in patients with bipolar depression: secondary analyses of a double-blind, placebo-controlled, randomized clinical trial. 2004;26: 1:125–34.

17 Tohen, M., Vieta, E., Calabrese, J., Ketter, T. A., Sachs, G., Bowden, C., Mitchell, P. B., Centorrino, F., Risser, R., Baker, R. W., Evans, A. R., Beymer, K., Dube, S., Tollefson, G. D., and Breier, A. Efficacy of olanzapine and olanzapine-fluoxetine combination in the treatment of bipolar I depression. 2003;60: 11:1079–88.

18 Tohen, M., Jacobs, T. G., Grundy, S. L., McElroy, S. L., Banov, M. C., Janicak, P. G., Sanger, T., Risser, R., Zhang, F., Toma, V., Francis, J., Tollefson, G. D., and Breier, A. Efficacy of olanzapine in acute bipolar mania: a double-blind, placebo-controlled study. The Olanzipine HGGW Study Group. 2000;57: 9:841–9.

19 Tohen, M., Sanger, T. M., McElroy, S. L., Tollefson, G. D., Chengappa, K. N., Daniel, D. G., Petty, F., Centorrino, F., Wang, R., Grundy, S. L., Greaney, M. G., Jacobs, T. G., David, S. R., and Toma, V. Olanzapine versus placebo in the treatment of acute mania. Olanzapine HGEH Study Group. 99;156: 5:702–9.

20 Tohen, M., Bowden, C., Calabrese, J., and et al. Olanzapine versus placebo for relapse prevention in bipolar disorder [poster]. Annual meeting of the American Psychiatric Association. 2003.

21 Tollefson, G. D., Dellva, M. A., Mattler, C. A., Kane, J. M., Wirshing, D. A., and Kinon, B. J. Controlled, double-blind investigation of the clozapine discontinuation symptoms with conversion to either olanzapine or placebo. The Collaborative Crossover Study Group. 99;19: 5:435–43.

22 van Reekum, R., Clarke, D., Conn, D., Herrmann, N., Eryavec, G., Cohen, T., and Ostrander, L. A randomized, placebo-controlled trial of the discontinuation of long-term antipsychotics in dementia. 2002;14: 2:197–210.

23 Calabrese, J., Macfadden, W., McCoy, R., Minkwitz, M., Wilson, E., and Mullen, J. Double-blind, placebo-controlled study of quetiapine in bipolar depression. 157th Annual Meeting of the American Pyschiatric Association. 2004.

24 Mintzer, J. and et al. Efficacy and safety of a flexible dose of risperidone versus placebo in the treatment of psychosis of Alzheimer’s disease. Poster presented at the 4th Annual Meeting of the ICGP. 2004.

25 Gharabawi, G. M., Mahmoud, R., Loescher, A., and et al. Augmentation with risperidone in patients with resistant depression: results of the 24-week randomized double-blind trial [poster]. 24th Annual Meeting of the Collegium Internationale Neuro-Psychopharmacologicum. 2004.

26 Daniels, D. G., Zimbroff, D., and Potkin, S. G. et al. Ziprasidone 80 mg/day and 160 mg/day in the acute exacerbation of schizophrenia nad schizoaffective disorder: a 6-week, placebo-controlled trial. The ziprasidone study group. 99;20:490–505.

27 Keck, P. Jr, Buffenstein, A., Ferguson, J., Feighner, J., Jaffe, W., Harrigan, E. P., and Morrissey, M. R. Ziprasidone 40 and 120 mg/day in the acute exacerbation of schizophrenia and schizoaffective disorder: a 4-week placebo-controlled trial. 98;140: 2:173–84.

28 Padala, P. R., Monnahan, M., Ramaswamy, S., and et al. Risperidone in the treatment for post-traumatic stress disorder (PTSD) in women [poster]. NCDEU. 2005.

29 Reich, D. B., Winternitz, S., Hennen, J., Watts, T., and Stanculescu, C. A preliminary study of risperidone in the treatment of posttraumatic stress disorder related to childhood abuse in women. 2004;65: 12:1601–6.

30 Bystritsky, A., Ackerman, D. L., Rosen, R. M., Vapnik, T., Gorbis, E., Maidment, K. M., and Saxena, S. Augmentation of serotonin reuptake inhibitors in refractory obsessive-compulsive disorder using adjunctive olanzapine: a placebo-controlled trial. 2004;65: 4:565–8.

31 Buchsbaum, M. S. Risperidone in refractory obsessive-compulsive disorder (OCD): positron emission tomography (PET) imaging [abstract]. 23rd Annual conference of the Anxiety Disorders Association of America. 2003.

32 Erzegovesi, S., Guglielmo, E., Siliprandi, F., and Bellodi, L. Low-dose risperidone augmentation of fluvoxamine treatment in obsessive-compulsive disorder: a double-blind, placebo-controlled study. 2005;15: 1:69–74.

33 Hollander, E., Rossi, N. B., Sood, E., and Pallanti, S. Risperidone augmentation in treatment-resistant obsessive-compulsive disorder: a double-blind, placebo-controlled study. 2003;6: 4:397–401.

34 Butterfield, M. I., Becker, M. E., Connor, K. M., Sutherland, S., Churchill, L. E., and Davidson, J. R. Olanzapine in the treatment of post-traumatic stress disorder: a pilot study. 2001;16: 4:197–203.

35 Stein, M. B., Kline, N. A., and Matloff, J. L. Adjunctive olanzapine for SSRI-resistant combat-related PTSD: a double-blind, placebo-controlled study. 2002;159: 10:1777–9.

36 Hamner, M. B., Faldowski, R. A., Ulmer, H. G., Frueh, B. C., Huber, M. G., and Arana, G. W. Adjunctive risperidone treatment in post-traumatic stress disorder: a preliminary controlled trial of effects on comorbid psychotic symptoms. 2003;18: 1:1–8.

37 Monnelly, E. P., Ciraulo, D. A., Knapp, C., and Keane, T. Low-dose risperidone as adjunctive therapy for irritable aggression in posttraumatic stress disorder. 2003;23: 2:193–6.

38 Bogenschutz, M. P. and George Nurnberg, H. Olanzapine versus placebo in the treatment of borderline personality disorder. 2004;65: 1:104–9.

39 Zanarini, M. C. and Frankenburg, F. R. Olanzapine treatment of female borderline personality disorder patients: a double-blind, placebo-controlled pilot study. 2001;62: 11:849–54.

40 Koenigsberg, H. W., Reynolds, D., Goodman, M., New, A. S., Mitropoulou, V., Trestman, R. L., Silverman, J., and Siever, L. J. Risperidone in the treatment of schizotypal personality disorder. 2003;64: 6:628–34.

41 Sallee, F. R., Kurlan, R., Goetz, C. G., Singer, H., Scahill, L., Law, G., Dittman, V. M., and Chappell, P. B. Ziprasidone treatment of children and adolescents with Tourette’s syndrome: a pilot study. 2000;39: 3:292–9.

42 Breder, C., Swanink, R., Marcus, R., and et al. Dose-ranging study of ariprprazole in patients with Alzheimer’s dementia. Poster. 9th International Conference on Alzheimer’s Desease and Related Disorders. 2004.

43 De Deyn, P., Jeste, D. V., Swanink, R., Kostic, D., Breder, C., Carson, W. H., and Iwamoto, T. Aripiprazole for the treatment of psychosis in patients with Alzheimer’s disease: a randomized, placebo-controlled study. 2005;25: 5:463–7.

44 Streim JE, McQuade RD, Stock E, Goyvaerts H, Breder C, Iwamoto T, and Yamamoto Y. Aripiprazole treatment of institutionalized patients with psychosis of alszheimer’s dementia. 2004.

45 McQuade R, Sanche R, Marcus R, Carson W, Rollin L, Iwamoto T, and Stock E. Aripiprazole for relapse prevention in bipolar depression in a 26-week trial. 2004.

46 Kennedy, J., Deberdt, W., Siegal, A., Micca, J., Degenhardt, E., Ahl, J., Meyers, A., Kaiser, C., and Baker, R. W. Olanzapine does not enhance cognition in non-agitated and non-psychotic patients with mild to moderate Alzheimer’s dementia. 2005;20: 11:1020–7.

47 Soler, J., Pascual, J. C., Campins, J., Barrachina, J., Puigdemont, D., Alvarez, E., and Perez, V. Double-blind, placebo-controlled study of dialectical behavior therapy plus olanzapine for borderline personality disorder. 2005;162: 6:1221–4.

48 Scahill, L., Leckman, J. F., Schultz, R. T., Katsovich, L., and Peterson, B. S. A placebo-controlled trial of risperidone in Tourette syndrome. 2003;60: 7:1130–5.

49 Gharabawi, G. M., Canuso, C., Greenspan, A., and et al. Remission and maintenance effect of risperidone augmentation for older patients with resistant depression [abstract]. 2004;29: Suppl 1:S87.

C4_ Evidence Tables

Augmentation Trials

Condition, Drug Author, Year, Country, Trial named | Study design Setting Quality (Jadad Score) | Eligibility criteria | Interventions (drug, dose, duration) | Run-in period/ Randomization Method Wash-out period/ Randomization Method | Allowed other medications | Method of outcome assessment Timing of assessment | Age mean/ Age range Gender Ethnicity | Screened/Eligible/Enrolled | Withdrawn/Lost to FU/Analyzed | Results | Methods of adverse events assessment | Adverse events reported | Total withdrawals Withdrawals due to adverse events
Depression Olanzapine (Tohen M et al., 2002)^1^ US & Canada | Design: RCT Setting: Multi- center Jadad: 3 | Inclusion criteria: Previous depressed, manic, or mixed episode, YMRS ≥ 16, Treatment = lithium or valproate at therapeutic level Exclusion criteria: NR | Lithium-dosage not reported or Valproate- dosage not reported Olanzapine-10.4 mg/day average final dose, Lithium or Valproate Duration: 1.5 months | None 2–7 dy of Concomitant medication except lithium or valproate for randomization not described | Benzodiazepines | Assessed at baseline and 6 weeks: YMRS, HAM_D_HDRS, PANSS, CGI | 41/NR 48% male Caucasian, NOS | 501/344/344 | 94/8/334 | Outcome of interested for statistical analysis not reported. | Monitored | Lithium or valproate vs Olanzapine + (lithium or valproate): Asthenia: 13.0%(14.95/115) vs 18.3%(41.907/229) Depression: 17.4%(20.01/115) vs 17.9%(40.991/229) Diarrhea: 14.8%(17.02/115) vs 11.8%(27.022/229) Dizziness: 7.0%(8.05/115) vs 13.5%(30.915/229) Dry mouth: 7.8%(8.97/115) vs 31.9%(73.051/229) Headache: 18.3%(21.045/115) vs 15.7%(35.953/229) Increased appetite: 7.8%(8.97/115) vs 23.6%(54.044/229) Nervousness: 14.8%(17.02/115) vs 10.5%(24.045/229) Somnolence: 27.0%(31.05/115) vs 51.5%(117.935/229) Speech disorder: 0.9%(1.035/115) vs 6.6%(15.114/229) Thirst: 6.1%(7.015/115) vs 10.0%(22.9/229) Tremor: 13.0%(14.95/115) vs 23.1%(52.899/229) Weight gain: 7.0%(8.05/115) vs 26.2%(59.998/229) Weight change in kg: Monotherapy, Full Sample-115 people (0.23 mean,2.48 SD) vs Monotherapy, Lithium-41 people (Mean NR, SD NR) vs Monotherapy, Valproate-73 people (Mean NR, SD NR) vs Olanzapine Cotherapy, Full Sample-229 people (3.08 mean,3.04 SD) vs Olanzapine Cotherapy, Lithium-74 people (Mean NR, SD NR) vs Olanzapine Cotherapy, Valproate-145 people (Mean NR, SD NR) | Lithium or valproate vs Olanzapine + (lithium or valproate): Withdrawals: 28.7%(33/115) vs 30.1%(69/229) Withdrawals due to adverse events: 1.7%(2/115) vs 10.9%(25/229)
Depression Quetiapine (Yargic LI et al., 2004)^2^ Turkey | Design: RCT Setting: Multi- center Jadad: 2 | Inclusion criteria: HAM- D Items 10 and 11 ≥ 2, HAM-D ≥ 26 Exclusion criteria: HAM- D Item 3 > 2, Psychotic disorder, Use psychotropic medications within 4 wks, Medically significant disorders, Abnormal laboratory results, Bipolar disorder, Alcohol or substance abuse or dependency, Pregnant | Paroxetine-27.6 mg/day average final dose Quetiapine-60 mg/day average final dose, Paroxetine-27.0 mg/day average final dose Duration: 2.0 months | None None | NR | Assessed at baseline and 8weeks: HAM_D_HDRS, HAM_A, CGI | 35/18–65 26% male NR | NR/120/NR | 17/NR/84 | Depression_mood- Change in HAM-D at 8 weeks: Paroxetine vs Paroxetine + quetiapine-SMD = −0.223 (−0.595,0.149) | Elicited by investigator, reported by patient | Paroxetine + quetiapine vs Paroxetine: Increased anxiety: 2.0%(1.16/58) vs 13.3%(7.182/54) Increased appetite: 20.4%(11.832/58) vs 2.4%(1.296/54) Insomnia: 0.0%(0/58) vs 31.0%(16.74/54) | Paroxetine + quetiapine vs Paroxetine: Withdrawals: 19.0%(11/58) vs 31.5%(17/54) Withdrawals due to adverse events: 3.4%(2/58) vs 16.7%(9/54)
OCD Quetiapine (Atmaca M et al., 2002)^3^ Turkey | Design: RCT Setting: Single center Jadad: 2 | Inclusion criteria: Y- BOCS ≥ 18, CGI-I minimal improvement Exclusion criteria: NR | SRI- varied depending on drug Quetiapine-91.1 mg/day average final dose, SRI- varied depending on drug Duration: 2.0 months | 3 mo of SSRIs for patients refractory to SRI monotherapy None | NR | Assessed at baseline and 8 weeks: YBOCS, CGI | 28/18–49 52% male NR | 52/27/27 | 0/0/27 | OCD-Change in Y- BOCS at 8 weeks: SRI + placebo vs SRI + quetiapine-WMD = −8(-−10.876, −5.124) OCD-Change in Number of Responders at 8 weeks: SRI + placebo vs SRI + quetiapine-RR = 19.6(1.263115, 304.1371) OCD_severity-Change in CGI-S at 8 weeks: SRI + placebo vs SRI + quetiapine-WMD = − 1.34 (−2.209,−0.471) | Monitored, reported by patient | SRI + placebo vs SRI + quetiapine: At least one adverse event: 30.8%(4/13) vs 64.3%(9/14) Dizziness: 0.0%(0/13) vs 7.1%(1/14) Headache: 7.7%(1/13) vs 0.0%(0/14) Nausea: 0.0%(0/13) vs 42.9%(6/14) Nervousness: 7.7%(1/13) vs 0.0%(0/14) Sedation: 15.4%(2/13) vs 21.4%(3/14) Weight change in kg: SRI + Placebo-13 people (1.6 mean,1.3 SD) vs SRI + Quetiapine-14 people (1.9 mean,1.8 SD) | SRI + placebo vs SRI + quetiapine: Withdrawals: 0.0%(0/13) vs 0.0%(0/14) Withdrawals due to adverse events: 0.0%(0/13) vs 0.0%(0/14)
OCD Quetiapine (Denys D et al., 2004)^4^ Western Europe | Design: RCT Setting: Single center Jadad: 4 | Inclusion criteria: Age 18–65, Y-BOCS ≥ 18, Y- BOCS ≥ 12, if only obsessions or compulsions were present, Refractory to SRI therapy Exclusion criteria: Tic disorder, Tourettes disorder, Major depressive disorder, Pregnant, Organic mental disorder, Seizure disorder or epilepsy or risk, Neurological disorder, Bipolar disorder | SRI-20 to 300 mg, depending on drug Quetiapine-150 mg/day average final dose, SRI-20 to 300 mg, depending on drug Duration: 2.0 months | None None | NR | Assessed at baseline and 8 weeks: YBOCS, HAM_D_HDRS, HAM_A, SDS, BABS, CGI | 35/18–60 25% male NR | NR/40/40 | 1/0/40 | OCD-Change in Y- BOCS at 8 weeks: SRI + placebo vs SRI + quetiapine-WMD = −5.4 (−9.342,−1.458) OCD-Change in Number of Responders at 8 weeks: SRI + placebo vs SRI + quetiapine-RR = 4(0.9,16.5) OCD_improvement- Change in CGI-I at 8 weeks: SRI + placebo vs SRI + quetiapine-WMD = − 0.85 (−1.411,−0.289) | Elicited by investigator, reported by patient, clinical observation and exam | SRI + placebo vs SRI + quetiapine: At least 2 or 3 adverse events: 100.0%(20/20) vs 100.0%(20/20) Asthenia: 0.0%(0/20) vs 10.0%(2/20) Change in mood: 15.0%(3/20) vs 10.0%(2/20) Diarrhea: 10.0%(2/20) vs 0.0%(0/20) Dizziness: 0.0%(0/20) vs 30.0%(6/20) Dry mouth: 40.0%(8/20) vs 55.0%(11/20) Increased appetite: 0.0%(0/20) vs 20.0%(4/20) Muscular pain: 0.0%(0/20) vs 10.0%(2/20) Nightmares: 0.0%(0/20) vs 10.0%(2/20) Palpitations: 10.0%(2/20) vs 0.0%(0/20) Problems with concentration: 0.0%(0/20) vs 15.0%(3/20) Somnolence: 35.0%(7/20) vs 95.0%(19/20) Sweating: 30.0%(6/20) vs 10.0%(2/20) Weight gain: 0.0%(0/20) vs 30.0%(6/20) | SRI + placebo vs SRI + quetiapine: Withdrawals: 0.0%(0/20) vs 5.0%(1/20) Withdrawals due to adverse events: 0.0%(0/20) vs 0.0%(0/20)
OCD Risperidone (Cavedini P et al., 2004)^5^ Western Europe | Design: RCT Setting: Single center Jadad: 4 | Inclusion criteria: NR Exclusion criteria: DSM- IV Axis I disorder, not including primary condition studied, Tic disorder, Medically significant disorders, Severe internal or neurological disease, Brain injury or head trauma, Alcohol or substance abuse or dependency | Fluvoxamine-245 mg/day average final dose Fluvoxamine-255 mg/day average final dose Risperidone-0.5 mg/day fixed single dose Duration: 3.0 months | None None | No other concomitant therapy, either pharmacologic or non-pharmacologic was allowed. | Assessed at baseline and 12 weeks: YBOCS, IGT | 36/NR 37% male NR | NR/30/30 | NR/NR/NR | OCD-Change in Y- BOCS at 12 weeks: Fluvoxamine + placebo (good IGT+) vs Fluvoxamine + risperidone (bad IGT)- WMD = −0.4 (−6.305,5.505) OCD-Change in Y- BOCS at 12 weeks: Fluvoxamine + placebo (bad IGT+) vs Fluvoxamine + risperidone (bad IGT)- WMD = −7.9 (−14.842,−0.958) OCD – Change in severity Fluv + placebo (good IGT) vs. Fluv + risperidone (bad IGT): RR=0.889, (0.612, 1.290) Fluv + placebo (bad IGT) vs. Fluv + risperidone (bad IGT): RR=8.0, (1.214, 52.692) | NR | No adverse events reported. | Fluvoxamine + Placebo vs Fluvoxamine + Placebo vs Fluvoxamine + Risperidone: Withdrawals: Not reported Withdrawals due to adverse events: Not reported
OCD Risperidone (McDougle CJ et al., 2000)^6^ US | Design: Trial + open label Setting: Single center Jadad: 4 | Inclusion criteria: 1 year duration primary condition, CGI ≥ moderate severity, Refractory to SRI therapy Exclusion criteria: Non- healthy, Pregnant, Use psychotropic medications within 4 wks | Risperidone-2.2 mg/day average final dose, Clomipramine-250 mg/day average final dose, Fluvoxamine-300 mg/day average final dose Duration: 1.5 months | 12 wk of SRI monotherapy for patients refractory to SRI monotherapy None | None | Assessed at baseline and 6 weeks: YBOCS, HAM_D_HDRS, HAM_A, Yale Global Tic, CGI | 37/19–63 58% male Caucasian, African-American, Hispanic, Asian | 70/36/36 | 3/0/33 | OCD-Change in Y- BOCS at 6 weeks: Placebo + SRI vs Risperidone + SRI- WMD = −6.29 (−10.777,−1.803) OCD-Change in Number of Responders at 6 weeks: Placebo + SRI vs Risperidone + SRI-RR = 16(1.0,254.1) OCD_improvement- Change in CGI-I at 6 weeks: Placebo + SRI vs Risperidone + SRI- WMD = −0.8 (−2.065,0.465) | Monitored | Placebo + SRI vs Risperidone + SRI: At least one adverse event: 100.0%(15/16) vs 90.0%(18/20) Blurred vision: 12.5%(2/16) vs 0.0%(0/20) Constipation: 0.0%(0/16) vs 5.0%(1/20) Diaphoresis: 25.0%(4/16) vs 5.0%(1/20) Diarrhea: 6.3%(1/16) vs 0.0%(0/20) Dry mouth: 31.3%(5/16) vs 25.0%(5/20) Headache: 31.3%(5/16) vs 0.0%(0/20) Increased appetite: 18.8%(3/16) vs 30.0%(6/20) Insomnia: 6.3%(1/16) vs 5.0%(1/20) Lightheadedness: 25.0%(4/16) vs 5.0%(1/20) Muscle stiffness: 6.3%(1/16) vs 0.0%(0/20) Palpitations: 6.3%(1/16) vs 0.0%(0/20) Restlessness: 37.5%(6/16) vs 30.0%(6/20) Sedation: 50.0%(8/16) vs 85.0%(17/20) Tinnitus: 6.3%(1/16) vs 10.0%(2/20) Urinary urgency: 0.0%(0/16) vs 5.0%(1/20) | Placebo + SRI vs Risperidone + SRI: Withdrawals: 6.3%(1/16) vs 10.0%(2/20) Withdrawals due to adverse events: 0.0%(0/16) vs 5.0%(1/20)
OCD and Tourettes Olanzapine (Shapira NA et al., 2004)^7^ US | Design: RCT Setting: Single center Jadad: 3 | Inclusion criteria: Age 14–70, 1 year duration primary condition, CGI ≥ moderate severity, Y-BOCS ≥ 19 Exclusion criteria: Major depressive disorder, Psychotic disorder, Bipolar disorder, Alcohol or substance abuse or dependency, Seizure disorder or epilepsy or risk, Encephalitis, Brain injury or head trauma, Medically significant disorders | Placebo-5.9 mg/day average final dose, Fluoxetine-40 mg Olanzapine-6.1 mg/day average final dose, Fluoxetine-40 mg Duration: 1.5 months | 1 wk of Placebo for randomization not described None | NR | Assessed at baseline and 6 weeks: YBOCS | 37/NR 41% male NR | 74/44/44 | 4/3/1944 | OCD-Change in Y- BOCS at 6 weeks: Fluoxetine + placebo vs Fluoxetine + olanzapine-WMD = − 1.9(−5.033,1.233) OCD-Change in Number of Responders at 6 weeks: Fluoxetine + placebo vs Fluoxetine + olanzapine-RR = 1(0.5,2.0) | NR | No adverse events reported. Weight change in kg: Fluoxetine + placebo-22 people (0.5 mean,1.8 SD) vs Fluoxetine + Olanzapine-22 people (2.8 mean,3.1 SD) | Fluoxetine + Placebo vs Fluoxetine + Olanzapine: Withdrawals: 9.1%(2/22) vs 22.7%(5/22) Withdrawals due to adverse events: 9.1%(2/22) vs 9.1%(2/22)
Depression Ziprasidone (Dunner D et al., 2003)^8^ US | Design: RCT Setting: NR Jadad: 1 | Inclusion criteria: Age 21–65, MADRS ≥ 20, Resistant to antidepressant therapy, MADRS ≥ 30% reduction at week 7, CGI ≥ 4, Male or female Exclusion criteria: NR | Sertraline -100–200 mg/day fixed titration schedule Ziprasidone -80 or 160 mg/day fixed titration schedule, Sertraline -100–200 mg/day fixed titration schedule Duration: 2.0 months | 6 wk of Sertraline for non-placebo responders None | Not reported | Assessed at baseline and 8 weeks: MADRS, HAM_D_HDRS, CGI | 44 / NR 48% male NR | 90/64/64 | NR/NR/60 | Depression_improvement-Change in CGI-I at 8 weeks: Sertraline vs Sertraline + Ziprasidone-WMD = −0.625(−1.006,−0.244) Depression_mood-Change in MADRS at 8 weeks: Sertraline vs Sertraline + Ziprasidone-SMD = −0.444(−0.807,−0.082) Depression_severity-Change in CGI-S at 8 weeks: Sertraline vs Sertraline + Ziprasidone-WMD = −0.62(−0.988,−0.252) | Monitored | Sertraline vs Ziprasidone: Abnormal ejaculation: 5.0%(1/21) vs 0.0%(0/43) Abnormal thinking: 0.0%(0/21) vs 9.3%(4/43) Abnormal vision: 0.0%(0/21) vs 11.6%(5/43) Agitation: 0.0%(0/21) vs 20.9%(9/43) Anxiety: 10.0%(2/21) vs 0.0%(0/43) Asthenia: 0.0%(0/21) vs 20.9%(9/43) Back pain: 0.0%(0/21) vs 4.7%(2/43) Constipation: 0.0%(0/21) vs 9.3%(4/43) Dizziness: 0.0%(0/21) vs 18.6%(8/43) Dry Mouth: 0.0%(0/21) vs 14.0%(6/43) Headache: 5.0%(1/21) vs 16.3%(7/43) Insomnia: 5.0%(1/21) vs 30.2%(13/43) Nausea: 0.0%(0/21) vs 11.6%(5/43) Neck pain: 0.0%(0/21) vs 4.7%(2/43) Respiratory tract infection: 0.0%(0/21) vs 11.6%(5/43) Somnolence: 10.0%(2/21) vs 18.6%(8/43) Tooth disorder: 0.0%(0/21) vs 7.0%(3/43) Tremor: 5.0%(1/21) vs 16.3%(7/43) | Sertraline vs Ziprasidone: Withdrawals: (NR/21) vs (NR/43) Withdrawals due to adverse events: (NR/21) vs (NR/43)
OCD and Depression Quetiapine (Carey PD et al., 2005)^9^ Canada, South Africa ISRCTN830507 62 | Design: RCT Setting: Multi- center Jadad: 5 | Inclusion criteria: Age 18–65, Y-BOCS < 25% improvement > 12 wks of SRI treatment at maximum tolerated dose, CGI-I minimal improvement, CGI = worse Exclusion criteria: Lactating, Sexually active females of child bearing age not using an effective contraceptive method, Medically significant disorders, Brain injury or head trauma, Co- existing Axis -I disorder unless deemed to be secondary to OCD, Brain Surgery, Seizure disorder or epilepsy or risk, Medications that interact with Quetiapine | Placebo -228.57 mg/day average final dose, Fluvoxamine 100–300 mg/day flexible dose, Fluoxetine 20–300 mg/day flexible dose, Paroxetine 60–300 mg/day flexible dose, Citalopram 50–300 mg/day flexible dose Quetiapine − 168.75 mg/day average final dose, Fluvoxamine 25– 300 mg/day flexible dose, Fluoxetine 20–300 mg/day flexible dose, Paroxetine 50–300 mg/day flexible dose, Citalopram 60–300 mg/day flexible dose, Clomipramine 100–300 mg/day flexible dose, Sert Duration: 1.5 months | 6–12 wk of SSRIs for patients refractory to SRI None | Not reported | Assessed at baseline and 6 weeks: YBOCS, CGI, MADRS, SDS, Yale Global Tic | 33 / NR 46% male NR | NR/42/42 | 2/0/41 | Depression_mood-Change in MADRS at 6 weeks: Placebo vs Quetiapine-SMD = 0.71(0.077,1.342) Depression_severity-Change in CGI-S at 6 weeks: Placebo vs Quetiapine-WMD = −3.61(−6.968,−0.252) OCD-Change in Y-BOCs at 6 weeks: Placebo vs Quetiapine-SMD = −0.146(− 0.759,0.467) OCD-Change in Number of Responders at 6 weeks: Placebo vs Quetiapine-RR = 1.28(0.609,2.691) | Monitored | Placebo vs Quetiapine: Abdominal tenderness: 0.0%(0/21) vs 5.0%(1/21) Delayed ejaculation: 0.0%(0/21) vs 5.0%(1/21) Dizziness: 14.3%(3/21) vs 5.0%(1/21) Dry Mouth: 0.0%(0/21) vs 15.0%(3/21) Fatigue: 19.0%(4/21) vs 15.0%(3/21) Headache: 38.0%(8/21) vs 15.0%(3/21) Impared concentration: 0.0%(0/21) vs 10.0%(2/21) Increased appetite: 9.5%(2/21) vs 5.0%(1/21) Irritability: 4.7%(1/21) vs 10.0%(2/21) Memory difficulties: 0.0%(0/21) vs 5.0%(1/21) Muscle aches: 0.0%(0/21) vs 5.0%(1/21) Nausea: 9.5%(2/21) vs 5.0%(1/21) Sedation: 33.3%(7/21) vs 75.0%(15/21) Slurred speech: 0.0%(0/21) vs 5.0%(1/21) Weight gain: 0.0%(0/21) vs 5.0%(1/21) Worsening mood: 4.7%(1/21) vs 5.0%(1/21) | Placebo vs Quetiapine: Withdrawals: 0.0%(0/21) vs 9.5%(2/21) Withdrawals due to adverse events: 0.0%(0/21) vs 9.5%(2/21)
OCD and Depression Quetiapine (Fineberg NA et al., 2005)^10^ UK | Design: RCT Setting: NR Jadad: 3 | Inclusion criteria: Y- BOCS < 25% improvement > 12 wks of SRI treatment at maximum tolerated dose, Y-BOCS ≥ 18 Exclusion criteria: DSM- IV Axis I disorder, not including primary condition studied, DSM- IV Axis I disorder, not including primary condition studied or depression with MADRS < 30, Tourettes disorder, Resistant to antipsychotic treatment | Placebo - dosage not reported, Paroxetine 40– 60 mg/day flexible dose, Citalopram 60–80 mg/day flexible dose, Sertraline 200 mg/day average final dose Quetiapine − 215 mg/day average final dose, Paroxetine 60 mg/day average final dose, Sertraline 75–200 mg/day flexible dose Duration: 4.0 months | None None | Not reported | Assessed at baseline and 16 weeks: YBOCS, Yale Global Tic, CGI, MADRS, NIMH-OC, Extrapyramidel side effects, SDS | 38 / NR 43% male NR | NR/21/21 | 4/0/21 | Depression_mood-Change in MADRS at 16 weeks: Placebo vs Quetiapine-SMD = −1.06(−1.98,−0.14) Depression_severity-Change in CGI-S at 16 weeks: Placebo vs Quetiapine-WMD = −0.4(−1.302,0.502) OCD-Change in Y-BOCs at 16 weeks: Placebo vs Quetiapine-SMD = 0.615(−0.264,1.493) OCD-Change in Number of Responders at 16 weeks: Placebo vs Quetiapine-RR = 2.727(0.336,22.158) | Monitored | Placebo vs Quetiapine: Drowsiness: (NR/10) vs 72.7%(8/11) Dry Mouth: (NR/10) vs 54.5%(6/11) Fatigue: (NR/10) vs 9.1%(1/11) Headache: (NR/10) vs 54.5%(6/11) Restless limbs: (NR/10) vs 36.4%(4/11) Stiffness: (NR/10) vs 45.5%(5/11) | Placebo vs Quetiapine: Withdrawals: 10.0%(1/10) vs 27.3%(3/11) Withdrawals due to adverse events: 0.0%(0/10) vs 9.1%(1/11)
OCD and Depression Risperidone (Li X et al., 2005)^11^ US | Design: CCT, Crossover Setting: Single center Jadad: 2 | Inclusion criteria: Y- BOCS ≥ 10 on items 1– 5, Y-BOCS ≥ 16 Exclusion criteria: DSM- IV Axis I disorder, not including primary condition studied, SADS-L (Schedule for Affective Disorders and Schizophrenia - Lifetime version) Criteria, Major motor disorder, Vocal tics | Placebo - dosage not reported, Fluoxetine or Paroxitine = 40/mg/day, Fluvoxamine = 200 mg/day, or Sertraline = 100mg/day - therapeutic doses for at least 12 weeks Haloperidol - 2 mg/day fixed single dose, Fluoxetine or Paroxitine = 40/mg/day, Fluvoxamine = 200 mg/day, or Sertraline = 100mg/day - therapeutic doses for at least 12 weeks Risperidone - 1 mg/day fixed single dose, Fluoxetine or Paroxitine = 40/mg/day, Fluvoxamine = 200 mg/day, or Sertraline = 100mg/day - therapeutic doses for at leas Duration: 2.3 months | 1 wk of placebo for randomization not described 1 wk of placebo for randomization not described | Antihistamine, Benztropine | Assessed at baseline and 2 weeks: YBOCS, SCL_90, HAM_D_HDRS, POMS, SNST, HVLT-R, CPT | 34 / 19–56 44% male NR | 27/16/16 | NR/NR/NR | OCD Crossover study. | Monitored | Adverse events not reported before crossover. | Placebo vs Placebo vs Haloperidol vs Haloperidol vs Risperidone vs Risperidone: Withdrawals: (NR/6) vs (NR/6) vs (NR/5) vs (NR/5) vs (NR/5) vs (NR/5) Withdrawals due to adverse events: (NR/6) vs (NR/6) vs (NR/5) vs (NR/5) vs (NR/5) vs (NR/5)

Acronyms in Evidence Table: CCT, Clinical control trial; kg, kilograms; lbs, pounds; ND, Not described; NOS, Not otherwise specified; NR, Not reported; RCT, Randomized control trial; RR, Risk ratio; SMD, Standard mean difference; WMD, Weighted mean difference

Outcomes: ABC, Aberrant Behavior Checklist; ACES, Agitation-Calmness Evaluation Scale; ADAS-cog, Alzheimer’s Disease Assessment Scale; ADHDRS, DuPaul Attention Deficit Hyperactivity Scale; ADL, Activities of Daily Life; AIAQ, Anger, Irritability, and Assault Questionnaire; ASI, Addiction Severity Index; BABS, Brown Assessment of Beliefs Scale; BAI, Beck Anxiety Index; BDHI, Buss-Durkee Hostility Index; BDI, Beck Depression Index; BDS, Blessed Dementia Scale; BEHAVE-AD, Behavioral Pathology in Alzheimer’s Disease Rating Scale; BPRS, Brief Psychiatric Rating Scale; BRMES, Bech-Rafaelsen Melancholia Scale; CAPS, Clinician Administered PTSD Scale; CDSS, Calgary Depression Scale for Schizophrenia; CES-D, Center for Epidemiologic Studies Depression Scale; CGI, Clinical Global Impression Scale; CMAI, Cohen-Mansfield Agitation Inventory; CM-PNB, Cohen-Mansfield Physically Non-Aggressive Behavior; CPRS, Children’s Psychiatric Rating Scale; CSDD, Cornell Scale for Depression in Dementia; CY-BOCS, Children’s Yale-Brown Obsessive-Compulsive Scale; DCM, Dementia Care Mapping; DES, Dissociative Experiences Scale; DTS, Davidson Trauma Scale; E-BEHAVE-AD, Empirical Behavioral Pathology in Alzheimer’s Disease Rating Scale; FAST, Functional Assessment Staging Rating Scale; GAF, Global Assessment of Functioning Scale; HAM-A, Hamilton Rating Scale for Anxiety; HAM-D/HDRS, Hamilton Rating Scale for Depression; IGT, Iowa Gambling Task; MADRS, Montgomery-Asberg Depression Rating Scale; MDRS, Mattis Dementia Rating Scale; MMSE, Mini-Mental State Examination; M-NCAS, Modified Strain in Nursing Care Assessment; MOSES, Multidimentional Observational Scale for Elderly Subjects; MOVES, Motor Tic, Obsessions, and Compulsions, Vocal Tic Evaluation Survey; N-CBRF, Nisonger Child Behavior Rating Scale; NIMH-OC, National Institute of Mental Health Obsessive-Compulsive Scale; NPI, Neuropsychiatric Inventory; NPI/NH, Neuropsychiatric Inventory/Nursing Home; NPI-Q, Neuropsychiatric Inventory Questionnaire; OAS-M, Overt Aggression Scale-Modified; PANSS, Positive and Negative Symptom Scale; PCL-M, Patient Checklist for PTSD--Military Version; PDC, Depression cluster; PDS, Progressive Deterioration Scale; PGDRS, Psychogeriatric Dependency Rating Scale; PGI, Patient Global Impressions; QLDS, Quality of Life in Depression Scale; Q-LES-Q, Quality of Life Enjoyment and Satisfaction Questionnaire; QLS, Quality of Life Scales; QUALID, Quality of Life in Late-Stage Dementia Scale; ROAS, Retrospective Overt Aggression Scale; SANS, Scale for the Assessment of Negative Symptoms; SCL-90, Symptom Checklist-90; SDS, Sheehan Disability Scale; SF-36, Medical Outcomes Study 36-Item Short-Form Health Survey; SIB, Severe Impairment Battery; SIB-Q, Self-injurious Behavior Questionnaire; SIP, Structured Interview for PTSD; SPQ, Schizotypal Personality Questionnaire; SPRINT, Short PTSD Rating Interview; STAS-AX, State-Trait Anger Expression Inventory; STAT-S, Spielberger State-Trait Anger Scale, state version; STAT-T, Spielberger State-Trait Anger Scale, trait version; TOP-8, Treatment Outcome PTSD Scale; TSSS, Tourette’s Syndrome Severity Scale; VAS, Visual Analog Scale; Y-BOCS, Yale-Brown Obsessive-Compulsive Scale; YGTSS, Yale Global Tic Severity Scale; YMRS, Young Mania Rating Scale

1 Tohen, M., Chengappa, K. N., Suppes, T., Zarate, C. A. Jr, Calabrese, J. R., Bowden, C. L., Sachs, G. S., Kupfer, D. J., Baker, R. W., Risser, R. C., Keeter, E. L., Feldman, P. D., Tollefson, G. D., and Breier, A. Efficacy of olanzapine in combination with valproate or lithium in the treatment of mania in patients partially nonresponsive to valproate or lithium monotherapy. 2002;59: 1:62–9.

2 Yargic, L. I., Corapcioglu, A., Kocabasoglu, N., Erdogan, A., Koroglu, G., and Yilmaz, D. A prospective randomized single-blind, multicenter trial comparing the efficacy and safety of paroxetine with and without quetiapine therapy in depression associated with anxiety. 2004;8: 4: 205–211 URL: http://www.tandf.co.uk/journals/md/13651501.html.

3 Atmaca, M., Kuloglu, M., Tezcan, E., and Gecici, O. Quetiapine augmentation in patients with treatment resistant obsessive-compulsive disorder: a single-blind, placebo-controlled study. 2002;17: 3:115–9.

4 Denys, D., de Geus, F., van Megen, H. J., and Westenberg, H. G. A double-blind, randomized, placebo-controlled trial of quetiapine addition in patients with obsessive-compulsive disorder refractory to serotonin reuptake inhibitors. 2004;65: 8:1040–8.

5 Cavedini, P., Bassi, T., Zorzi, C., and Bellodi, L. The advantages of choosing antiobsessive therapy according to decision-making functioning. 2004;24: 6:628–31.

6 McDougle, C. J., Epperson, C. N., Pelton, G. H., Wasylink, S., and Price, L. H. A double-blind, placebo-controlled study of risperidone addition in serotonin reuptake inhibitor-refractory obsessive-compulsive disorder. 2000;57: 8:794–801.

7 Shapira, N. A., Ward, H. E., Mandoki, M., Murphy, T. K., Yang, M. C., Blier, P., and Goodman, W. K. A double-blind, placebo-controlled trial of olanzapine addition in fluoxetine-refractory obsessive-compulsive disorder. 2004;55: 5:553–5.

8 Dunner, D., Amsterdam, J., Shelton, R., Hassman, H., Rosenthal, M., and Romano, S. Adjunctive ziprasidone in treatment-resistant depression: a pilot study {Abstract NR238]. 156th APA Annual Meeting. 2003.

9 Carey, P. D., Vythilingum, B., Seedat, S., Muller, J. E., van Ameringen, M., and Stein, D. J. Quetiapine augmentation of SRIs in treatment refractory obsessive-compulsive disorder: a double-blind, randomised, placebo-controlled study. 2005;5: 1:5.

10 Fineberg, N. A., Sivakumaran, T., Roberts, A., and Gale, T. Adding quetiapine to SRI in treatment-resistant obsessive-compulsive disorder: a randomized controlled treatment study. 2005;20: 4:223–6.

11 Li, X., May, R. S., Tolbert, L. C., Jackson, W. T., Flournoy, J. M., and Baxter, L. R. Risperidone and haloperidol augmentation of serotonin reuptake inhibitors in refractory obsessive-compulsive disorder: a crossover study. 2005;66: 6:736–43.

C5_ Evidence Tables

Head to Head Trials

Study | Randomization adequate? | Allocation concealment adequate? | Groups similar at baseline? | Eligibility criteria specified? | Outcome assessors masked? | Care provider masked? | Patient masked? | Attrition, crossovers, adherence, contamination | Loss to follow-up: differential/high | Intention-to-treat analysis | Post- randomization exclusions | Quality rating (Jadad score) | Number screened/Eligible/Enrolled | Exclusion criteria | Run-in/Randomization Method Washout/Randomization Method | Class naïve patients only | Control group standard of care | Funding | Relevance
(Fontaine CS et al., 2003)^1^ | Method NR | Method NR | Yes | Yes | NR | Yes, but not described | Yes, but not described | Yes/NR/NR/NR | No | Yes | No | 3 | NR/47/39 | Neuroleptic malignant syndrome, Atypical antipsychotics sensitivity, Major depressive disorder, Schizophrenia, Bipolar disorder, Antihypertensive drug treatment, Antibiotic treatment, Antiparkinsonian drug treatment | NR Washout period reported | No | Yes | Source: Industry Role: described | Yes
(Herz LR et al., 2002)^2^ | Yes | Yes | NR | Yes | NR | Yes, but not described | Yes, but not described | Yes/NR/NR/NR | No | Yes | No | 3 | NR/29/29 | NR | NR NR | NR | No - Placebo | Source: NR Role: NR | Yes
(Mullen J et al., 2001)^3^ | Method NR | Method NR | Yes | Yes | No | No | No | Yes/NR/NR/NR | No | No | No | 1 | NR/728/728 | Under 18 years old, Medically significant disorders, Clozapine treatment, Clozapine unresponsiveness, Previous drug-induced agranulocytosis, Pregnant, Lactating, Participation in previous quetiapine trial, Participation in previous clinical trial within 4 months, Risperidone treatment within 4 months | NR NR | No | Yes | Source: Industry Role: NR | Yes
(Deberdt WG et al., 2005)^4^ | Method NR | Method NR | Yes | Yes | NR | Yes, but not described | Yes, but not described | Yes/NR/NR/NR | NR | Yes | No | 2 | NR/494/494 | Frontotemporal dementia, Lewy body dementia, MMSE > 24, Parkinsons disease, Picks disease | NR Washout period reported | NR | Yes | Source: Industry Role: NR | Yes
(Levitt A et al., 2004)^5^ | Method NR | Method NR | Yes | Yes | Yes, but not described | Yes, but not described | Yes, but not described | NR/NR/NR/NR | NR | Yes | No | 3 | NR/43/43 | Suicidal, current Axis 1 DSM IV diagnosis other than anxiety disorder, substance abuse in past 3 months, pregnant, lactating or certain other medications | NR NR | NR | Yes | Source: Industry Role: NR | Yes
(Mulsant BH et al., 2004)^6^ | Method NR | Method NR | Yes | Yes | NR | Yes, but not described | Yes, but not described | Yes/NR/NR/NR | NR | Yes | No | 2 | NR/86/86 | Psychosis before dementia onset, Delirium, Inability to swallow oral medication or unable to cooperate with study | Run-in period reported Washout period reported | NR | Yes | Source: Industry Role: described | Yes
(Tollefson GD et al., 1999)^7^ | Method NR | Method NR | Yes | Yes | Yes, but not described | Yes, but not described | Yes, but not described | Yes/NR/Yes/NR | No | No | No | 2 | NR/339/339 | NR | NR NR | NR | Yes | Source: Industry Role: NR | Yes
(Kinon BJ et al., 2005)^8^ | Method NR | Method NR | Yes | Yes | NR | Yes, but not described | Yes, but not described | Yes/NR/NR/NR | NR | No | No | 2 | NR/394/NR | Previous sensitivity or unresponsiveness to stuffy drug | NR NR | NR | Yes | Source: Industry Role: NR | Yes
(Simpson GM et al., 2004)^9^ | Method NR | Method NR | Yes | Yes | NR | Yes | Yes | Yes/NR/NR/NR | NR | Yes | No | 4 | 367/269/269 | Pregnant, Hospitalized ≥ 2 wks, Abnormal laboratory results, DSM-IV Axis I disorder, not including primary condition studied, Depot neuroleptic within 1 treatment cycle, Resistant to antipsychotic treatment, Suicidal or violent, Olanzapine > 14 days life time exposure or olanzapine daily dose >10 m | NR Washout period reported | NR | Yes | Source: Industry Role: NR | Yes

Acronyms in Evidence Table: CCT Clinical control trial; kg kilograms; lbs pounds; ND Not described; NOS Not otherwise specified; NR Not reported; RCT Randomized control trial; RR Risk ratio; SMD Standard mean difference; WMD Weighted mean difference

Outcomes: ABC, Aberrant Behavior Checklist; ACES, Agitation-Calmness Evaluation Scale; ADAS-cog, Alzheimer’s Disease Assessment Scale; ADHDRS, DuPaul Attention Deficit Hyperactivity Scale; ADL, Activities of Daily Life; AIAQ, Anger, Irritability, and Assault Questionnaire; ASI, Addiction Severity Index; BABS, Brown Assessment of Beliefs Scale; BAI, Beck Anxiety Index; BDHI, Buss-Durkee Hostility Index; BDI, Beck Depression Index; BDS, Blessed Dementia Scale; BEHAVE-AD, Behavioral Pathology in Alzheimer’s Disease Rating Scale; BPRS, Brief Psychiatric Rating Scale; BRMES, Bech-Rafaelsen Melancholia Scale; CAPS, Clinician Administered PTSD Scale; CDSS, Calgary Depression Scale for Schizophrenia; CES-D, Center for Epidemiologic Studies Depression Scale; CGI, Clinical Global Impression Scale; CMAI, Cohen-Mansfield Agitation Inventory; CM-PNB, Cohen-Mansfield Physically Non-Aggressive Behavior; CPRS, Children’s Psychiatric Rating Scale; CSDD, Cornell Scale for Depression in Dementia; CY-BOCS, Children’s Yale-Brown Obsessive-Compulsive Scale; DCM, Dementia Care Mapping; DES, Dissociative Experiences Scale; DTS, Davidson Trauma Scale; E-BEHAVE-AD, Empirical Behavioral Pathology in Alzheimer’s Disease Rating Scale; FAST, Functional Assessment Staging Rating Scale; GAF, Global Assessment of Functioning Scale; HAM-A, Hamilton Rating Scale for Anxiety; HAM-D/HDRS, Hamilton Rating Scale for Depression; IGT, Iowa Gambling Task; MADRS, Montgomery-Asberg Depression Rating Scale; MDRS, Mattis Dementia Rating Scale; MMSE, Mini-Mental State Examination; M-NCAS, Modified Strain in Nursing Care Assessment; MOSES, Multidimentional Observational Scale for Elderly Subjects; MOVES, Motor Tic, Obsessions, and Compulsions, Vocal Tic Evaluation Survey; N-CBRF, Nisonger Child Behavior Rating Scale; NIMH-OC, National Institute of Mental Health Obsessive-Compulsive Scale; NPI, Neuropsychiatric Inventory; NPI/NH, Neuropsychiatric Inventory/Nursing Home; NPI-Q, Neuropsychiatric Inventory Questionnaire; OAS-M, Overt Aggression Scale-Modified; PANSS, Positive and Negative Symptom Scale; PCL-M, Patient Checklist for PTSD--Military Version; PDC, Depression cluster; PDS, Progressive Deterioration Scale; PGDRS, Psychogeriatric Dependency Rating Scale; PGI, Patient Global Impressions; QLDS, Quality of Life in Depression Scale; Q-LES-Q, Quality of Life Enjoyment and Satisfaction Questionnaire; QLS, Quality of Life Scales; QUALID, Quality of Life in Late-Stage Dementia Scale; ROAS, Retrospective Overt Aggression Scale; SANS, Scale for the Assessment of Negative Symptoms; SCL-90, Symptom Checklist-90; SDS, Sheehan Disability Scale; SF-36, Medical Outcomes Study 36-Item Short-Form Health Survey; SIB, Severe Impairment Battery; SIB-Q, Self-injurious Behavior Questionnaire; SIP, Structured Interview for PTSD; SPQ, Schizotypal Personality Questionnaire; SPRINT, Short PTSD Rating Interview; STAS-AX, State-Trait Anger Expression Inventory; STAT-S, Spielberger State-Trait Anger Scale, state version; STAT-T, Spielberger State-Trait Anger Scale, trait version; TOP-8, Treatment Outcome PTSD Scale; TSSS, Tourette’s Syndrome Severity Scale; VAS, Visual Analog Scale; Y-BOCS, Yale-Brown Obsessive-Compulsive Scale; YGTSS, Yale Global Tic Severity Scale; YMRS, Young Mania Rating Scale

1 Fontaine, C. S., Hynan, L. S., Koch, K., Martin-Cook, K., Svetlik, D., and Weiner, M. F. A double-blind comparison of olanzapine versus risperidone in the acute treatment of dementia-related behavioral disturbances in extended care facilities. 2003;64:6:726–30.

2 Herz, L. R., Volier, L., Frankenburg, F., Colon, S., and Kittur, S. A 6-week, double-blind comparison of olanzapine, risperidone, and placebo for behavioral disturbances in Alzheimer’s disease (abstract). 2002:63:1065.

3 Mullen, J., Jibson, M. D., and Sweitzer, D. A comparison of the relative safety, efficacy, and tolerability of quetiapine and risperidone in outpatients with schizophrenia and other psychotic disorders: the quetiapine experience with safety and tolerability (QUEST) study. 2001;23:11:1839–54.

4 Deberdt, W. G., Dysken, M. W., Rappaport, S. A., Feldman, P. D., Young, C. A., Hay, D. P., Lehman, D. L., Dossenbach, M., Degenhardt, E. K., and Breier, A. Comparison of olanzapine and risperidone in the treatment of psychosis and associated behavioral disturbances in patients with dementia. 2005;13:8:722–30.

5 Levitt, A., Lam, R., Chaput, Y., and et al. Risperidone vs. olanzapine as add-on treatment in treatment resistant depression: a randomized double blind comparison [poster]. 24th Congress of the Collegium Internationale Neuro-Psychopharmacologicum. 2004.

6 Mulsant, B. H., Gharabawi, G. M., Bossie, C. A., and et al. Correlates of anticholinergic activity in patients with demntia and psychosis treated with risperidone or olanzapine. 2004;65:1708–14.

7 Tollefson, G. D., Andersen, S. W., and Tran, P. V. The course of depressive symptoms in predicting relapse in schizophrenia: a double-blind, randomized comparison of olanzapine and risperidone. 99;46:3:365–73.

8 Kinon, B. J., Lipkovich, I., and Edwards, S. B. Improvement of comorbid depression with olanzapine versus ziprasidone treatment in patients with schizophrenia or schizoaffective disorder. International Congress on Schizophrenia Research (ICOSR). 2005.

9 Simpson, G. M., Glick, I. D., Weiden, P. J., Romano, S. J., and Siu, C. O. Randomized, controlled, double-blind multicenter comparison of the efficacy and tolerability of ziprasidone and olanzapine in acutely ill inpatients with schizophrenia or schizoaffective disorder. 2004;161:10:1837–47.

C6_ Evidence Tables

Active Control Trials

Author, Year | Randomization adequate? | Allocation concealment adequate? | Groups similar at baseline? | Eligibility criteria specified? | Outcome assessors masked? | Care provider masked? | Patient masked? | Attrition, crossovers, adherence, contamination | Loss to follow-up: differential/high | Intention-to-treat analysis | Post-randomization exclusions | Quality rating (Jadad score) | Number screened/Eligible/Enrolled | Exclusion criteria | Run-in/Randomization Method Washout/Randomization Method | Class naïve patients only | Control group standard of care | Funding | Relevance
(Malone RP et al., 2001)^1^ | Yes | Method NR | Yes | Yes | No | No | No | Yes/NR/NR/NR | No | Yes | No | 3 | NR/13/12 | Medically significant disorders, Seizure disorder or epilepsy or risk, Neurological disorder, Psychotropic medications, Previous exposure to study drug | NR NR | NR | Yes | Source: Industry Role: described | Yes
(Meehan KM et al., 2002)^2^ | Method NR | Method NR | Yes | Yes | NR | Yes, but not described | Yes, but not described | Yes/NR/NR/NR | NR | No | No | 2 | 331/272/272 | Anticholinergic medications, Antipsychotic medications, Benzodiazepines, Neurological conditions, excluding Alzheimers or vascular dementia, contributing to psychosis or dementia, Abnormal laboratory results, Suicidal or violent | NR NR | NR | No - Placebo | Source: Industry Role: NR | Yes
(Ballard C et al., 2005)^3^ | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes/NR/NR/NR | No | Yes | No | 4 | 282/93/93 | Antipsychotics treatment≥4 wks, Cholinesterase treatment≥4 wks, Previous sensitivity or unresponsiveness to stuffy drug, Severe internal or neurological disease, Medically significant disorders | NR NR | NR | No - Placebo | Source: Industry & Private Role: described | Yes
(Chan WC et al., 2001)^4^ | Method NR | Method NR | Yes | Yes | NR | Yes, but not described | Yes, but not described | Yes/NR/NR/NR | NR | Yes | No | 3 | NR/58/58 | Lewy body dementia, Neurological or medical conditions diminishing cognitive function, Psychosis/psychotic features, Medically significant disorders, Abnormal laboratory results, Allergic or toxic reactions to psychotropic medications, Neuroleptic malignant syndrome | NR Washout period reported | No | Yes | Source: Industry Role: NR | Yes
(De Deyn PP et al., 1999)^5^ | Yes | Yes | Yes | Yes | NR | Yes, but not described | Yes, but not described | Yes/NR/NR/NR | No | No | No | 4 | 371/344/344 | Neurological or medical conditions diminishing cognitive function, Other psychiatric disorders, Severe internal or neurological disease, Abnormal laboratory results, Depot neuroleptic within 1 treatment cycle, Allergic or toxic reactions to psychotropic medication, Participation in a clinical trial with investigational drugs during the 4 weeks preceding this trial, Other psychotropics, psychotropic herbs, history of non-affective disorder. | NR Washout period reported | No | Yes | Source: Industry Role: NR | Yes
(Suh GH et al., 2004)^6^ | Method NR | Yes | Yes | Yes | NR | Yes | Yes | Yes/NR/NR/NR | No | Yes | No | 4 | 280/120/120 | Neurological or medical conditions diminishing cognitive function, Psychotic disorder, Severe internal or neurological disease, Medically significant disorders, Abnormal laboratory results, Allergic or toxic reactions to antipsychotic medications, Neuroleptic malignant syndrome | NR Washout period reported | NR | Yes | Source: Industry Role: described | Yes
(David S JBAKWP, 2002)^7^ | Method NR | Method NR | NR | NR | NR | No | No | NR/NR/NR/NR | NR | No | Unable to determine | 2 | NR/1054/NR | NR | NR NR | NR | No - Placebo | Source: NR Role: NR | Yes
(McEvoy J et al.,)^8^ | Method NR | Method NR | Yes | Yes | NR | Yes, but not described | Yes, but not described | Yes/NR/NR/NR | No | Yes | No | 2 | NR/263/263 | Pregnant, Clozapine treatment, Antipsychotic treatment > 16 wks in a lifetime, Lactating, Medically significant disorders, Previous sensitivity or unresponsiveness to stuffy drug, Alcohol or substance abuse or dependency, Suicidal or violent | NR Washout period reported | No | Yes | Source: Industry Role: NR | Yes
(Shelton RC et al., 2001)^9^ | Method NR | Method NR | NR | Yes | Yes, but not described | Yes, but not described | Yes, but not described | Yes/NR/NR/NR | No | Yes | No | 2 | 34/33/28 | Psychosis/psychotic features, Dysthymic disorder, Bipolar disorder | NR NR | NR | No - Fluoxetine (for nonresponders) | Source: Government & Industry Role: NR | Yes
(Street JS et al., 2000)^10^ | Not randomized | Not randomized | NR | Yes | NR | NR | NR | NR/NR/NR/NR | NR | No | Unable to determine | 1 | NR/NR/NR | NR | NR NR | NR | NR | Source: Industry Role: NR | Yes
(Svestka J SO, 2000)^11^ | Method NR | Method NR | NR | Yes | NR | Yes, but not described | Yes, but not described | NR/NR/NR/NR | No | Yes | No | 3 | NR/40/40 | NR | Run-in period reported NR | NR | No - Amitriptyline | Source: NR Role: NR | Yes
(Tohen M et al., 1999)^12^ | Method NR | Method NR | NR | Yes | NR | Yes, but not described | Yes, but not described | Yes/NR/NR/NR | NR | No | No | 2 | NR/28/NR | NR | Run-in period reported NR | NR | NR | Source: NR Role: NR | Yes
(Tohen M et al., 2002)^13^ | Method NR | Method NR | Yes | Yes | Yes | Yes | Yes | Yes/NR/NR/NR | No | Yes | No | 3 | 330/251/251 | Medically significant disorders, Alcohol or substance abuse or dependency, Atypical antipsychotics sensitivity, Sensitivity to mood stabilizer, Treatment with lithium, anticonvulsant, or antipsychotic within 24 hrs | NR NR | NR | Yes | Source: Industry Role: NR | Yes
(Tohen M et al., 2005)^14^ | Method NR | Method NR | Yes | Yes | Yes | Yes | Yes | Yes/NR/Yes/NR | No | Yes | No | 4 | 543/431/431 | Medically significant disorders, Alcohol or substance abuse or dependency, Depot neuroleptic within 6 weeks, Suicidal or violent, Previous sensitivity or unresponsiveness to stuffy drug | NR Washout period reported | No | Yes | Source: Industry Role: NR | Yes
(Tollefson GD et al., 1997)^15^ | Yes | Method NR | Yes | Yes | NR | Yes, but not described | Yes, but not described | Yes/NR/NR/NR | No | Yes | No | 5 | 2223/1996/1996 | NR | NR Washout period reported | No | Yes | Source: Industry Role: NR | Yes
(Gareri P et al., 2004)^16^ | Method NR | Method NR | NR | Yes | Yes | Yes, but not described | Yes, but not described | Yes/NR/NR/NR | No | Yes | No | 3 | NR/60/60 | NR | NR Washout period reported | NR | Yes | Source: Government Role: NR | Yes
(Altamura AC et al., 2003)^17^ | Method NR | Method NR | Yes | Yes | Yes | No | No | NR/NR/NR/NR | No | Yes | No | 2 | NR/28/28 | Abnormal laboratory results, HIV dementia | NR NR | NR | Yes | Source: NR Role: NR | Yes
(Muller-Siecheneder F et al., 1998)^18^ | Method NR | Method NR | Yes | Yes | Yes, but not described | Yes, but not described | Yes, but not described | Yes/NR/NR/NR | No | Yes | No | 4 | NR/123/123 | Suicidal or violent, Severe internal or neurological disease, Abnormal laboratory results, Allergic or toxic reactions to psychotropic medications, Participation in previous clinical trial within 4 months, Pregnant, Lactating | NR Washout period reported | No | Yes | Source: Industry Role: NR | Yes
(Shelton RC et al., 2004)^19^ | Method NR | Method NR | Yes | Yes | NR | Yes | Yes | Yes/NR/NR/NR | No | Yes | No | 4 | NR/30/30 | Current psychosis, Alcohol or substance abuse or dependency, Other psychotropics, psychotropic herbs, history of non-affective disorder | NR NR | NR | Yes | Source: Government & Industry Role: described | Yes
(Weiser M et al., 2002)^20^ | Method NR | Method NR | Yes | Yes | No | No | No | Yes/NR/NR/NR | NR | Yes | No | 1 | NR/90/85 | NR | NR NR | NR | Yes | Source: Industry Role: NR | Yes
(Zanarini MC et al., 2004)^21^ | Method NR | Method NR | Yes | Yes | Yes, but not described | NR | Yes, but not described | Yes/NR/NR/NR | No | Yes | No | 2 | NR/45/45 | Fluoxetine successful treatment, Olanzapine successful treatment, Medically significant disorders, Seizure disorder or epilepsy or risk, Psychotropic medications, Alcohol or substance abuse or dependency, Suicidal or violent, Major depressive disorder | NR NR | NR | NR | Source: Industry Role: NR | Yes
(Bruggeman R et al., 2001)^22^ | Yes | Yes | Yes | Yes | NR | Yes | Yes | Yes/NR/NR/NR | No | Yes | Yes | 5 | NR/51/51 | NR | NR Washout period reported | NR | Yes | Source: Industry Role: described | Yes
(Gaffney GR et al., 2002)^23^ | Method NR | Method NR | Yes | Yes | NR | Yes, but not described | Yes, but not described | Yes/NR/NR/NR | No | Yes | No | 3 | 24/21/21 | Seizure disorder or epilepsy or risk, Neurological disorder, Pregnant, Abnormal laboratory results | Run-in period reported Washout period reported | NR | Yes | Source: Industry & Private Role: NR | Yes
(Kinon BJ et al., 2005)^24^ | Method NR | Method NR | Yes | Yes | Yes, but not described | No | No | Yes/NR/Yes/NR | No | Yes | No | 2 | NR/293/293 | Tardive dyskinesia | Run-in period reported NR | No | Yes | Source: Industry Role: NR | Yes
(Kasper S et al., 2003)^25^ | Method NR | Method NR | Yes | Yes | NR | Yes, but not described | Yes, but not described | Yes/NR/Yes/NR | NR | Yes | No | 2 | NR/1294/1294 | Pregnant, Lactating, Resistant to antipsychotic treatment, Suicidal or violent, Alcohol or substance abuse or dependency, Neurological disorder, Investigational drug use ≥4 wks, Psychiatric disorder, not including primary conditioned studied | NR Washout period reported | No | Yes | Source: Industry Role: NR | Yes
(Corya SA et al., 2005)^26^ | Method NR | Method NR | NR | Yes | NR | Yes | Yes | Yes/NR/Yes/NR | No | Yes | No | 3 | 807/483/483 | Bipolar disorder, Psychotic disorder, Schizophrenia, Schizoaffective disorder, PTSD, Major depressive disorder with seasonal pattern, Dissociative disorder | Run-in period reported NR | No | Yes | Source: Industry Role: NR | Yes
(Dunner DL et al., 2005)^27^ | Method NR | Method NR | Yes | Yes | NR | Yes, but not described | Yes, but not described | Yes/NR/NR/NR | Yes | Yes | No | 2 | NR/410/410 | Suicidal or violent, Alcohol or substance abuse or dependency, Previous exposure to study drug, Previous failure or responded poorly to olanzapine, antidepressants or lamotrigine, Olanzapine + antidepressants treatment, Lamotrigine treatment, YMRS ≥15 | NR NR | NR | Yes | Source: Industry Role: NR | Yes
(Shelton RC et al., 2005)^28^ | Method NR | Method NR | Yes | Yes | NR | Yes | Yes | Yes/NR/Yes/NR | No | Yes | No | 3 | 946/500/500 | BPRS positive item score ≥3, Pregnant, Lactating, ECT treatment history or requiring during study | Run-in period reported Washout period reported | No | Yes | Source: Industry Role: described | Yes
(Gilbert DL et al., 2004)^29^ | Yes | Yes | NR | Yes | NR | Yes, but not described | Yes, but not described | Yes/Yes/NR/NR | No | Yes | No | 5 | NR/19/19 | Psychotic disorder, Alcohol or substance abuse or dependency, Pervasive developmental disorder, Eating disorders, Transient tic disorder, Medically significant disorders, Abnormal laboratory results, Sexually active females of child bearing age not using an effective contraceptive method | Run-in period reported Washout period reported | No | Yes | Source: Government & Industry Role: NR | Yes

Acronyms in Evidence Table: CCT, Clinical control trial; kg, kilograms; lbs, pounds; ND, Not described; NOS, Not otherwise specified; NR, Not reported; RCT, Randomized control trial; RR, Risk ratio; SMD, Standard mean difference; WMD, Weighted mean difference

Outcomes: ABC, Aberrant Behavior Checklist; ACES, Agitation-Calmness Evaluation Scale; ADAS-cog, Alzheimer’s Disease Assessment Scale; ADHDRS, DuPaul Attention Deficit Hyperactivity Scale; ADL, Activities of Daily Life; AIAQ, Anger, Irritability, and Assault Questionnaire; ASI, Addiction Severity Index; BABS, Brown Assessment of Beliefs Scale; BAI, Beck Anxiety Index; BDHI, Buss-Durkee Hostility Index; BDI, Beck Depression Index; BDS, Blessed Dementia Scale; BEHAVE-AD, Behavioral Pathology in Alzheimer’s Disease Rating Scale; BPRS, Brief Psychiatric Rating Scale; BRMES, Bech-Rafaelsen Melancholia Scale; CAPS, Clinician Administered PTSD Scale; CDSS, Calgary Depression Scale for Schizophrenia; CES-D, Center for Epidemiologic Studies Depression Scale; CGI, Clinical Global Impression Scale; CMAI, Cohen-Mansfield Agitation Inventory; CM-PNB, Cohen-Mansfield Physically Non-Aggressive Behavior; CPRS, Children’s Psychiatric Rating Scale; CSDD, Cornell Scale for Depression in Dementia; CY-BOCS, Children’s Yale-Brown Obsessive-Compulsive Scale; DCM, Dementia Care Mapping; DES, Dissociative Experiences Scale; DTS, Davidson Trauma Scale; E-BEHAVE-AD, Empirical Behavioral Pathology in Alzheimer’s Disease Rating Scale; FAST, Functional Assessment Staging Rating Scale; GAF, Global Assessment of Functioning Scale; HAM-A, Hamilton Rating Scale for Anxiety; HAM-D/HDRS, Hamilton Rating Scale for Depression; IGT, Iowa Gambling Task; MADRS, Montgomery-Asberg Depression Rating Scale; MDRS, Mattis Dementia Rating Scale; MMSE, Mini-Mental State Examination; M-NCAS, Modified Strain in Nursing Care Assessment; MOSES, Multidimentional Observational Scale for Elderly Subjects; MOVES, Motor Tic, Obsessions, and Compulsions, Vocal Tic Evaluation Survey; N-CBRF, Nisonger Child Behavior Rating Scale; NIMH-OC, National Institute of Mental Health Obsessive-Compulsive Scale; NPI, Neuropsychiatric Inventory; NPI/NH, Neuropsychiatric Inventory/Nursing Home; NPI-Q, Neuropsychiatric Inventory Questionnaire; OAS-M, Overt Aggression Scale-Modified; PANSS, Positive and Negative Symptom Scale; PCL-M, Patient Checklist for PTSD--Military Version; PDC, Depression cluster; PDS, Progressive Deterioration Scale; PGDRS, Psychogeriatric Dependency Rating Scale; PGI, Patient Global Impressions; QLDS, Quality of Life in Depression Scale; Q-LES-Q, Quality of Life Enjoyment and Satisfaction Questionnaire; QLS, Quality of Life Scales; QUALID, Quality of Life in Late-Stage Dementia Scale; ROAS, Retrospective Overt Aggression Scale; SANS, Scale for the Assessment of Negative Symptoms; SCL-90, Symptom Checklist-90; SDS, Sheehan Disability Scale; SF-36, Medical Outcomes Study 36-Item Short-Form Health Survey; SIB, Severe Impairment Battery; SIB-Q, Self-injurious Behavior Questionnaire; SIP, Structured Interview for PTSD; SPQ, Schizotypal Personality Questionnaire; SPRINT, Short PTSD Rating Interview; STAS-AX, State-Trait Anger Expression Inventory; STAT-S, Spielberger State-Trait Anger Scale, state version; STAT-T, Spielberger State-Trait Anger Scale, trait version; TOP-8, Treatment Outcome PTSD Scale; TSSS, Tourette’s Syndrome Severity Scale; VAS, Visual Analog Scale; Y-BOCS, Yale-Brown Obsessive-Compulsive Scale; YGTSS, Yale Global Tic Severity Scale; YMRS, Young Mania Rating Scale

1 Malone, R. P., Cater, J., Sheikh, R. M., Choudhury, M. S., and Delaney, M. A. Olanzapine versus haloperidol in children with autistic disorder: an open pilot study. 2001;40: 8:887–94.

2 Meehan, K. M., Wang, H., David, S. R., Nisivoccia, J. R., Jones, B., Beasley, C. M. Jr, Feldman, P. D., Mintzer, J. E., Beckett, L. M., and Breier, A. Comparison of rapidly acting intramuscular olanzapine, lorazepam, and placebo: a double-blind, randomized study in acutely agitated patients with dementia. 2002;26: 4:494–504.

3 Ballard, C., Margallo-Lana, M., Juszczak, E., Douglas, S., Swann, A., Thomas, A., O’Brien, J., Everratt, A., Sadler, S., Maddison, C., Lee, L., Bannister, C., Elvish, R., and Jacoby, R. Quetiapine and rivastigmine and cognitive decline in Alzheimer’s disease: randomised double blind placebo controlled trial. 2005;330: 7496:874.

4 Chan, W. C., Lam, L. C., Choy, C. N., Leung, V. P., Li, S. W., and Chiu, H. F. A double-blind randomised comparison of risperidone and haloperidol in the treatment of behavioural and psychological symptoms in Chinese dementia patients. 2001;16: 12:1156–62.

5 De Deyn, P. P., Rabheru, K., Rasmussen, A., Bocksberger, J. P., Dautzenberg, P. L., Eriksson, S., and Lawlor, B. A. A randomized trial of risperidone, placebo, and haloperidol for behavioral symptoms of dementia. 99;53: 5:946–55.

6 Suh, G. H., Son, H. G., Ju, Y. S., Jcho, K. H., Yeon, B. K., Shin, Y. M., Kee, B. S., and Choi, S. K. A randomized, double-blind, crossover comparison of risperidone and haloperidol in Korean dementia patients with behavioral disturbances. 2004;12: 5:509–16.

7 David S, Jones B Alaka K Wright P. Intramuscular olanzapine demonstrates safety in acutely agitated patients with schizophrenia, bipolar mania, and dementia. 2002;5: Suppl 1:S83.

8 McEvoy, J., Lieberman, J., Green, A. I., Perkins, D., Hamer, R. M., Sharma, T., Zipursky, R., Kahn, R., Gur, R., Centorrino, F., Glick, I., Nemeroff, C., Rothchild, A., Strakowski, S., Tohen, M., Tollefson, G., and HGDH Study Group. Long-term efficacy and safety of atypical and conventional antipsychotic drugs in first episode schizophrenia: comparison of treatment with olanzapine and haloperidol.

9 Shelton, R. C., Tollefson, G. D., Tohen, M., Stahl, S., Gannon, K. S., Jacobs, T. G., Buras, W. R., Bymaster, F. P., Zhang, W., Spencer, K. A., Feldman, P. D., and Meltzer, H. Y. A novel augmentation strategy for treating resistant major depression. 2001;158: 1:131–4.

10 Street JS, Tollefson GD, Tohen M, and et al. Olanzapine for psychotic conditions in the elderly. 2000;30:191–196.

11 Svestka J, Synek O. Does olanzapine have antidepressant effect? A double-blind, amitriptyline-controlled study. 2000;3: Suppl 1:S251.

12 Tohen, M., Shelton, R., Tollefson, G. D., Stahl, S., Jacobs, T., and Gannon, K. S. Olanzapine plus fluoxetine: double-blind and open-label results in treatment-resistant major depressive disorder. 99;9: Suppl 5:S246.

13 Tohen, M., Baker, R. W., Altshuler, L. L., Zarate, C. A., Suppes, T., Ketter, T. A., Milton, D. R., Risser, R., Gilmore, J. A., Breier, A., and Tollefson, G. A. Olanzapine versus divalproex in the treatment of acute mania. 2002;159: 6:1011–7.

14 Tohen, M., Greil, W., Calabrese, J. R., Sachs, G. S., Yatham, L. N., Oerlinghausen, B. M., Koukopoulos, A., Cassano, G. B., Grunze, H., Licht, R. W., Dell’Osso, L., Evans, A. R., Risser, R., Baker, R. W., Crane, H., Dossenbach, M. R., and Bowden, C. L. Olanzapine versus lithium in the maintenance treatment of bipolar disorder: a 12-month, randomized, double-blind, controlled clinical trial. 2005;162: 7:1281–90.

15 Tollefson, G. D., Beasley, C. M. Jr., Tran, P. V., Street, J. S., and et al. Olanzapine versus haloperidol in the treatment of schizophrenia and schizoaffective and schizophreniform disorders: results of an international collaborative trial. 97;154: 4: 457–465.

16 Gareri, P., Cotroneo, A., Lacava, R., Seminara, G., Marigliano, N., Loiacono, A., and De Sarro, G. Comparison of the efficacy of new and conventional antipsychotic drugs in the treatment of behavioral and psychological symptoms of dementia (BPSD). 2004: 9:207–15.

17 Altamura, A. C., Salvadori, D., Madaro, D., Santini, A., and Mundo, E. Efficacy and tolerability of quetiapine in the treatment of bipolar disorder: preliminary evidence from a 12-month open-label study. 2003;76: 1–3:267–71.

18 Muller-Siecheneder, F., Muller, M. J., Hillert, A., Szegedi, A., Wetzel, H., and Benkert, O. Risperidone versus haloperidol and amitriptyline in the treatment of patients with a combined psychotic and depressive syndrome. 98;18: 2:111–20.

19 Shelton, R. C. and Stahl, S. M. Risperidone and paroxetine given singly and in combination for bipolar depression. 2004;65: 12:1715–9.

20 Weiser, M., Rotmensch, H. H., Korczyn, A. D., Hartman, R., Cicin-Sain, A., and Anand, R. A pilot, randomized, open-label trial assessing safety and pharmakokinetic parameters of co-administration of rivastigmine with risperidone in dementia patients with behavioral disturbances. 2002;17: 4:343–6.

21 Zanarini, M. C., Frankenburg, F. R., and Parachini, E. A. A preliminary, randomized trial of fluoxetine, olanzapine, and the olanzapine-fluoxetine combination in women with borderline personality disorder. 2004;65: 7:903–7.

22 Bruggeman, R., van der Linden, C., Buitelaar, J. K., Gericke, G. S., Hawkridge, S. M., and Temlett, J. A. Risperidone versus pimozide in Tourette’s disorder: a comparative double-blind parallel-group study. 2001;62: 1:50–6.

23 Gaffney, Gary R., Perry, Paul J., Lund, Brian C., Bever-Stille, Kristine A., Arndt, Stephan, and Kuperman, Samuel. Risperidone versus clonidine in the treatment of children and adolescents with tourette’s syndrome. 2002;41: 3: 330–336.

24 Kinon BJ, Stauffer VL, Kaiser CJ, Hay DP, and Kollack-Walker S. Incidence of presumptive tardive dyskinesia in elderly patients treated with olanzapine or conventional antipsychotics. International Congress of Parkinson’s Disease and Movement Disorders. 2005.

25 Kasper, S., Lerman, M. N., McQuade, R. D., Saha, A., Carson, W. H., Ali, M., Archibald, D., Ingenito, G., Marcus, R., and Pigott, T. Efficacy and safety of aripiprazole vs. haloperidol for long-term maintenance treatment following acute relapse of schizophrenia. 2003;6: 4:325–37.

26 Corya SA, Williamson D, Sanger TM, Briggs SD, Case M, and Tollefson G. A randomized, double-blind comparison of olanzapine/fluoxetine combination, olanzapine, fluoxetine and venlafaxine in treatment-resistant depression. 2005:1–9.

27 Dunner, D. L., Brown, E., Adams, D. H., Degenhardt, E., Tohen, M., and Houston, J. P. Olanzapine/fluoxetine combination versus lamotrigine in the long-term treatment of bipolar I depression. American College of Neuropsychopharmacology. 2005.

28 Shelton, R. C., Williamson, D. J., Corya, S. A., Sanger, T. M., Van Campen, L. E., Case, M., Briggs, S. D., and Tollefson, G. D. Olanzapine/fluoxetine combination for treatment-resistant depression: a controlled study of SSRI and nortriptyline resistance. 2005;66: 10:1289–97.

29 Gilbert, D. L., Batterson, J. R., Sethuraman, G., and Sallee, F. R. Tic reduction with risperidone versus pimozide in a randomized, double-blind, crossover trial. 2004;43: 2:206–14.

C7_ Evidence Tables

Placebo Control Trials

Author, Year | Randomization adequate? | Allocation concealment adequate? | Groups similar at baseline? | Eligibility criteria specified? | Outcome assessors masked? | Care provider masked? | Patient masked? | Attrition, crossovers, adherence, contamination | Loss to follow-up: differential/high | Intention-to- treat analysis | Post-randomization exclusions | Quality rating (Jadad score) | Number screened/Eligible/Enrolled | Exclusion criteria | Run-in/Randomization Method Washout/Randomization Method | Class naïve patients only | Control group standard of care | Funding | Relevance
(McCracken JT et al., 2002)^1^ | Yes | Yes | Yes, except on ABC in appropriate speech score | Yes | Yes | Yes | Yes, but not described | Yes/NR/Yes/NR | No | Yes | Yes | 4 | 270/104/104 | Medically significant disorders, DSM-IV Axis I disorder, not including primary condition studied, Psychotropic medication for behavioral disturbances | 2–4 week washout period for all psychotropics | NR | No - Placebo | Source: Government, Industry & Private Role: described | Yes
(Shea S et al., 2004)^2^ | Yes | Yes | Yes | Yes | No | No | No | Yes/NR/Yes/NR | No | Yes | Yes | 5 | NR/80/79 | Schizophrenia or other psychotic disorder, Risperidone use in last 3 mos, Previously unresponsive or intolerant to Risperidone, Medically significant disorders, Abnormal laboratory results, Seizure disorder, Allergic or toxic reactions to antipsychotic medications, HIV, Tardive dyskinesia, Neuroleptic malignant syndrome, Alcohol or substance abuse | NR NR | NR | No - Anticonvulsant, anti-EPS, anxiety, sleep medications only | Source: Industry Role: Described | Yes
(De Deyn PP et al., 2004)^3^ | Method NR | Method NR | Yes | Yes | NR | Yes, but not described | Yes, but not described | Yes/NR/Yes/NR | NR | No | No | 2 | NR/652/NR | DSM-IV Axis I disorder, not including primary condition studied | Run-in period reported NR | NR | No - Antidepressants, benzodiazepines, acetylcholinesterase inhibitors | Source: Industry Role: NR | Yes
(Street JS et al., 2000)^4^ | Yes | Method NR | Yes | Yes | NR | Yes | Yes | Yes/NR/NR/NR | No | Yes | No | 5 | 288/206/206 | DSM-IV Axis I disorder, not including primary condition studied, Neurological conditions, excluding Alzheimers or vascular dementia, contributing to psychosis or dementia, MMSE > 24, Bedridden, Anticholinergic medications, Mood stabilizers, Antipsychotics other than the ones studied, Tricyclic antidepressants | Run-in period reported NR | NR | No - Benzodiazepines prn only | Source: Government, Industry & Private Role: described | Yes
(Ruths S et al., 2004)^5^ | Method NR | Yes | NR | Yes | Yes | Yes | Yes | NR/NR/NR/NR | No | Yes | No | 4 | 51/30/30 | Psychotic disorder, Mental retardation, Terminal illness, Recent major changes in health status | Run-in period reported NR | No | No | Source: NR Role: NR | Yes
(Zhong X et al., 2004)^6^ | Method NR | Method NR | Yes | NR | NR | Yes, but not described | Yes, but not described | Yes/NR/NR/NR | NR | No | No | 2 | NR/333/NR | NR | NR NR | NR | No - Placebo | Source: NR Role: NR | Yes
(Ballard CG et al., 2004)^7^ | Method NR | Method NR | Yes | Yes | Yes | Yes | Yes | Yes/NR/NR/NR | No | No | No | 3 | NR/100/100 | NPI > 7 | NR NR | NR | No - Placebo | Source: Unclear Role: NR | Yes
(Brodaty H et al., 2003)^8^ | Yes | Method NR | Yes | Yes | NR | Yes, but not described | Yes, but not described | Yes/NR/NR/NR | No | Yes | No | 3 | 384/345/345 | Neurological or medical conditions diminishing cognitive function, Dementia other than primary condition, Major depressive disorder, Psychotic disorder, Tardive dyskinesia, Medically significant disorders, Abnormal laboratory results, Depot neuroleptic within 2 treatment cycles | NR Washout period reported | No | No - Anti-EPS, oxazepam, sedatives prn only | Source: Industry Role: described | Yes
(Katz IR et al., 1999)^9^ | Method NR | Yes | Yes | Yes | NR | Yes | Yes | Yes/NR/NR/NR | No | Yes | No | 4 | 729/625/625 | Untreated reversible causes of dementia, Neurological or medical conditions diminishing cognitive function, HIV dementia, Substance induced dementia, Delirium, Amnestic disorder, Psychosis/psychotic features | NR Washout period reported | NR | No - Anti-EPS, benzodiazepines, chloral hydrate prn only | Source: Industry Role: described | Yes
(Meguro K et al., 2004)^10^ | Method NR | Method NR | Yes | Yes | NR | NR | NR | NR/NR/NR/NR | NR | No | No | 1 | NR/34/34 | Cerebrovascular disease, Parkinsons disease | NR NR | NR | No | Source: Private Role: NR | Yes
(Mertens C, 1993)^11^ | Not randomized | Not randomized | Yes | Yes | NR | Yes | Yes | Yes/NR/NR/NR | No | Yes | No | 3 | NR/39/39 | Neurological or medical conditions diminishing cognitive function, Neurologic disorder, not including primary conditioned studied, Psychiatric disorder, not including primary conditioned studied | Run-in period reported NR | No | No - Placebo | Source: Industry Role: NR | Yes
(Corya S et al., 2002)^12^ | Method NR | Method NR | NR | NR | NR | Yes, but not described | Yes, but not described | NR/NR/NR/NR | NR | No | No | 2 | NR/249/NR | NR | NR NR | NR | No - Placebo | Source: Industry Role: NR | Yes
(Howanitz E et al., 2001)^13^ | Method NR | Method NR | NR | NR | NR | Yes, but not described | Yes, but not described | Yes/NR/NR/NR | No | Yes | No | 2 | NR/16/16 | NR | NR NR | NR | No - Placebo | Source: NR Role: NR | Yes
(Kinrys G et al., 2002)^14^ | Method NR | Method NR | NR | Yes | NR | Yes, but not described | Yes, but not described | Yes/NR/NR/NR | No | Yes | No | 3 | NR/14/14 | NR | Run-in period reported NR | NR | Yes | Source: Industry Role: NR | Yes
(Rothschild AJ et al., 2004)^15^ | Method NR | Method NR | Yes | Yes | NR | Yes, but not described | Yes, but not described | Yes/NR/Yes/NR | NR | Yes | No | 2 | NR/124/124 | Psychotic disorder, Pregnant, Lactating | NR NR | NR | No - Benzodiazepines prn only | Source: Industry Role: NR | Yes
(Shi L et al., 2004)^16^ | Method NR | Yes | Yes | Yes | Yes | Yes | Yes | Yes/NR/NR/NR | No | Yes | No | 3 | 1072/833/833 | Alcohol or substance abuse or dependency, Suicidal or violent, Medically significant disorders | NR Washout period reported | NR | No - Anti-EPS, benzodiazepines only | Source: Industry Role: NR | Yes
(Street JS et al., 2000)^17^ | Not randomized | Not randomized | NR | Yes | NR | NR | NR | NR/NR/NR/NR | NR | No | Unable to determine | 1 | NR/NR/NR | NR | NR NR | NR | NR | Source: Industry Role: NR | Yes
(Tohen M et al., 2003)^18^ | Method NR | Yes | Yes | Yes | Yes | Yes | Yes | Yes/NR/NR/NR | No | Yes | No | 4 | 1072/833/833 | Alcohol or substance abuse or dependency, Suicidal or violent, Medically significant disorders | NR Washout period reported | NR | No - Anti-EPS, benzodiazepines only | Source: Industry Role: described | Yes
(Tohen M et al., 2000)^19^ | Yes | Method NR | Yes | Yes | NR | Yes, but not described | Yes, but not described | Yes/NR/NR/NR | No | Yes | No | 4 | NR/115/115 | Medically significant disorders, Alcohol or substance abuse or dependency, Suicidal or violent | NR Washout period reported | No | No - Lorazepam, benztropine | Source: Industry Role: NR | Yes
(Tohen M et al., 1999)^20^ | Method NR | Method NR | Yes | Yes | NR | Yes, but not described | Yes, but not described | Yes/NR/NR/NR | NR | Yes | No | 3 | NR/139/139 | Medically significant disorders, Alcohol or substance abuse or dependency, Suicidal or violent | NR Washout period reported | NR | No - Lorazepam, benztropine | Source: Industry Role: NR | Yes
(Tohen M et al., 2003)^21^ | Method NR | Method NR | NR | Yes | NR | Yes, but not described | Yes, but not described | Yes/NR/NR/NR | NR | Yes | No | 2 | NR/361/361 | NR | NR NR | NR | No - Placebo | Source: Industry Role: NR | Yes
(Tollefson GD et al., 1999)^22^ | Method NR | Method NR | Yes | Yes | NR | Yes, but not described | Yes, but not described | Yes/NR/NR/NR | No | Yes | No | 3 | 115/106/106 | Alcohol or substance abuse or dependency, Suicidal or violent, Previous exposure to study drug, Medically significant disorders | NR NR | No | No - Anti-EPS, benzodiazepines prn | Source: Industry Role: NR | Yes
(van Reekum R et al., 2002)^23^ | Yes | Method NR | NR | Yes | NR | Yes | Yes | Yes/NR/NR/NR | No | Yes | No | 5 | NR/34/34 | Schizophrenia, Delirium, Resistant to antipsychotic treatment, Antipsychotic use for nausea, BEHAVE-AD ≥ 3 at screening, 1 week before study, or within 2 weeks pretrial period | Run-in period reported NR | No | NR | Source: Private (Non- Industry) Role: NR | Yes
(Calabrese J et al., 2004)^24^ | Method NR | Method NR | Yes | Yes | NR | Yes, but not described | Yes, but not described | NR/NR/NR/NR | NR | Yes | No | 2 | 832/542/542 | DSM-IV Axis I disorder, not including primary condition studied | NR NR | NR | No - Placebo | Source: Industry Role: NR | Yes
(Mintzer J et al., 2004)^25^ | Method NR | Method NR | Yes | Yes | NR | Yes, but not described | Yes, but not described | Yes/NR/NR/NR | NR | Yes | No | 2 | NR/473/473 | Medically significant disorders, Abnormal laboratory results, Epilepsy, Neurological or medical conditions diminishing cognitive function or that cause psychosis, Cancer, except for non-melanoma of the skin, Recent depot neuroleptic injections, Change in medications in preceding 30 dys | NR Washout period reported | No | No - Placebo | Source: Industry Role: NR | Yes
(Gharabawi GM et al., 2004)^26^ | Yes | Method NR | Yes | Yes | Yes, but not described | Yes, but not described | Yes, but not described | Yes/NR/Yes/NR | No | Yes | No | 4 | 489/241/241 | Pregnant, lactating, psychiatric history, DSM-IV diagnosis confounded by various things, including being medically unstable, testing positive on urine drug screen, impaired hepatic or renal function, history failure of citalopram or any antidepressant with risperidone augmentation, etc. | Run-in period reported NR | No | Yes | Source: Industry Role: NR | Yes
(Daniels DG et al., 1999)^27^ | Method NR | Method NR | Yes | Yes | NR | Yes, but not described | Yes, but not described | NR/NR/NR/NR | NR | Yes | No | 3 | 440/302/302 | Resistant to antipsychotic treatment, Hospitalized > 4 weeks, Alcohol or substance abuse or dependency, Mental retardation, Organic mental disorder, Brief reactive psychosis, Depot neuroleptic within 4 weeks, Suicidal or violent | NR Washout period reported | No | No - Lorazepam, benztropine, beta- blockers only | Source: Industry Role: NR | Yes
(Keck P Jr et al., 1998)^28^ | Method NR | Method NR | Yes | Yes | NR | Yes, but not described | Yes, but not described | Yes/NR/NR/NR | No | Yes | No | 2 | 203/139/139 | Nursing home/residential center resident, Resistant to antipsychotic treatment, Alcohol or substance abuse or dependency, Residual schizophrenia, Mental retardation, Organic mental disorder, Brief reactive psychosis, Suicidal or violent | NR Washout period reported | NR | No - Lorazepam, benztropine, beta- blockers only | Source: Industry Role: NR | Yes
(Bartzokis G et al., 2004) | Method NR | Method NR | Yes | Yes | NR | Yes, but not described | Yes, but not described | Yes/NR/Yes/NR | No | Yes | No | 3 | 73/65/65 | Alcohol or substance abuse or dependency, Suicidal or violent, Medically significant disorders, Neurological or medical conditions diminishing cognitive function, Antipsychotic medications, Seizure disorder or epilepsy or risk, Change in antidepressant regimen within 6 wk prior to study entry | NR NR | NR | Yes | Source: Government, Industry & Private Role: NR | Yes
(Padala PR et al., 2005)^29^ | Method NR | Method NR | NR | Yes | NR | Yes, but not described | Yes, but not described | Yes/NR/NR/NR | NR | Yes | No | 2 | NR/20/20 | Bipolar disorder, Schizophrenia, Medically significant disorders, Abnormal laboratory results, Suicidal or violent, Pregnancy, Nursing, Previous exposure to study drug, Psychotropic use, Alcohol or substance abuse or dependency, Antipsychotics other than the ones studied | NR Washout period reported | NR | No - Placebo | Source: Industry Role: NR | Yes
(Reich DB et al., 2004)^30^ | Method NR | Method NR | Yes | Yes | NR | Yes, but not described | Yes, but not described | Yes/NR/NR/NR | NR | Yes | No | 2 | NR/21/21 | Medically significant disorders, Alcohol or substance abuse or dependency, Psychotic disorder, Organic mental disorder, Antipsychotics other than the ones studied, Mood stabilizers, Risperidone treatment of 1 week or more, Suicidal or violent, Entry into individual psychotherapy within 3 mos of study, Entry into group therapy within 1 mo of study, | NR NR | NR | Yes | Source: Industry Role: NR | Yes
(Bystritsky A et al., 2004)^31^ | Method NR | Method NR | Yes | Yes | NR | Yes, but not described | Yes, but not described | Yes/NR/NR/NR | No | Yes | No | 3 | NR/26/26 | DSM-IV Axis I disorder, not including primary condition studied, DSM-IV Axis II disorder, not including primary condition studied, Neurological conditions, excluding Alzheimers or vascular dementia, contributing to psychosis or dementia, Pregnant, Medically significant disorders, HAM-D > 20, Bizarre psychosis | NR NR | NR | Yes | Source: Industry Role: NR | Yes
(Buchsbaum MS, 2003)^32^ | Not randomized | Not randomized | NR | Yes | NR | Yes, but not described | Yes, but not described | Yes/NR/NR/NR | NR | No | No | 1 | NR/16/16 | NR | NR NR | NR | NR | Source: NR Role: NR | Limited
(Erzegovesi S et al., 2005)^33^ | Yes | Yes | Yes | Yes | Yes, but not described | Yes, but not described | Yes, but not described | Yes/NR/NR/NR | NR | No | No | 4 | NR/45/45 | Antiobsessional medications, Psychiatric disorders except for panic disorder and tic disorders, Pregnant, Contraindication to risperidone, Lactating, Seizure disorder or epilepsy or risk, Medical conditions contraindicating use of fluvoxamine | Run-in period reported NR | NR | Yes | Source: NR Role: NR | Yes
(Hollander E et al., 2003)^34^ | Yes | Method NR | Yes | Yes | Yes | Yes | Yes | Yes/NR/NR/NR | No | Yes | No | 4 | NR/16/16 | Medically significant disorders, Schizophrenia and schizoafective disorder, Bipolar disorder | NR NR | NR | Yes | Source: Industry & Private Role: described | Yes
(Butterfield MI et al., 2001)^35^ | Method NR | Method NR | Yes | Yes | NR | Yes, but not described | Yes, but not described | Yes/NR/NR/NR | No | Yes | No | 3 | NR/15/15 | Bipolar disorder, Psychotic disorder, Mental retardation, Alcohol or substance abuse or dependency, Suicidal or violent | NR NR | NR | NR | Source: Industry Role: NR | Yes
(Stein MB et al., 2002)^36^ | Method NR | Method NR | Yes | Yes | NR | Yes, but not described | Yes, but not described | Yes/NR/NR/NR | No | Yes | No | 3 | NR/21/19 | NR | Run-in period reported NR | NR | No - SRI | Source: Industry Role: NR | Yes
(Hamner MB et al., 2003)^37^ | Yes | Method NR | Yes | Yes | NR | Yes | Yes | Yes/NR/NR/NR | No | Yes | No | 4 | NR/40/40 | Risperidone hypersensitivity, Medically significant disorders, Alcohol or substance abuse or dependency, Schizophrenia, Bipolar disorder, Suicidal or violent | Run-in period reported Washout period reported | No | Yes | Source: Industry Role: described | Yes
(Monnelly EP et al., 2003)^38^ | Yes | Method NR | Yes | Yes | NR | Yes, but not described | Yes, but not described | Yes/NR/NR/NR | No | Yes | No | 4 | NR/16/16 | Schizophrenia, Bipolar disorder with psychotic features, Organic mental disorder, Antipsychotic medications, Alcohol/substance dependency in remission | NR NR | Yes | Yes | Source: Government & Industry Role: NR | Yes
(Bogenschutz MP et al., 2004)^39^ | Method NR | Method NR | Yes | Yes | NR | Yes, but not described | Yes, but not described | Yes/NR/NR/NR | No | Yes | No | 3 | NR/40/40 | Psychotropic medications, Pregnant, Bipolar disorder, Psychotic disorder, Major depressive disorder, Alcohol or substance abuse or dependency, Suicidal or violent, Neurological disorder | NR NR | No | Yes | Source: Industry Role: NR | Yes
(Zanarini MC et al., 2001)^40^ | Yes | Method NR | Yes | Yes | NR | Yes | Yes | Yes/NR/NR/NR | Yes | Yes | No | 5 | 30/28/28 | Previous exposure to study drug, Medically significant disorders, Seizure disorder or epilepsy or risk, Psychotropic medications, Alcohol or substance abuse or dependency, Suicidal or violent, Pregnant, Lactating | NR NR | No | NR | Source: Industry Role: NR | Limited
(Koenigsberg HW et al., 2003)^41^ | Method NR | Method NR | Yes | Yes | Yes, but not described | Yes, but not described | Yes, but not described | Yes/NR/NR/NR | No | Yes | No | 4 | NR/25/25 | Alcohol or substance abuse or dependency, Use psychotropic medications within 2 wks | Run-in period reported NR | NR | No - No other psychotropic medications allowed | Source: Government & Industry Role: described | Yes
(Sallee FR et al., 2000)^42^ | Method NR | Method NR | Yes | Yes | NR | Yes, but not described | Yes, but not described | Yes/NR/NR/NR | No | Yes | No | 3 | 29/28/28 | Abnormal laboratory results, Neuroleptic malignant syndrome, Atypical antipsychotics sensitivity, Major depressive disorder, Pervasive developmental disorder, Autism, Mental retardation, Eating disorders | NR NR | NR | No - Placebo | Source: Industry Role: NR | Yes
(Breder C et al., 2004)^43^ | Method NR | Method NR | Yes | Yes | NR | No | No | Yes/NR/NR/NR | NR | Yes | No | 1 | NR/487/487 | NR | NR Washout period reported | NR | No - Placebo | Source: Industry Role: NR | Yes
(De Deyn P et al., 2005)^44^ | Method NR | Method NR | Yes | Yes | NR | Yes, but not described | Yes, but not described | Yes/NR/NR/NR | No | Yes | No | 3 | NR/208/208 | Bipolar disorder, Schizophrenia, Delirium, Amnestic disorder, Schizoaffective disorder, Mood disorders with psychotic features, Psychotic features accounted better by disease other than the one studied or by effects of a substance, Refractory to neuroleptics | NR Washout period reported | No | No - Placebo | Source: Industry Role: NR | Yes
(Streim JE et al., 2004)^45^ | Method NR | Method NR | Yes | Yes | NR | Yes, but not described | Yes, but not described | Yes/NR/NR/NR | NR | Yes | No | 2 | NR/256/256 | NR | NR NR | NR | No - Placebo | Source: Industry Role: NR | Yes
(McQuade R et al., 2004)^46^ | Method NR | Method NR | NR | Yes | NR | Yes, but not described | Yes, but not described | Yes/NR/NR/NR | NR | Yes | No | 2 | 567/161/161 | NR | Run-in period reported NR | No | No - Placebo | Source: Industry Role: NR | Yes
(Kennedy J et al., 2005)^47^ | Method NR | Method NR | Yes | Yes | NR | Yes, but not described | Yes, but not described | Yes/NR/Yes/NR | No | Yes | No | 3 | 446/268/268 | DSM-IV Axis I disorder, not including primary condition studied, Neurologic disorder, not including primary conditioned studied, NPI > 1 on delusions, hallucinations, agitation/aggression or dysphoria items, Score ≥ 1 on cholinesterase inhibitor use, antioxidant or herbal supplement items ≤ 4 week | NR Washout period reported | No | Yes | Source: Industry Role: NR | Yes
(Soler J et al., 2005)^48^ | Method NR | Method NR | Yes | Yes | Yes, but not described | Yes, but not described | Yes, but not described | Yes/NR/NR/NR | NR | Yes | No | 2 | 125/60/60 | DSM-IV Axis I disorder, not including primary condition studied, Psychotherapy, Sexually active females of child bearing age not using an effective contraceptive method | NR NR | NR | Yes | Source: Government & Industry Role: NR | Yes
(Scahill L et al., 2003)^49^ | Method NR | Method NR | NR | Yes | Yes | Yes | Yes | Yes/NR/NR/NR | No | Yes | No | 3 | 49/34/34 | Major depressive disorder, Psychosis/psychotic features, Anxiety disorder, Wechsler Intelligence Scale age approximate IQ < 70, Previous adequate trial of risperidone, Medically significant disorders, Y-BOCS or CY-BOCS > 15, Psychotropic medications | NR Washout period reported | No | No - Placebo | Source: Government, Industry & Private Role: NR | Yes

Acronyms in Evidence Table: CCT, Clinical control trial; kg, kilograms; lbs, pounds; ND, Not described; NOS, Not otherwise specified; NR, Not reported; RCT, Randomized control trial; RR, Risk ratio; SMD, Standard mean difference; WMD, Weighted mean difference

Outcomes: ABC, Aberrant Behavior Checklist; ACES, Agitation-Calmness Evaluation Scale; ADAS-cog, Alzheimer’s Disease Assessment Scale; ADHDRS, DuPaul Attention Deficit Hyperactivity Scale; ADL, Activities of Daily Life; AIAQ, Anger, Irritability, and Assault Questionnaire; ASI, Addiction Severity Index; BABS, Brown Assessment of Beliefs Scale; BAI, Beck Anxiety Index; BDHI, Buss-Durkee Hostility Index; BDI, Beck Depression Index; BDS, Blessed Dementia Scale; BEHAVE-AD, Behavioral Pathology in Alzheimer’s Disease Rating Scale; BPRS, Brief Psychiatric Rating Scale; BRMES, Bech-Rafaelsen Melancholia Scale; CAPS, Clinician Administered PTSD Scale; CDSS, Calgary Depression Scale for Schizophrenia; CES-D, Center for Epidemiologic Studies Depression Scale; CGI, Clinical Global Impression Scale; CMAI, Cohen-Mansfield Agitation Inventory; CM-PNB, Cohen-Mansfield Physically Non-Aggressive Behavior; CPRS, Children’s Psychiatric Rating Scale; CSDD, Cornell Scale for Depression in Dementia; CY-BOCS, Children’s Yale-Brown Obsessive-Compulsive Scale; DCM, Dementia Care Mapping; DES, Dissociative Experiences Scale; DTS, Davidson Trauma Scale; E-BEHAVE-AD, Empirical Behavioral Pathology in Alzheimer’s Disease Rating Scale; FAST, Functional Assessment Staging Rating Scale; GAF, Global Assessment of Functioning Scale; HAM-A, Hamilton Rating Scale for Anxiety; HAM-D/HDRS, Hamilton Rating Scale for Depression; IGT, Iowa Gambling Task; MADRS, Montgomery-Asberg Depression Rating Scale; MDRS, Mattis Dementia Rating Scale; MMSE, Mini-Mental State Examination; M-NCAS, Modified Strain in Nursing Care Assessment; MOSES, Multidimentional Observational Scale for Elderly Subjects; MOVES, Motor Tic, Obsessions, and Compulsions, Vocal Tic Evaluation Survey; N-CBRF, Nisonger Child Behavior Rating Scale; NIMH-OC, National Institute of Mental Health Obsessive-Compulsive Scale; NPI, Neuropsychiatric Inventory; NPI/NH, Neuropsychiatric Inventory/Nursing Home; NPI-Q, Neuropsychiatric Inventory Questionnaire; OAS-M, Overt Aggression Scale-Modified; PANSS, Positive and Negative Symptom Scale; PCL-M, Patient Checklist for PTSD--Military Version; PDC, Depression cluster; PDS, Progressive Deterioration Scale; PGDRS, Psychogeriatric Dependency Rating Scale; PGI, Patient Global Impressions; QLDS, Quality of Life in Depression Scale; Q-LES-Q, Quality of Life Enjoyment and Satisfaction Questionnaire; QLS, Quality of Life Scales; QUALID, Quality of Life in Late-Stage Dementia Scale; ROAS, Retrospective Overt Aggression Scale; SANS, Scale for the Assessment of Negative Symptoms; SCL-90, Symptom Checklist-90; SDS, Sheehan Disability Scale; SF-36, Medical Outcomes Study 36-Item Short-Form Health Survey; SIB, Severe Impairment Battery; SIB-Q, Self-injurious Behavior Questionnaire; SIP, Structured Interview for PTSD; SPQ, Schizotypal Personality Questionnaire; SPRINT, Short PTSD Rating Interview; STAS-AX, State-Trait Anger Expression Inventory; STAT-S, Spielberger State-Trait Anger Scale, state version; STAT-T, Spielberger State-Trait Anger Scale, trait version; TOP-8, Treatment Outcome PTSD Scale; TSSS, Tourette’s Syndrome Severity Scale; VAS, Visual Analog Scale; Y-BOCS, Yale-Brown Obsessive-Compulsive Scale; YGTSS, Yale Global Tic Severity Scale; YMRS, Young Mania Rating Scale

1 McCracken, J. T., McGough, J., Shah, B., Cronin, P., Hong, D., Aman, M. G., Arnold, L. E., Lindsay, R., Nash, P., Hollway, J., McDougle, C. J., Posey, D., Swiezy, N., Kohn, A., Scahill, L., Martin, A., Koenig, K., Volkmar, F., Carroll, D., Lancor, A., Tierney, E., Ghuman, J., Gonzalez, N. M., Grados, M., Vitiello, B., Ritz, L., Davies, M., Robinson, J., and McMahon, D. Risperidone in children with autism and serious behavioral problems. 2002;347: 5:314–21.

2 Shea, S., Turgay, A., Carroll, A., Schulz, M., Orlik, H., Smith, I., and Dunbar, F. Risperidone in the treatment of disruptive behavioral symptoms in children with autistic and other pervasive developmental disorders. 2004;114: 5:e634–41.

3 De Deyn, P. P., Carrasco, M. M., and Deberdt, W. et al. Olanzapine versus placebo in the treatment of psychosis with or without associated behavioral disturbances in patients with Alzheimer’s disease. 2004;19: 2:115–126.

4 Street, J. S., Clark, W. S., Gannon, K. S., Cummings, J. L., Bymaster, F. P., Tamura, R. N., Mitan, S. J., Kadam, D. L., Sanger, T. M., Feldman, P. D., Tollefson, G. D., and Breier, A. Olanzapine treatment of psychotic and behavioral symptoms in patients with Alzheimer disease in nursing care facilities: a double-blind, randomized, placebo-controlled trial. The HGEU Study Group. 2000;57: 10:968–76.

5 Ruths, S., Straand, J., Nygaard, H. A., Bjorvatn, B., and Pallesen, S. Effect of antipsychotic withdrawal on behavior and sleep/wake activity in nursing home residents with dementia: a randomized, placebo-controlled, double-blinded study. The Bergen District Nursing Home Study. 2004;52: 10:1737–43.

6 Zhong, X., Tariot, P., Minkwitz, M. C., Devine, N. A., and Mintzer, J. Quetiapine for the treatment of agitation in elderly institutionalized patients with dementia: a randomized, double-blind trial. 56th Institute in Psychiatric Services (IPS). 2004.

7 Ballard, C. G., Thomas, A., Fossey, J., Lee, L., Jacoby, R., Lana, M. M., Bannister, C., McShane, R., Swann, A., Juszczak, E., and O’Brien, J. T. A 3-month, randomized, placebo-controlled, neuroleptic discontinuation study in 100 people with dementia: the neuropsychiatric inventory median cutoff is a predictor of clinical outcome. 2004;65: 1:114–9.

8 Brodaty, H., Ames, D., Snowdon, J., Woodward, M., Kirwan, J., Clarnette, R., Lee, E., Lyons, B., and Grossman, F. A randomized placebo-controlled trial of risperidone for the treatment of aggression, agitation, and psychosis of dementia. 2003;64: 2:134–43.

9 Katz, I. R., Jeste, D. V., Mintzer, J. E., Clyde, C., Napolitano, J., and Brecher, M. Comparison of risperidone and placebo for psychosis and behavioral disturbances associated with dementia: a randomized, double-blind trial. Risperidone Study Group. 99;60: 2:107–15.

10 Meguro, K., Meguro, M., Tanaka, Y., Akanuma, K., Yamaguchi, K., and Itoh, M. Risperidone is effective for wandering and disturbed sleep/wake patterns in Alzheimer’s disease. 2004;17: 2:61–7.

11 Mertens, C. Risperidone in the treatment of behavioural disturbances in patients with Alzheimer’s dementia: a double-blind placebo-controlled trial. Beerse: Janssen Research Foundation; 93.

12 Corya, S., Dube, S., and Andersen, T. M. et al. Olanzapine-fluoxetine combination for psychotic major depression.Int. J. Neuropsychopharmacol. 2002;5: Suppl. 1:S144.

13 Howanitz, E. and Wisotzek, I. Olanzapine versus placebo in the treatment of behavioral disturbances associated with vascular dementia. 2001.

14 Kinrys, G., Nicolaou, C., Simon, N., Worthington, J., and Pollack, M. Adjunctive olanzapine for treatment refractory generalized anxiety disorder: an interim analysis. 2002;5: Suppl 1.

15 Rothschild, A. J., Williamson, D. J., Tohen, M. F., Schatzberg, A., Andersen, S. W., Van Campen, L. E., Sanger, T. M., and Tollefson, G. D. A double-blind, randomized study of olanzapine and olanzapine/fluoxetine combination for major depression with psychotic features. 2004;24: 4:365–73.

16 Shi, L., Namjoshi, M. A., Swindle, R., Yu, X., Risser, R., Baker, R. W., and Tohen, M. Effects of olanzapine alone and olanzapine/fluoxetine combination on health-related quality of life in patients with bipolar depression: secondary analyses of a double-blind, placebo-controlled, randomized clinical trial. 2004;26: 1:125–34.

17 Street, J. S., Kinon, F., and Stauffer, V. Olanzapine in dementia. In: Tran PV, ed. Olanzapine (Zyprexa): A Novel Antipsychotic. Philadelphia, PA: Lippincott Wiliams & Wilkins; 2000:416–426.

18 Tohen, M., Vieta, E., Calabrese, J., Ketter, T. A., Sachs, G., Bowden, C., Mitchell, P. B., Centorrino, F., Risser, R., Baker, R. W., Evans, A. R., Beymer, K., Dube, S., Tollefson, G. D., and Breier, A. Efficacy of olanzapine and olanzapine-fluoxetine combination in the treatment of bipolar I depression. 2003;60: 11:1079–88.

19 Tohen, M., Jacobs, T. G., Grundy, S. L., McElroy, S. L., Banov, M. C., Janicak, P. G., Sanger, T., Risser, R., Zhang, F., Toma, V., Francis, J., Tollefson, G. D., and Breier, A. Efficacy of olanzapine in acute bipolar mania: a double-blind, placebo-controlled study. The Olanzipine HGGW Study Group. 2000;57: 9:841–9.

20 Tohen, M., Sanger, T. M., McElroy, S. L., Tollefson, G. D., Chengappa, K. N., Daniel, D. G., Petty, F., Centorrino, F., Wang, R., Grundy, S. L., Greaney, M. G., Jacobs, T. G., David, S. R., and Toma, V. Olanzapine versus placebo in the treatment of acute mania. Olanzapine HGEH Study Group. 99;156: 5:702–9.

21 Tohen, M., Bowden, C., Calabrese, J., and et al. Olanzapine versus placebo for relapse prevention in bipolar disorder [poster]. Annual meeting of the American Psychiatric Association. 2003.

22 Tollefson, G. D., Dellva, M. A., Mattler, C. A., Kane, J. M., Wirshing, D. A., and Kinon, B. J. Controlled, double-blind investigation of the clozapine discontinuation symptoms with conversion to either olanzapine or placebo. The Collaborative Crossover Study Group. 99;19: 5:435–43.

23 van Reekum, R., Clarke, D., Conn, D., Herrmann, N., Eryavec, G., Cohen, T., and Ostrander, L. A randomized, placebo-controlled trial of the discontinuation of long-term antipsychotics in dementia. 2002;14: 2:197–210.

24 Calabrese, J., Macfadden, W., McCoy, R., Minkwitz, M., Wilson, E., and Mullen, J. Double-blind, placebo-controlled study of quetiapine in bipolar depression. 157th Annual Meeting of the American Pyschiatric Association. 2004.

25 Mintzer, J. and et al. Efficacy and safety of a flexible dose of risperidone versus placebo in the treatment of psychosis of Alzheimer’s disease. Poster presented at the 4th Annual Meeting of the ICGP. 2004.

26 Gharabawi, G. M., Mahmoud, R., Loescher, A., and et al. Augmentation with risperidone in patients with resistant depression: results of the 24-week randomized double-blind trial [poster]. 24th Annual Meeting of the Collegium Internationale Neuro-Psychopharmacologicum. 2004.

27 Daniels, D. G., Zimbroff, D., and Potkin, S. G. et al. Ziprasidone 80 mg/day and 160 mg/day in the acute exacerbation of schizophrenia nad schizoaffective disorder: a 6-week, placebo-controlled trial. The ziprasidone study group. 99;20:490–505.

28 Keck, P. Jr, Buffenstein, A., Ferguson, J., Feighner, J., Jaffe, W., Harrigan, E. P., and Morrissey, M. R. Ziprasidone 40 and 120 mg/day in the acute exacerbation of schizophrenia and schizoaffective disorder: a 4-week placebo-controlled trial. 98;140: 2:173–84.

29 Padala, P. R., Monnahan, M., Ramaswamy, S., and et al. Risperidone in the treatment for post-traumatic stress disorder (PTSD) in women [poster]. NCDEU. 2005.

30 Reich, D. B., Winternitz, S., Hennen, J., Watts, T., and Stanculescu, C. A preliminary study of risperidone in the treatment of posttraumatic stress disorder related to childhood abuse in women. 2004;65: 12:1601–6.

31 Bystritsky, A., Ackerman, D. L., Rosen, R. M., Vapnik, T., Gorbis, E., Maidment, K. M., and Saxena, S. Augmentation of serotonin reuptake inhibitors in refractory obsessive-compulsive disorder using adjunctive olanzapine: a placebo-controlled trial. 2004;65: 4:565–8.

32 Buchsbaum, M. S. Risperidone in refractory obsessive-compulsive disorder (OCD): positron emission tomography (PET) imaging [abstract]. 23rd Annual conference of the Anxiety Disorders Association of America. 2003.

33 Erzegovesi, S., Guglielmo, E., Siliprandi, F., and Bellodi, L. Low-dose risperidone augmentation of fluvoxamine treatment in obsessive-compulsive disorder: a double-blind, placebo-controlled study. 2005;15: 1:69–74.

34 Hollander, E., Rossi, N. B., Sood, E., and Pallanti, S. Risperidone augmentation in treatment-resistant obsessive-compulsive disorder: a double-blind, placebo-controlled study. 2003;6: 4:397–401.

35 Butterfield, M. I., Becker, M. E., Connor, K. M., Sutherland, S., Churchill, L. E., and Davidson, J. R. Olanzapine in the treatment of post-traumatic stress disorder: a pilot study. 2001;16: 4:197–203.

36 Stein, M. B., Kline, N. A., and Matloff, J. L. Adjunctive olanzapine for SSRI-resistant combat-related PTSD: a double-blind, placebo-controlled study. 2002;159: 10:1777–9.

37 Hamner, M. B., Faldowski, R. A., Ulmer, H. G., Frueh, B. C., Huber, M. G., and Arana, G. W. Adjunctive risperidone treatment in post-traumatic stress disorder: a preliminary controlled trial of effects on comorbid psychotic symptoms. 2003;18: 1:1–8.

38 Monnelly, E. P., Ciraulo, D. A., Knapp, C., and Keane, T. Low-dose risperidone as adjunctive therapy for irritable aggression in posttraumatic stress disorder. 2003;23: 2:193–6.

39 Bogenschutz, M. P. and George Nurnberg, H. Olanzapine versus placebo in the treatment of borderline personality disorder. 2004;65: 1:104–9.

40 Zanarini, M. C. and Frankenburg, F. R. Olanzapine treatment of female borderline personality disorder patients: a double-blind, placebo-controlled pilot study. 2001;62: 11:849–54.

41 Koenigsberg, H. W., Reynolds, D., Goodman, M., New, A. S., Mitropoulou, V., Trestman, R. L., Silverman, J., and Siever, L. J. Risperidone in the treatment of schizotypal personality disorder. 2003;64: 6:628–34.

42 Sallee, F. R., Kurlan, R., Goetz, C. G., Singer, H., Scahill, L., Law, G., Dittman, V. M., and Chappell, P. B. Ziprasidone treatment of children and adolescents with Tourette’s syndrome: a pilot study. 2000;39: 3:292–9.

43 Breder, C., Swanink, R., Marcus, R., and et al. Dose-ranging study of ariprprazole in patients with Alzheimer’s dementia. Poster. 9th International Conference on Alzheimer’s Desease and Related Disorders. 2004.

44 De Deyn, P., Jeste, D. V., Swanink, R., Kostic, D., Breder, C., Carson, W. H., and Iwamoto, T. Aripiprazole for the treatment of psychosis in patients with Alzheimer’s disease: a randomized, placebo-controlled study. 2005;25: 5:463–7.

45 Streim JE, McQuade RD, Stock E, Goyvaerts H, Breder C, Iwamoto T, and Yamamoto Y. Aripiprazole treatment of institutionalized patients with psychosis of alszheimer’s dementia. 2004.

46 McQuade R, Sanche R, Marcus R, Carson W, Rollin L, Iwamoto T, and Stock E. Aripiprazole for relapse prevention in bipolar depression in a 26-week trial. 2004.

47 Kennedy, J., Deberdt, W., Siegal, A., Micca, J., Degenhardt, E., Ahl, J., Meyers, A., Kaiser, C., and Baker, R. W. Olanzapine does not enhance cognition in non-agitated and non-psychotic patients with mild to moderate Alzheimer’s dementia. 2005;20: 11:1020–7.

48 Soler, J., Pascual, J. C., Campins, J., Barrachina, J., Puigdemont, D., Alvarez, E., and Perez, V. Double-blind, placebo-controlled study of dialectical behavior therapy plus olanzapine for borderline personality disorder. 2005;162: 6:1221–4.

49 Scahill, L., Leckman, J. F., Schultz, R. T., Katsovich, L., and Peterson, B. S. A placebo-controlled trial of risperidone in Tourette syndrome. 2003;60: 7:1130–5.

C8_ Evidence Tables

Augmentation Trials

Author, Year | Randomization adequate? | Allocation concealment adequate? | Groups similar at baseline? | Eligibility criteria specified? | Outcome assessors masked? | Care provider masked? | Patient masked? | Attrition, crossovers, adherence, contamination | Loss to follow-up: differential/high | Intention-to-treat analysis | Post-randomization exclusions | Quality rating (Jadad score) | | Number screened/Eligible/Enrolled | Exclusion criteria | Run-in/Randomization Method Washout/Randomization Method | Class naïve patients only | Control group standard of care | Funding | Relevance
(Tohen M et al., 2002)^1^ | Method NR | Method NR | Yes | Yes | NR | Yes, but not described | Yes, but not described | Yes/NR/NR/NR | No | Yes | No | | 3 | 501/344/344 | NR | NR Washout period reported | NR | Yes | Source: Industry Role: NR | Yes
(Yargic LI et al., 2004)^2^ | Method NR | Method NR | Yes | Yes | Yes | No | No | Yes/NR/NR/NR | NR | No | No | | 2 | NR/120/NR | HAM-D Item 3 > 2, Psychotic disorder, Use psychotropic medications within 4 wks, Medically significant disorders, Abnormal laboratory results, Bipolar disorder, Alcohol or substance abuse or dependency, Pregnant | NR NR | NR | Yes | Source: NR Role: NR | Yes
(Atmaca M et al., 2002)^3^ | Method NR | Method NR | Yes | Yes | NR | NR | NR | Yes/NR/NR/NR | No | Yes | No | | 2 | 52/27/27 | NR | Run-in period reported NR | NR | Yes | Source: NR Role: NR | Yes
(Denys D et al., 2004)^4^ | Method NR | Method NR | Yes | Yes | Yes | Yes | Yes | Yes/NR/NR/NR | No | Yes | No | | 4 | NR/40/40 | Tic disorder, Tourettes disorder, Major depressive disorder, Pregnant, Organic mental disorder, Seizure disorder or epilepsy or risk, Neurological disorder, Bipolar disorder | NR NR | NR | Yes | Source: Industry Role: NR | Yes
(Cavedini P et al., 2004)^5^ | Yes | Method NR | Yes | Yes | Yes | No | Yes | NR/NR/NR/NR | NR | No | No | | 4 | NR/30/30 | DSM-IV Axis I disorder, not including primary condition studied, Tic disorder, Medically significant disorders, Severe internal or neurological disease, Brain injury or head trauma, Alcohol or substance abuse or dependency | NR NR | Yes | Yes | Source: NR Role: NR | Yes
(McDougle CJ et al., 2000)^6^ | Yes | Method NR | Yes | Yes | Yes | Yes, but not described | Yes, but not described | Yes/NR/NR/NR | No | Yes | No | | 4 | 70/36/36 | Non-healthy, Pregnant, Use psychotropic medications within 4 wks | Run-in period reported NR | NR | Yes | Source: Government & Private Role: described | Yes
(Shapira NA et al., 2004)^7^ | Method NR | Method NR | Yes | Yes | NR | Yes, but not described | Yes, but not described | Yes/NR/NR/NR | No | Yes | No | | 3 | 74/44/44 | Major depressive disorder, Psychotic disorder, Bipolar disorder, Alcohol or substance abuse or dependency, Seizure disorder or epilepsy or risk, Encephalitis, Brain injury or head trauma, Medically significant disorders | Run-in period reported NR | NR | Yes | Source: Government & Industry Role: NR | Yes
(Dunner D et al., 2003)^8^ | Method NR | Method NR | Yes | Yes | Yes | No | No | NR/NR/Yes/NR | NR | Yes | No | 1 | | 90/64/64 | NR | Run-in period reported NR | NR | Yes | Source: Industry Role: NR | Yes
(Carey PD et al., 2005)^9^ | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes/NR/NR/NR | No | Yes | Yes, exclusions reported by group:0/1/. | 5 | | NR/42/42 | Lactating, Sexually active females of child bearing age not using an effective contraceptive method, Medically significant disorders, Brain injury or head trauma, Co- existing Axis -I disorder unless deemed to be secondary to OCD, Brain Surgery, Seizure disorder or epilepsy or risk, Medications that that interact with Quetiapine | Run-in period reported NR | No | Yes | Source: Industry Role: NR | Yes
(Fineberg NA et al., 2005)^10^ | Method NR | Method NR | Yes | Yes | Yes, but not described | Yes, but not described | Yes, but not described | Yes/NR/NR/NR | No | Yes | No | 3 | | NR/21/21 | DSM-IV Axis I disorder, not including primary condition studied, DSM-IV Axis I disorder, not including primary condition studied or depression with MADRS < 30, Tourettes disorder, Resistant to antipsychotic treatment | NR NR | No | Yes | Source: Industry Role: described | Yes
(Li X et al., 2005)^11^ | Method NR | Method NR | NR | Yes | NR | Yes, but not described | Yes, but not described | Yes/Yes/Yes/NR | NR | No | No | 2 | | 27/16/16 | DSM-IV Axis I disorder, not including primary condition studied, SADS-L (Schedule for Affective Disorders and Schizophrenia - Lifetime version) Criteria, Major motor disorder, Vocal tics | Run-in period reported Washout period reported | NR | Yes | Source: Industry Role: NR | Yes

Acronyms in Evidence Table: CCT, Clinical control trial; kg, kilograms; lbs, pounds; ND, Not described; NOS, Not otherwise specified; NR, Not reported; RCT, Randomized control trial; RR, Risk ratio; SMD, Standard mean difference; WMD, Weighted mean difference

Outcomes: ABC, Aberrant Behavior Checklist; ACES, Agitation-Calmness Evaluation Scale; ADAS-cog, Alzheimer’s Disease Assessment Scale; ADHDRS, DuPaul Attention Deficit Hyperactivity Scale; ADL, Activities of Daily Life; AIAQ, Anger, Irritability, and Assault Questionnaire; ASI, Addiction Severity Index; BABS, Brown Assessment of Beliefs Scale; BAI, Beck Anxiety Index; BDHI, Buss-Durkee Hostility Index; BDI, Beck Depression Index; BDS, Blessed Dementia Scale; BEHAVE-AD, Behavioral Pathology in Alzheimer’s Disease Rating Scale; BPRS, Brief Psychiatric Rating Scale; BRMES, Bech-Rafaelsen Melancholia Scale; CAPS, Clinician Administered PTSD Scale; CDSS, Calgary Depression Scale for Schizophrenia; CES-D, Center for Epidemiologic Studies Depression Scale; CGI, Clinical Global Impression Scale; CMAI, Cohen-Mansfield Agitation Inventory; CM-PNB, Cohen-Mansfield Physically Non-Aggressive Behavior; CPRS, Children’s Psychiatric Rating Scale; CSDD, Cornell Scale for Depression in Dementia; CY-BOCS, Children’s Yale-Brown Obsessive-Compulsive Scale; DCM, Dementia Care Mapping; DES, Dissociative Experiences Scale; DTS, Davidson Trauma Scale; E-BEHAVE-AD, Empirical Behavioral Pathology in Alzheimer’s Disease Rating Scale; FAST, Functional Assessment Staging Rating Scale; GAF, Global Assessment of Functioning Scale; HAM-A, Hamilton Rating Scale for Anxiety; HAM-D/HDRS, Hamilton Rating Scale for Depression; IGT, Iowa Gambling Task; MADRS, Montgomery-Asberg Depression Rating Scale; MDRS, Mattis Dementia Rating Scale; MMSE, Mini-Mental State Examination; M-NCAS, Modified Strain in Nursing Care Assessment; MOSES, Multidimentional Observational Scale for Elderly Subjects; MOVES, Motor Tic, Obsessions, and Compulsions, Vocal Tic Evaluation Survey; N-CBRF, Nisonger Child Behavior Rating Scale; NIMH-OC, National Institute of Mental Health Obsessive-Compulsive Scale; NPI, Neuropsychiatric Inventory; NPI/NH, Neuropsychiatric Inventory/Nursing Home; NPI-Q, Neuropsychiatric Inventory Questionnaire; OAS-M, Overt Aggression Scale-Modified; PANSS, Positive and Negative Symptom Scale; PCL-M, Patient Checklist for PTSD--Military Version; PDC, Depression cluster; PDS, Progressive Deterioration Scale; PGDRS, Psychogeriatric Dependency Rating Scale; PGI, Patient Global Impressions; QLDS, Quality of Life in Depression Scale; Q-LES-Q, Quality of Life Enjoyment and Satisfaction Questionnaire; QLS, Quality of Life Scales; QUALID, Quality of Life in Late-Stage Dementia Scale; ROAS, Retrospective Overt Aggression Scale; SANS, Scale for the Assessment of Negative Symptoms; SCL-90, Symptom Checklist-90; SDS, Sheehan Disability Scale; SF-36, Medical Outcomes Study 36-Item Short-Form Health Survey; SIB, Severe Impairment Battery; SIB-Q, Self-injurious Behavior Questionnaire; SIP, Structured Interview for PTSD; SPQ, Schizotypal Personality Questionnaire; SPRINT, Short PTSD Rating Interview; STAS-AX, State-Trait Anger Expression Inventory; STAT-S, Spielberger State-Trait Anger Scale, state version; STAT-T, Spielberger State-Trait Anger Scale, trait version; TOP-8, Treatment Outcome PTSD Scale; TSSS, Tourette’s Syndrome Severity Scale; VAS, Visual Analog Scale; Y-BOCS, Yale-Brown Obsessive-Compulsive Scale; YGTSS, Yale Global Tic Severity Scale; YMRS, Young Mania Rating Scale

1 Tohen, M., Chengappa, K. N., Suppes, T., Zarate, C. A. Jr, Calabrese, J. R., Bowden, C. L., Sachs, G. S., Kupfer, D. J., Baker, R. W., Risser, R. C., Keeter, E. L., Feldman, P. D., Tollefson, G. D., and Breier, A. Efficacy of olanzapine in combination with valproate or lithium in the treatment of mania in patients partially nonresponsive to valproate or lithium monotherapy. 2002;59: 1:62–9.

2 Yargic, L. I., Corapcioglu, A., Kocabasoglu, N., Erdogan, A., Koroglu, G., and Yilmaz, D. A prospective randomized single-blind, multicenter trial comparing the efficacy and safety of paroxetine with and without quetiapine therapy in depression associated with anxiety. 2004;8: 4: 205–211 URL: http://www.tandf.co.uk/journals/md/13651501.html.

3 Atmaca, M., Kuloglu, M., Tezcan, E., and Gecici, O. Quetiapine augmentation in patients with treatment resistant obsessive-compulsive disorder: a single-blind, placebo-controlled study. 2002;17: 3:115–9.

4 Denys, D., de Geus, F., van Megen, H. J., and Westenberg, H. G. A double-blind, randomized, placebo-controlled trial of quetiapine addition in patients with obsessive-compulsive disorder refractory to serotonin reuptake inhibitors. 2004;65: 8:1040–8.

5 Cavedini, P., Bassi, T., Zorzi, C., and Bellodi, L. The advantages of choosing antiobsessive therapy according to decision-making functioning. 2004;24: 6:628–31.

6 McDougle, C. J., Epperson, C. N., Pelton, G. H., Wasylink, S., and Price, L. H. A double-blind, placebo-controlled study of risperidone addition in serotonin reuptake inhibitor-refractory obsessive-compulsive disorder. 2000;57: 8:794–801.

7 Shapira, N. A., Ward, H. E., Mandoki, M., Murphy, T. K., Yang, M. C., Blier, P., and Goodman, W. K. A double-blind, placebo-controlled trial of olanzapine addition in fluoxetine-refractory obsessive-compulsive disorder. 2004;55: 5:553–5.

8 Dunner, D., Amsterdam, J., Shelton, R., Hassman, H., Rosenthal, M., and Romano, S. Adjunctive ziprasidone in treatment-resistant depression: a pilot study {Abstract NR238]. 156th APA Annual Meeting. 2003.

9 Carey, P. D., Vythilingum, B., Seedat, S., Muller, J. E., van Ameringen, M., and Stein, D. J. Quetiapine augmentation of SRIs in treatment refractory obsessive-compulsive disorder: a double-blind, randomised, placebo-controlled study. 2005;5: 1:5.

10 Fineberg, N. A., Sivakumaran, T., Roberts, A., and Gale, T. Adding quetiapine to SRI in treatment-resistant obsessive-compulsive disorder: a randomized controlled treatment study. 2005;20: 4:223–6.

11 Li, X., May, R. S., Tolbert, L. C., Jackson, W. T., Flournoy, J. M., and Baxter, L. R. Risperidone and haloperidol augmentation of serotonin reuptake inhibitors in refractory obsessive-compulsive disorder: a crossover study. 2005;66: 6:736–43.