# Exact Search Strings

- PsycInfo Searches
- Searched: 1/7/05

- Off-label & drug names – 6 citations
- Off-label & conditions –- 41 citations
- clinical trials & drug names & conditions –- 28 citations
- clinical trials & drug names & conditions & off-label – 0 citations
- drug names & conditions – 657 citations
- off-label & drug names & conditions – 1 citation

Total Unique Results in PsycInfo: 702

Search Strategies:

- Conditions
- (((su= “personality disorders” OR su= “obsessive compulsive disorder” OR su= “obsessive compulsive personality disorder” OR su= “posttraumatic stress disorder”)) or ((su: dementia OR su: depression)) or (kw: severe w geriatric w agitation OR kw: geriatric w agitation) and yr: 1990–2005) or (((kw: personality w disorders OR kw: obsessive w compulsive w disorder OR kw: obsessive w compulsive w personality w disorder OR kw: posttraumatic w stress w disorder OR kw: ptsd OR kw: ocd OR kw: post w traumatic w stress OR kw: obsessive w compulsive)) or ((kw: dementia OR kw: depression)) or (kw: severe w geriatric w agitation OR kw: geriatric w agitation) and yr: 1990–2005)
- Total Results: 96355

- Off-Label
- kw: off w label or kw: off-label OR kw: offlabel OR kw: atypical w use OR kw: non w intended w use OR kw: non w intentional w use OR kw: “not” w intended w use and yr: 1990–2005
- Total Results: 346

- Clinical Trials
- (de= “clinical trials”) or ((kw: controlled w clinical w trial OR kw: controlled w clinical w trials OR kw: randomized w trial OR kw: randomized w trials OR kw: randomized w controlled w trial OR kw: randomized w controlled w trials OR kw: clinical w trial OR kw: clincal w trials)) and yr: 1990–2005
- Total Results: 4709

- Drug Names
- (kw: Risperidone OR kw: olanzapine OR kw: quetiapine OR kw: aripiprazole OR kw: ziprasidone) or ((de: Risperidone OR de: olanzapine OR de: quetiapine OR de: aripiprazole OR de: ziprasidone)) and yr: 1990–2005
- Total Results: 3698

- The Cochrane Central Register of Controlled Trials (CENTRAL) Searches
- (Note: Clinical trial terms were not included in search strategy as this database is limited to controlled trials already)
- Searched: 1/7/05

- Off-label & drug names -- 0
- Off-label & conditions -- 0
- Drug names & conditions & off-label -- 0
- Drug names & conditions -- 299

Total Unique Results in Cochrane CENTRAL: 299

Search Strategies:

- Off-label
- (“atypical use” OR “off label” OR “non intended use” OR “non intentional use” OR “not intended use” OR “use not intended”) in All Fields,
- Limited to: 1990 to 2005
- Total Results: 1

- Drug names
- (Risperidone OR olanzapine OR quetiapine OR aripiprazole OR ziprasidone) in Abstract or (Risperidone OR olanzapine OR quetiapine OR aripiprazole OR ziprasidone) in Keywords or (Risperidone OR olanzapine OR quetiapine OR aripiprazole OR ziprasidone) in Record Title or (MeSH descriptor Risperidone explode all trees in MeSH products)
- Limited to: 1990 to 2005
- Total Results: 1901

- Conditions
- (“Personality Disorder*” OR “Dementia” OR “Depression” OR “Depressive Disorder” OR depress* OR “Obsessive Compulsive Disorder” OR ocd OR “Post-Traumatic Stress disorder*” OR ptsd OR severe geriatric agitation OR geriatric agitation) in Abstract or (“Personality Disorder*” OR “Dementia” OR “Depression” OR “Depressive Disorder” OR depress* OR “Obsessive Compulsive Disorder” OR ocd OR “Post-Traumatic Stress disorder*” OR ptsd OR severe geriatric agitation OR geriatric agitation) in Record Title or (“Personality Disorder*” OR “Dementia” OR “Depression” OR “Depressive Disorder” OR depress* OR “Obsessive Compulsive Disorder” OR ocd OR “Post-Traumatic Stress disorder*” OR ptsd OR severe geriatric agitation OR geriatric agitation) in Keywords
  OR
  (MeSH descriptor Personality Disorders explode all trees in MeSH products OR
  MeSH descriptor Dementia explode all trees in MeSH products OR MeSH descriptor Depression explode all trees in MeSH products OR MeSH descriptor Depressive Disorder explode all trees in MeSH products OR MeSH descriptor Obsessive-Compulsive Disorder explode all trees in MeSH products ORMeSH descriptor Stress Disorders, Post-Traumatic explode all trees in MeSH products)
- Limited to: 1990 to 2005
- Total Results: 16389

- Cochrane Database - Search Strategy
- (Antipsychotic Agents[MeSh descriptor] OR risperidone OR olanzapine OR quetiapine OR aripiprazole OR ziprasidone) AND (depression OR dementia OR obsessive compulsive disorder OR post traumatic stress disorder OR ptsd OR off label OR off-label)
- Date Searched: 12/15/2004
- Limited search to: The Cochrane Database of Systematic Reviews
- Total Results: 78

- PubMed Search Strategy
- (“Antipsychotic Agents”[MeSH] OR “Antipsychotic Agents”[Pharmacological Action] OR aripiprazole OR olanzapine OR quetiapine OR risperidone OR ziprasidone) AND (depression OR dementia OR obsessive compulsive disorder OR post traumatic stress disorder OR ptsd OR off label OR off-label)
- Date Searched: 12/15/2004
- Limited to: Systematic Reviews
- Total Results: 95

- PubMed Search Strategy
- Limited: 1990–2005
- Database searched: January 4, 2005
- Total Results: 996
- [(Risperidone OR olanzapine OR quetiapine OR aripiprazole OR ziprasidone) OR
  (“Risperidone”[MeSH] OR “olanzapine”[Substance Name] OR “quetiapine”[Substance Name] OR “aripiprazole”[Substance Name] OR “ziprasidone”[Substance Name])
  AND
  “atypical use” OR “off label” OR “non intended” OR “non intentional”
  AND
  (“Personality Disorders”[MeSH] OR “Dementia”[MeSH] OR “Depression”[MeSH] OR “Depressive Disorder”[MeSH] OR “Obsessive-Compulsive Disorder”[MeSH] OR “Stress Disorders, Post-Traumatic”[MeSH]) OR (“Personality Disorder*” OR “Dementia” OR “Depression” OR “Depressive Disorder” OR depress* OR “Obsessive Compulsive Disorder” OR ocd OR “Post-Traumatic Stress disorder*” OR ptsd OR severe geriatric agitation OR geriatric agitation)]
  OR
  [(Risperidone OR olanzapine OR quetiapine OR aripiprazole OR ziprasidone) OR
  (“Risperidone”[MeSH] OR “olanzapine”[Substance Name] OR “quetiapine”[Substance Name] OR “aripiprazole”[Substance Name] OR “ziprasidone”[Substance Name])
  AND
  “atypical use” OR “off label” OR “non intended” OR “non intentional”]
  OR
  [“atypical use” OR “off label” OR “non intended” OR “non intentional”
  AND
  (“Personality Disorders”[MeSH] OR “Dementia”[MeSH] OR “Depression”[MeSH] OR “Depressive Disorder”[MeSH] OR “Obsessive-Compulsive Disorder”[MeSH] OR “Stress Disorders, Post-Traumatic”[MeSH]) OR (“Personality Disorder*” OR “Dementia” OR “Depression” OR “Depressive Disorder” OR depress* OR “Obsessive Compulsive Disorder” OR ocd OR “Post-Traumatic Stress disorder*” OR ptsd OR severe geriatric agitation OR geriatric agitation)]
  OR
  [(Risperidone OR olanzapine OR quetiapine OR aripiprazole OR ziprasidone) OR
  (“Risperidone”[MeSH] OR “olanzapine”[Substance Name] OR “quetiapine”[Substance Name] OR “aripiprazole”[Substance Name] OR “ziprasidone”[Substance Name])
  AND
  (“Personality Disorders”[MeSH] OR “Dementia”[MeSH] OR “Depression”[MeSH] OR “Depressive Disorder”[MeSH] OR “Obsessive-Compulsive Disorder”[MeSH] OR “Stress Disorders, Post-Traumatic”[MeSH]) OR (“Personality Disorder*” OR “Dementia” OR “Depression” OR “Depressive Disorder” OR depress* OR “Obsessive Compulsive Disorder” OR ocd OR “Post-Traumatic Stress disorder*” OR ptsd OR severe geriatric agitation OR geriatric agitation)]