# Appendixes

Appendix A Exact Search Strings

Appendix B Data Collection Forms

Appendix C Evidence and Quality Tables

Appendix D Excluded Articles

Appendix E Adverse Event Analysis