# Technical Expert Panel

Jennifer Burr, M.R.C.Ophth., D.O., M.Sc.

Centre for Healthcare Randomised Trials

Health Services Research Unit, University of Aberdeen

Aberdeen, UK

Murray Fingeret, O.D., FAAO

State University of New York College of Optometry

Department of Veterans Affairs

Hewlett, NY

Flora Lum, M.D.

H. Dunbar Hoskins Center

American Academy of Ophthalmology

San Francisco, CA