# Peer Reviewers

Anne Coleman, M.D.

Ronald Reagan UCLA Medical Center

Los Angeles, CA

Rosanne Leipzig, M.D., Ph.D.

Mount Sinai School of Medicine

New York, NY

Flora Lum, M.D.

H. Dunbar Hoskins Center

American Academy of Ophthalmology

San Francisco, CA

Diana Petitti, M.D., M.P.H.

Arizona State University

Phoenix, AZ

Timothy Wilt, M.D., M.P.H.

Minneapolis Veterans Affairs Medical Center

University of Minnesota Department of Medicine

Minneapolis, MN

Linda Zangwill, Ph.D.

University of California, San Diego

Hamilton Glaucoma Center

La Jolla, CA