# Key Informants

Ross J. Brechner, M.D., M.S., M.P.H.

Lead Medical Officer National Coverage & Analysis Group

Centers for Medicare & Medicaid Services

Catonsville, MD

Anne Coleman, M.D.

Ronald Reagan UCLA Medical Center

Representative from the American Glaucoma Society

Los Angeles, CA

Murray Fingeret, O.D., FAAO

State University of New York College of Optometry

Department of Veterans Affairs

Representative from The Glaucoma Foundation

Hewlett, NY

Stephen A. Kamenetzky, M.D.

Washington University School of Medicine

Associate Medical Director, Blue Cross Blue Shield Missouri

St. Louis, MO

Paul P. Lee, M.D.

Department of Ophthalmology

Clinician/Representative from the American Glaucoma Society

Duke University School of Medicine

Durham, NC

Edith Marks

Glaucoma Support & Education Group

Patient/Representative from the Glaucoma Support and Education Group

New York, NY

Mildred Olivier, M.D.

Representative from the National Medical Association Midwest Glaucoma Center PC

Chicago, IL

Clifton L. Peay, M.D.

Clinician/Representative from the Roman-Barnes Society of Ophthalmology

Mechanicsville, VA

Bruce Prum, Jr., M.D.

University of Virginia Health System

Charlottesville, VA

Art Takahara

Patient/Representative from the Glaucoma Research Foundation

San Francisco, CA

Timothy Wilt, M.D., M.P.H.

Minneapolis Veterans Affairs Medical Center

University of Minnesota Department of Medicine

Representative of U.S. Preventive Services Task Force

Minneapolis, MN