# Included Devices

PERIMETRY (Device with Testing Algorithm)

Humphrey Field Analyzer | HFA Fastpac | HFA Full Threshold | HFA SITA-Standard | HFA SITA-Fast | HFA SWAP | HFA SITA-SWAP | HFA Unspecified white on white or static perimetry | HFA Unspecified SWAP | HFA Unspecified | HFA Other
Matrix FDT | FDT N-30 | FDT C-20 | FDT Full Threshold | FDT SITA | FDT Other | FDT Unspecified
Octopus | 300-TOP | 300-White on White | 300-SWAP | 300-Unspecified | 900-TOP | 900-White on White | 900-SWAP | 900-Unspecified | Octopus other

OPTICAL COHERENCE TOMOGRAPHY (OCT)

Zeiss Stratus | Stratus Optic Disc | Stratus RNFL | Stratus Fast Optic Disc | Stratus Fast RNFL | Stratus Unspecified | Stratus Other
Zeiss Cirrus | Cirrus Optic Disc | Cirrus RNFL | Cirrus Unspecified | Cirrus Other
Heidelberg | Spectralis Optic Disc | Spectralis RNFL | Spectralis Unspecified | Spectralis Other
Optovue | RTVue Optic Disc | RTVue RNFL | RTVue GCC | RTVue Unspecified | RTVue Other
Topcon | 3D OCT-1000 Optic Disc | 3D OCT-1000 RNFL | 3D OCT-1000 Unspecified | 3D OCT-1000 Other | 3D OCT-2000 Optic Disc | 3D OCT-2000 RNFL | 3D OCT-2000 Unspecified | 3D OCT-2000 Other

SCANNING LASER OPHTHALMOSCOPY (as HRT)

HRT | HRT II | HRT III

SCANNING LASER POLARIMETRY (as Gdx)

GDX | GDX-VCC | GDX-ECC

CONTACT AND NON-CONTACT TONOMETRY (Device details not abstracted)

DIRECT AND INDIRECT OPHTHALMOSCOPY (Device details not abstracted)

FUNDUS PHOTOGRAPHY (Device details not abstracted)