# Excluded Articles

Aasved H, Hovding G. The Bergen Glaucoma Study: Diagnostic criteria, epidemiology, prognostic factors and indications for treatment. CHIBRET INT. J OPHTHALMOL. 87; 5(3):4-19. Does not address any key questions
Ia Abakumova L, Nesterov AP, Mitkokh DI, Sushkova OP. Statistical analysis of data from glaucoma examinations. Med Tekh. 79(6):16-20. Foreign language
Abdel-Ghafar RA, Morris T. Progress towards automated detection and characterization of the optic disc in glaucoma and diabetic retinopathy. Med Inform Internet Med. 2007;32(1):19-25. [pmid: 17365641]. Data not abstractable
Abdul Majid AS, Kwag JH, Jung SH, Yim HB, Kim YD, Kang KD. Correlation between disc damage likelihood scale and optical coherence tomography in the diagnosis of glaucoma. Ophthalmologica. 2010;224(5):274-82. [pmid: 20185941]. Testing in-house scoring system only
Abraham-Cohen JA, Bass SJ, Feldman J, Wyatt H. HUMPHREY SITA VS OCTOPUS TOP IN GLAUCOMA PATIENTS. American Academy of Optometry. 99:176. Abstract only
Accornero N, Capozza M, De Feo A, Rinalduzzi S, De Marinis M, Pecori-Giraldi J, Mollicone A, Volante V. Video color perimetry: impairment in glaucoma suspects. Doc Ophthalmol. 2001;103(2):81-90. [pmid: 11720258]. Does not address any key questions
Adachi M, Shirato S. The usefulness of the Noise-Field Test as a screening method for visual field defects. JPN. J OPHTHALMOL. 94; 38(4):392-399. Does not address any key questions
Adler W, Warntges S, Lausen B, Michelson G. Prevalence of glaucomatous optic nerve atrophy among a working population in Germany diagnosed by a telemedical approach. Klin Monbl Augenheilkd. 2010;227(11):905-11. [pmid: 20603781]. Foreign language
Agbeja-Baiyeroju AM, Bekibele CO, Bamgboye EA, Omokhodion F, Oluleye TS. The Ibadan glaucoma study. Afr J Med Med Sci. 2003;32(4):371-376. [pmid: 15259920]. Other (specify): not all subjects given definitive exam
Agbeja-Baiyeroju AM, Bekibele CO, Bamgboye EA, Omokhodion F, Oluleye TS. The Ibadan glaucoma study. Afr J Med Med Sci. 2003;32(4):371-376. [pmid: 15259920]. Unspecified diagnosis of Glaucoma
Ahn B-S, Kee C. Ability of a confocal scanning laser ophthalmoscope (TopSS) to detect early glaucomatous visual field defect. Br. J Ophthalmol. 2000;84(8):852-855. [pmid: 10906090]. Infrequently used device: TopSS
Ahnoux-Zabsonre A, Keita C, Safede K, Tanoe A. Prevalence of primary chronic open-angle glaucoma in Ivory Coast. J Fr Ophtalmol. 98; 21(9):643-7. Does not address any key questions
Alberta Heritage Foundation for Medical Research. Confocal scanning laser ophthalmoscopy and scanning laser polarimetry for early diagnosis of glaucoma. Brief Record
Edmonton: Alberta Heritage Foundation for Medical Research (AHFMR). 2006:42. Brief Record
Alembn Edgardo, Celis Vanessa, Dreyer M nica. Campimetria computarizada con el analizador de campos visuales humphrey: estudio de 350 casos. Centro mqd. 97; 42(2):92-4. Foreign language
Alencar LM, Bowd C, Weinreb RN, Zangwill LM, Sample PA, Medeiros FA. Comparison of HRT-3 glaucoma probability score and subjective stereophotograph assessment for prediction of progression in glaucoma. Invest Ophthalmol Vis Sci. 2008;49(5):1898-906. [pmid: 18436823]. Does not address any key questions
Alias Alegre EG, Ferreras A, Polo V, Larrosa JM, Pueyo V, Honrubia FM. Importance of central corneal thickness when studying ocular hypertensive eyes, glaucoma suspects and preperimetric glaucomatous eyes. Importancia del espesor corneal central en el estudio de hipertensos oculares, sospechosos de glaucoma y glaucomas preperimetricos. Arch. Soc. Esp Oftalmol. 2007;82(10):615-621. [pmid: 17929204]. Foreign language
Alias EG, Ferreras A, Polo V, Larrosa JM, Pueyo V, Honrubia FM. Importance of central corneal thickness when studying ocular hypertensive eyes, glaucoma suspects and preperimetric glaucomatous eyes. Arch Soc Esp Oftalmol. 2007;82(10):615-21. [pmid: 17929204]. Does not address any key questions
Allen CS, Sponsel WE, Trigo Y, Dirks MS, Flynn WJ. Comparison of the frequency doubling technology screening algorithm and the Humphrey 24-2 SITA-FAST in a large eye screening. Clin Experiment Ophthalmol. 2002;30(1):8-14. [pmid: 11885802]. Does not use clinical assessment as reference standard
Allingham RR, Loftsdottir M, Gottfredsdottir MS, Thorgeirsson E, Jonasson F, Sverisson T, Hodge WG, Damji KF, Stefansson E. Pseudoexfoliation syndrome in Icelandic families. Br J Ophthalmol. 2001;85(6):702-7. [pmid: 11371492]. Does not address any key questions
Almeida GVd, Mandia C J•nior, Paolera MD, et al. ImportGncia da perimetria de dupla freqnWncia na detecgPo do glaucoma: rastreamento em funcionbrios de hospital p•blico numa brea urbana de SPo Paulo. Arq. Bras Oftalmol. 2005;68(1):49-53. [pmid: 15824803]. Foreign language
Almeida GVd. Campimetria e pressåo intra-ocular. An Oftalmol. 1986;5(1):9-15. Foreign language
Almeida PBd, Almeida GVd, Cohen R, Prata JA J•nior, Melo PAdA. Correla gåo e correspondWncia topogrbfica entre espessura da camada de fibras nervosas da retina e campo visual no glaucoma prim brio de Gngulo aberto. Arq. Bras Oftalmol. 2001;64(2):109-15. Foreign language
Altangerel U, Nallamshetty HS, Uhler T, Fontanarosa J, Steinmann WC, Almodin JM, Chen BH, Henderer JD. Knowledge about glaucoma and barriers to follow-up care in a community glaucoma screening program. Can J Ophthalmol. 2009;44(1):66-9. [pmid: 19169316]. Does not address any key questions
Andrada MT, Bernaldo De Quiros P, Villegas RS, Anton A. Diagnostic accuracy of frequency doubling perimetry. Arch Soc Esp Oftalmol. 2001;76(12):711-8. [pmid: 11753693]. Foreign language
Andreou PA, Wickremasinghe SS, Asaria RH, Tay E, Franks WA. A comparison of HRT II and GDx imaging for glaucoma detection in a primary care eye clinic setting. Eye (Lond). 2007;21(8):1050-5. [pmid: 16691256]. Foreign language
Anicho UM, Yager D. A SIMPLE, LOW-COST SLIDE-BASED STATIC (SBS) PERIMETER FOR THE SCREENING OF GLAUCOMA: PRELIMINARY EVALUATION. American Academy of Optometry. 99:251. Abstract only
Armaly MF. Ocular pressure and visual fields. A ten-year follow-up study. Arch Ophthalmol. 69; 81(1):25-40. Does not address any key questions
Armaly MF. The visual field defect and ocular pressure level in open angle glaucoma. Invest Ophthalmol. 69; 8(1):105-24. Does not address any key questions
Armaly MF. The visual field defect and ocular pressure level in open angle glaucoma. Invest Ophthalmol. 69; 8(1):105-24. Does not examine candidate screening tests for glaucoma
Artes PH, Iwase A, Ohno Y, Kitazawa Y, Chauhan BC. Properties of perimetric threshold estimates from Full Threshold, SITA Standard, and SITA Fast strategies. Invest Ophthalmol Vis Sci. 2002;43(8):2654-9. [pmid: 12147599]. Does not address any key questions
Artes PH, Hutchison DM, Nicolela MT, LeBlanc RP, Chauhan BC. Threshold and variability properties of matrix frequency-doubling technology and standard automated perimetry in glaucoma. Invest Ophthalmol Vis Sci. 2005;46(7):2451-7. [pmid: 15980235]. Data not abstractable
Arthur SN, Aldridge AJ, De Leon-Ortega J, McGwin G, Xie A, Girkin CA. Agreement in assessing cup-to-disc ratio measurement among stereoscopic optic nerve head photographs, HRT II, and Stratus OCT. J Glaucoma. 2006;15(3):183-9. [pmid: 16778638]. Data not abstractable
Asaoka R, Ishii R, Kyu N, Hotta Y, Sato M. Early detection of thinning of retinal nerve fiber layer in glaucomatous eyes by optical coherence tomography 3000: analysis of retinal nerve fiber layer corresponding to the preserved hemivisual field. Ophthalmic Res. 2006;38(1):29-35. [pmid: 16192746]. Data not abstractable
Asman P, Fingeret M. Comparison of diagnostic performance and fixation control of two automated perimeters. Journal of the American Optometric Association. 97; 68(12):763-8. Infrequently used device
Asman P, Britt JM, Mills RP, Heijl A. Evaluation of adaptive spatial enhancement in suprathreshold visual field screening. Ophthalmology. 88; 95(12):1656-62. Infrequently used device: Unusual visual field strategy
Astrom S, Linden C. Incidence and prevalence of pseudoexfoliation and open-angle glaucoma in northern Sweden:I. Baseline report. Acta Ophthalmol Scand. 2007;85(8):828-831. [pmid: 17986290]. Does not address any key questions
Astrom S, Stenlund H, Linden C. Incidence prevalence of pseudoexfoliations and open-angle glaucoma in northern Sweden: II. Results after 21 years of follow-up. Acta Ophthalmol Scand. 2007;85(8):832-837. [pmid: 17986292]. Does not address any key questions
Aue A, Geitzenauer W, Hirn C, Bolz M, Ahlers C, Leydolt C. Comparison of Retinal Thickness Measures Obtained by STRATUS®-OCT and HD-OCT in Normal and Glaucoma Eyes. IOVS. 2007;48. ARVO E-Abstract 513. Abstract only
Austin MW, O’Brien CJ, Wishart PK. Flicker perimetry using a luminance threshold strategy at frequencies from 5–25 Hz in glaucoma, ocular hypertension and normal controls. CURR EYE RES. 94; 13(10):717-723. Does not address any key questions
Babel J, Vali M. Detection of glaucoma and the organization of consultative services for glaucoma patients. Rev Med Suisse Romande. 70; 90(11):861-8. Foreign language
Bagga H, Greenfield DS. Quantitative assessment of structural damage in eyes with localized visual field abnormalities. Am J Ophthalmol. 2004;137(5):797-805. [pmid: 15126142]. Data not abstractable
Bagga H, Greenfield DS. Quantitative assessment of structural damage in eyes with localized visual field abnormalities. Am J Ophthalmol. 2004;137(5):797-805. [pmid: 15126142]. Does not address any key questions
Bagga H, Greenfield DS, Feuer WJ. Quantitative assessment of atypical birefringence images using scanning laser polarimetry with variable corneal compensation. Am J Ophthalmol. 2005;139(3):437-46. [pmid: 15767051]. Does not address any key questions
Bagga H, Greenfield DS, Feuer W, Knighton RW. Scanning laser polarimetry with variable corneal compensation and optical coherence tomography in normal and glaucomatous eyes. Am J Ophthalmol. 2003;135(4):521-9. [pmid: 12654370]. Does not address any key questions
Bai Z-L, Ren B-C, He Y, Yang J-G, Chen L, Sun N-X. Epidemiology of primary open angle glaucoma in a rural population in Shaanxi Province of China. Int. J Ophthalmol. 2005;5(5):864-871. Foreign language
Bai Z-L, Ren B-C, Yang J-G, He Y, Chen L, Sun N-X. Systemic blood pressure, intraocular pressure and primary open-glaucoma: A population-based study in Shaanxi Province of China. Int. J Ophthalmol. 2005;5(6):1122-1127. Foreign language
Balazsi AG, Saheb NE, Kasner OP, Overbury O, Faubert J. THE EFFECTS OF TIMOLOL MALEATE ON STATIC VISUAL FIELDS, TEMPORAL MODULATION FIELDS, AND SPATIAL CONTRAST SENSITIVITY IN EARLY GLAUCOMA. IOVS. 91:32. ARVO abstraact 2151. Abstract only
Bandyopadhyay M, Raychaudhuri A, Lahiri SK, Schwartz EC, Myatt M, Johnson GJ. Comparison of Goldmann applanation tonometry with the Tonopen for measuring intraocular pressure in a population-based glaucoma survey in rural West Bengal. Ophthalmic Epidemiol. 2002;9(3):215-24. [pmid: 12045888]. Does not address any key questions
Bandyopadhyay M, Raychaudhuri A, Lahiri SK, Schwartz EC, Myatt M, Johnson GJ. Comparison of Goldmann applanation tonometry with the Tonopen for measuring intraocular pressure in a population-based glaucoma survey in rural West Bengal. Ophthalmic Epidemiol. 2002;9(3):215-24. [pmid: 12045888]. Other (specify): reliability only
Baraibar B, Sanchez-Cano A, Pablo LE, Honrubia FM. Preperimetric glaucoma assessment with scanning laser polarimetry (GDx VCC): analysis of retinal nerve fiber layer by sectors. J Glaucoma. 2007;16(8):659-64. [pmid: 18091451]. Does not use clinical assessment as reference standard
Barleon L, Hoffmann EM, Berres M, Pfeiffer N, Grus FH. Comparison of dynamic contour tonometry and goldmann applanation tonometry in glaucoma patients and healthy subjects. Am J Ophthalmol. 2006;142(4):583-90. [pmid: 17011849]. Data not abstractable
BarrÆa Von Bischoffshausen F, Vigueras ChiJ, Riquelme RA. Grant I. V. An blisis del perÆmetro de doble frecuencia como mqtodo diagn£stico en la pesquisa del glaucoma. Arch. Chil Oftalmol. 2000;57(2):47-56. Foreign language
Bass SJ, Cooper J, Feldman J, Horn DA. NEW AUTOMATED CONFRONTATION TESTING DEVICE VS. FINGER COUNTING IN THE DETECTION OF FIELD LOSS IN GLAUCOMA. IOVS. 2004;45. ARVO E-abstract 4507. Abstract only
Bassi CJ, Galanis JC, Hoffman J. Comparison of the Farnsworth-Munsell 100-Hue, the Farnsworth D-15, and the L’Anthony D-15 desaturated color tests. ARCH OPHTHALMOL. 93; 111(5):639-641. Does not address any key questions
Bassi CJ, Galanis JC, Hoffman J. Comparison of the Farnsworth-Munsell 100-Hue, the Farnsworth D-15, and the L’Anthony D-15 desaturated color tests. ARCH OPHTHALMOL. 93; 111(5):639-641. Does not examine candidate screening tests for glaucoma
Bathija R, Zangwill L, Berry CC, Sample PA, Weinreb RN. Detection of early glaucomatous structural damage with confocal scanning laser tomography. J Glaucoma. 98; 7(2):121-7. Infrequently used device: HRT1
Bayraktar S, Bayraktar Z. Central corneal thickness and intraocular pressure relationship in eyes with and without previous LASIK: comparison of Goldmann applanation tonometer with pneumatonometer. Eur J Ophthalmol. 2005;15(1):81-8. [pmid: 15751244]. Does not address any key questions
Belen’kii KR. Pre-glaucoma. Oftalmol Zh. 75; 30(4):275-7. Foreign language
Bella-Hiag AL, Ebana Mvogo C, Ngosso A, Ellong A. Intraocular pressure in a young Cameroonian population. J Fr Ophtalmol. 96; 19(10):585-90. Foreign language
Bellios N, Horn FK, Lammer R, Gottschalk K, Dehne K, Ruhl S, Junemann AG. Peripheral suprathreshold stimulation in preperimetric glaucoma. Ophthalmologe. 2008;105(7):656-60. [pmid: 18415108]. Foreign language
Beneyto P, Barajas MA, Garcia-de-Blas F, Del Cura I, Sanz T, Vello R, Salvador C. Predictive value of tonometry with Tono-pen XL in primary care. Br J Gen Pract. 2007;57(541):653-4. [pmid: 17688761]. Does not address any key questions
Bengtsson B, Heijl A. Diagnostic sensitivity of fast blue-yellow and standard automated perimetry in early glaucoma: a comparison between different test programs. Ophthalmology. 2006;113(7):1092-7. [pmid: 16815399]. Does not address any key questions
Bengtsson B, Heijl A. Diurnal IOP fluctuation: not an independent risk factor for glaucomatous visual field loss in high-risk ocular hypertension. Graefes Arch Clin Exp Ophthalmol. 2005;243(6):513-8. [pmid: 15756577]. Does not address any key questions
Bengtsson BM, Heijl A. SITA SWAP, a New Rapid Threshold Testing Strategy for Blue-On-Yellow Perimetry. IOVS. 2003. ARVO E-abstract 52. Abstract only
Bengtsson BO. Incidence of manifest glaucoma. Br J Ophthalmol. 89; 73(7):483-7. Does not address any key questions
Bengtsson B, Leske MC, Hyman L, Heijl A. Fluctuation of intraocular pressure and glaucoma progression in the early manifest glaucoma trial. Ophthalmology. 2007;114(2):205-9. [pmid: 17097736]. Does not address any key questions
Bengtsson B. A new rapid threshold algorithm for short-wavelength automated perimetry. Invest Ophthalmol Vis Sci. 2003;44(3):1388-94. [pmid: 12601072]. Does not address any key questions
Bengtsson B. Characteristics of manifest glaucoma at early stages. Graefes Arch Clin Exp Ophthalmol. 89; 227(3):241-3. Does not address any key questions
Bengtsson B. Glaucoma case detection. Acta Ophthalmol (Copenh). 91; 69(3):288-92. Does not address any key questions
Bengtsson B. The prevalence of glaucoma. Br J Ophthalmol. 81; 65(1):46-9. Does not address any key questions
Bernardi L, Costa VP, Mutton F, Kara Josq N. Campos visuais nåo-confibveis em pacientes glaucomatosos ou com suspeita de glaucoma: uma anblise dos fatores de risco. Arq. Bras Oftalmol. 1999;62(1):56-66. Foreign language
Bernardin P, Rabeantoandro H, Ratsimbazafy J, Rasikindrahona E. New epidemiologic approach to intraocular pressure in an Antananarivo population. Nouvelle approche epidemiologique de la tension oculaire dans une population d’Antananarivo. J. Fr Ophtalmol. 2001;24(1):21-28. [pmid: 11240467]. Does not address any key questions
Beynat J, Charles A, Soulie M, Metral P, Creuzot-Garcher C, Bron AM. Combined glaucoma and diabetic retinopathy screening in Burgundy. Depistage itinerant du glaucome associe a celui de la retinopathie diabetique en Bourgogne. J Fr Ophtalmol. 2008;31(6 Pt 1):591-596. [pmid: 18772810]. Does not address any key questions
Bhatt N, Bhojwani R, Morrison A, Kwartz J, Laiquzzaman M, Shah SA. 10-year follow up of ocular hypertensive patients within the Bolton Corneal Thickness Study. Can measured factors predict prognostic outcomes?. Cont Lens Anterior Eye. 2008;31(3):147-53. [pmid: 18321766]. Does not address any key questions
Bjerre A, Henson DB, Grigg JR, Parry NRA. Test-Retest Variability of Multifocal Visual Evoked Potential and SITA Standard Perimetry. IOVS. 2003;44. ARVO E-abstract 28. Abstract only
Blumenthal EZ, Sample PA, Berry CC, Lee AC, Girkin CA, Zangwill L, Caprioli J, Weinreb RN. Evaluating several sources of variability for standard and SWAP visual fields in glaucoma patients, suspects, and normals. Ophthalmology. 2003;110(10):1895-902. [pmid: 14522760]. Does not address any key questions
Bobeico V, Zemba M, Bratulescu M, Ciuca C, Popescu M. Blue-yellow full threshold automated perimetry in glaucoma diagnosis. Oftalmologia. 2002;55(4):18-24. [pmid: 12723172]. Foreign language
Bodis-Wollner I, Brannan JR. Hidden visual loss in optic neuropathy is revealed using gabor patch contrast perimetry. CLIN NEUROSCI. 97; 4(5):284-291. Does not address any key questions
Boiko EV, Simakova IL, Kuz’micheva OV, Mechetin AA, Tselomudryi AI, Filina EV. High-technological screening for glaucoma. Voen Med Zh. 2010;331(2):23-6. [pmid: 20536045]. Foreign language
Bolla N, Savio E, Bellone A, Palanza L, Favero C, Brogliatti B. The Draeger autotonometer: its advantages and limits. Acta Ophthalmol Scand Suppl. 98(227):21-2. Does not address any key questions
Bonomi L, Marchini G, Marraffa M, Morbio R. The relationship between intraocular pressure and glaucoma in a defined population. Data from the Egna-Neumarkt Glaucoma Study. Ophthalmologica. 2001;215(1):34-8. [pmid: 11125267]. Other: not all subjects received exam for glaucoma
Bonomi L, Marchini G, Marraffa M, Bernardi P, De Franco I, Perfetti S, Varotto A, Tenna V. Prevalence of glaucoma and intraocular pressure distribution in a defined population. The Egna-Neumarkt Study. Ophthalmology. 98; 105(2):209-15. Does not address any key questions
Borges KF. Anblise com Heidelberg Retina Tomograph da espessura da camada de fibras nervosas retinianas e do volume de escavagåo papilar em zonas alfa e beta de atrofia para-papilar em pacientes glaucomatosos. Rev. Bras Oftalmol. 2000;59(3):204-8. Foreign language
Borges KF. Anblise esteriomqtrica do disco £ptico comHeildelberg Retina Tomograph (HRT) em pacientes com Glaucoma de Tensåo Normal (GNT). Rev. Bras Oftalmol. 1999;58(6):459-62. Foreign language
Borque E, Ferreras A, Polo V, Larrosa JM, Alias E, Honrubia FM. Evaluation of four new discriminant functions for HRT II in glaucoma diagnosis. Arch Soc Esp Oftalmol. 2008;83(6):349-56. [pmid: 18521767]. Foreign language
Borque E, Ferreras A, Polo V, Larrosa JM, Pablo LE, Honrubia FM. Diagnostic ability of GDx VCC for glaucoma diagnosis. Arch Soc Esp Oftalmol. 2008;83(6):357-64. [pmid: 18521768]. Foreign language
Borque E, Pueyo V, Polo V, Larrosa J, Ferreras A, Honrubia F. Diagnostic Ability of the Heidelberg Retina Tomograph, Optical Coherence Tomography and Laser Polarimetry to Detect Structural Damage in Glaucoma. IOVS. 2006;47. ARVO E-abstract 3626. Abstract only
Bosworth CF, Sample PA, Gupta N, Bathija R, Weinreb RN. Motion automated perimetry identifies early glaucomatous field defects. Arch Ophthalmol. 98; 116(9):1153-8. Non-commercially available analysis of data
Bourne RR, Medeiros FA, Bowd C, Jahanbakhsh K, Zangwill LM, Weinreb RN. Comparability of retinal nerve fiber layer thickness measurements of optical coherence tomography instruments. Invest Ophthalmol Vis Sci. 2005;46(4):1280-5. [pmid: 15790891]. Does not use clinical assessment as reference standard
Bowd C, Hao J, Tavares IM, Medeiros FA, Zangwill LM, Lee TW, Sample PA, Weinreb RN, Goldbaum MH. Bayesian machine learning classifiers for combining structural and functional measurements to classify healthy and glaucomatous eyes. Invest Ophthalmol Vis Sci. 2008;49(3):945-53. [pmid: 18326717]. Non-commercially available analysis of data
Bowd C, Medeiros FA, Zhang Z, Zangwill LM, Hao J, Lee TW, Sejnowski TJ, Weinreb RN, Goldbaum MH. Relevance vector machine and support vector machine classifier analysis of scanning laser polarimetry retinal nerve fiber layer measurements. Invest Ophthalmol Vis Sci. 2005;46(4):1322-9. [pmid: 15790898]. Does not use clinical assessment as reference standard
Bowd C, Vizzeri G, Tafreshi A, Zangwill LM, Sample PA, Weinreb RN. Diagnostic accuracy of pattern electroretinogram optimized for glaucoma detection. Ophthalmology. 2009;116(3):437-43. [pmid: 19167080]. Does not examine candidate screening tests for glaucoma
Bowd C, Weinreb RN, Williams JM, Zangwill LM. The retinal nerve fiber layer thickness in ocular hypertensive, normal, and glaucomatous eyes with optical coherence tomography. Arch Ophthalmol. 2000;118(1):22-6. [pmid: 10636409]. Does not address any key questions
Bowd C, Zangwill LM, Berry CC, Blumenthal EZ, Vasile C, Sanchez-Galeana C, Bosworth CF, Sample PA, Weinreb RN. Detecting early glaucoma by assessment of retinal nerve fiber layer thickness and visual function. Invest Ophthalmol Vis Sci. 2001;42(9):1993-2003. [pmid: 11481263]. Infrequently used device: GDX-OCT
Bowling B, Chen SD, Salmon JF. Outcomes of referrals by community optometrists to a hospital glaucoma service. Br J Ophthalmol. 2005;89(9):1102-4. [pmid: 16113358]. Does not address any key questions
Bozkurt B, Irkec M, Karaagaoglu E, Orhan M. Scanning laser polarimetric analysis of retinal nerve fiber layer thickness in Turkish patients with glaucoma and ocular hypertension. Eur J Ophthalmol. 2002;12(5):406-12. [pmid: 12474924]. Other (specify): outdated device
Bozkurt B, Ylmaz PT, Irkec M. Relationship between Humphrey 30-2 SITA standard test, matrix 30-2 threshold test, and Heidelberg Retina Tomograph in ocular hypertensive and glaucoma patients. J Glaucoma. 2008;17(3):203-210. [pmid: 18414106]. Does not address any key questions
Brogliatti B, Boles Carenini A, Bogetto C, Vadala G, Grignolo FM, Boles Carenini B. Ibopamine test in healthy and glaucomatous eyes: Tonometric and pupillographic study. Acta Ophthalmol. Scand. Suppl. 2000;78(232):13-14. [pmid: 11235513]. Does not address any key questions
Bron A, Baudouin C, Nordmann JP, Rouland JF, Thomas F, Bean K, De Clercq B, Benetos A, de Gendre AS, Lefebvre S. Prevalence of intraocular hypertension and glaucoma in a nonselected French population. J Fr Ophtalmol. 2006;29(6):635-41. [pmid: 16885893]. Foreign language
Brusini P, Salvetat ML, Parisi L, Zeppieri M. Probing glaucoma visual damage by rarebit perimetry. Br J Ophthalmol. 2005;89(2):180-4. [pmid: 15665349]. Testing in-house scoring system only
Brusini P, Salvetat ML, Zeppieri M, Parisi L. Frequency doubling technology perimetry with the Humphrey Matrix 30-2 test. J Glaucoma. 2006;15(2):77-83. [pmid: 16633218]. Non-commercially available analysis of data
Brusini P, Tosoni C, Parisi L, Rizzi L. Ocular hypertension and corneal thickness: a long-term prospective study. Results after two years. Eur J Ophthalmol. 2005;15(5):550-5. [pmid: 16167285]. Does not address any key questions
Brusini P, Zeppieri M, Tosoni C, Parisi L, Salvetat ML. Optic disc damage staging system. J Glaucoma. 2010;19(7):442-9. [pmid: 20051883]. Non-commercially available analysis of data
Brusini P, Zeppieri M, Tosoni C, Parisi L, Felletti M, Salvetat ML. Stratus-OCT imaging in early glaucomatous and in ocular hypertensive patients with and without frequency-doubling technology abnormalities. Eye (Lond). 2008;22(3):406-13. [pmid: 17304263]. Data not abstractable
Budenz DL, Anderson DR, Feuer WJ, Beiser JA, Schiffman J, Parrish RK 2nd, Piltz-Seymour JR, Gordon MO, Kass MA. Detection and prognostic significance of optic disc hemorrhages during the Ocular Hypertension Treatment Study. Ophthalmology. 2006;113(12):2137-43. [pmid: 16996592]. Does not address any key questions
Budenz DL, Michael A, Chang RT, McSoley J, Katz J. Sensitivity and specificity of the StratusOCT for perimetric glaucoma. Ophthalmology. 2005;112(1):3-9. [pmid: 15629813]. Data not abstractable
Buhrmann RR, Quigley HA, Barron Y, West SK, Oliva MS, Mmbaga BB. Prevalence of glaucoma in a rural East African population. Invest Ophthalmol Vis Sci. 2000;41(1):40-8. [pmid: 10634599]. Does not address any key questions
Buhrmann RR, Quigley HA, Barron Y, West SK, Oliva MS, Mmbaga BB. Prevalence of glaucoma in a rural East African population. Invest Ophthalmol Vis Sci. 2000;41(1):40-8. [pmid: 10634599]. Other (specify): prevalence
Burgansky-Eliash Z, Wollstein G, Chu T, Ramsey JD, Glymour C, Noecker RJ, Ishikawa H, Schuman JS. Optical coherence tomography machine learning classifiers for glaucoma detection: a preliminary study. Invest Ophthalmol Vis Sci. 2005;46(11):4147-52. [pmid: 16249492]. Non-commercially available analysis of data
Burk ROW, Konig J, Rohrschneider K, Noack H, Volcker HE. Three-dimensional optic disc topography by laser scanning tomography: Clinical correlation of a cluster analysis. DREIDIMENSIONALE PAPILLENTOPOGRAPHIE MITTELS LASER SCANNING TOMOGRAPHIE: KLINISCHES KORRELAT EINER CLUSTER-ANALYSE. KLIN. MONATSBL. AUGENHEILKD. 94; 204(6):504-512. Foreign language
Burk RO, Konig J, Rohrschneider K, Noack H, Volcker HE. 3-dimensional topography of the optic papilla with laser scanning tomography: clinical correlation of cluster analysis. Klin Monbl Augenheilkd. 94; 204(6):504-12. Foreign language
Burr JM, Campbell MK, Campbell SE, Francis JJ, Greene A, Hernandez R, Hopkins D, McCann SK, Vale LD. Developing the clinical components of a complex intervention for a glaucoma screening trial: a mixed methods study. BMC Med Res Methodol. 2011;11:54. [pmid: 21510850]. Data not abstractable
Byles DB, Sherafat H, Diamond JP. Frequency Doubling Technology screening test in glaucoma detection. IOVS. 2000;41. ARVO Abstract 452. Abstract only
Calixto N, Cronemberger S. Glaucoma simples x glaucoma agudo: estudo eco-biom qtrico. Arq. Bras. Oftalmol. 1986;49(1):1-8. Foreign language
Caprioli J, Coleman A. Pressure fluctuation. Ophthalmology. 2009;116(4):817. [pmid: 19344837]. No original data (e.g., systematic review, narrative review, editorial, letter)
Caprioli J, Coleman A. Pressure fluctuation. Ophthalmology. 2009;116(4):817. [pmid: 19344837]. Other (specify): this is a letter to the editor
Casson EJ, Johnson CA, Shapiro LR. Longitudinal comparison of temporal-modulation perimetry with white-on-white and blue-on-yellow perimetry in ocular hypertension and early glaucoma. J Opt Soc Am A Opt Image Sci Vis. 93; 10(8):1792-806. Does not address any key questions
Casson RJ, Newland HS, Muecke J, McGovern S, Abraham L, Shein WK, Selva D, Aung T. Prevalence of glaucoma in rural Myanmar: the Meiktila Eye Study. Br J Ophthalmol. 2007;91(6):710-4. [pmid: 17510475]. Does not address any key questions
Casson R, James B, Rubinstein A, Ali H. Clinical comparison of frequency doubling technology perimetry and Humphrey perimetry. Br J Ophthalmol. 2001;85(3):360-2. [pmid: 11222348]. Does not use clinical assessment as reference standard
Cellini M, Bernabini B, Carbonelli M, Zamparini E, Campos EC. Optical coherence tomography, frequency-doubling technology, and colour Doppler imaging in ocular hypertension. Eye (Lond). 2007;21(8):1071-7. [pmid: 16888642]. It does not address the adequate population
Ceruti P, Morbio R, Marraffa M, Marchini G. Comparison of Goldmann applanation tonometry and dynamic contour tonometry in healthy and glaucomatous eyes. Eye (Lond). 2009;23(2):262-9. [pmid: 18219335]. Data not abstractable
Chang YC, Tsai RK. Correlation between quadrant specific automatic visual field defect and retinal nerve fiber layer thickness as measured by scanning laser polarimetry in patients with primary open angle glaucoma. Kaohsiung J Med Sci. 2008;24(5):233-9. [pmid: 18508420]. Other (specify): GDX
Chauhan BC, House PH, McCormick TA, LeBlanc RP. Comparison of conventional and high-pass resolution perimetry in a prospective study of patients with glaucoma and healthy controls. Arch Ophthalmol. 99; 117(1):24-33. Does not examine candidate screening tests for glaucoma
Chen HY, Huang ML. Discrimination between normal and glaucomatous eyes using Stratus optical coherence tomography in Taiwan Chinese subjects. Graefes Arch Clin Exp Ophthalmol. 2005;243(9):894-902. [pmid: 15834602]. Does not use clinical assessment as reference standard
Chen HY, Huang ML, Hung PT. Logistic regression analysis for glaucoma diagnosis using Stratus Optical Coherence Tomography. Optom Vis Sci. 2006;83(7):527-34. [pmid: 16840878]. Non-commercially available analysis of data
Chen XM, Wu ZZ, Jiang YQ. Automatic perimetry in detecting early glaucomatous visual field defects. A follow-up study. Chin Med J (Engl). 92; 105(4):298-301. Does not address any key questions
Chen XM. Frequency distribution of earliest glaucomatous visual field defects. Zhonghua Yan Ke Za Zhi. 92; 28(4):206-8. Foreign language
Cheng Y-C, Duan X-C. Application of retinal nerve fiber layer thickness detected by HRT- II and OCT3 in early diagnosis of primary open angle glaucoma. Int. J. Ophthalmol. 2007;7(4):1022-1024. Foreign language
Chiselita D, Crenguta MI, Danielescu C, Mihaela NM. A comparative analysis of standard automated perimetry and short wavelength automated perimetry in early diagnosis of glaucoma. Oftalmologia. 2006;50(2):94-102. [pmid: 16927766]. Foreign language
Chiselita D, Danielescu C, Gagos-Zaharia O, Gherman C. Central thickness of the cornea in ocular hypertension and open-angle glaucoma. Oftalmologia. 2007;51(3):98-103. [pmid: 18064964]. Foreign language
Choplin NT, Lundy DC. The sensitivity and specificity of scanning laser polarimetry in the detection of glaucoma in a clinical setting. Ophthalmology. 2001;108(5):899-904. [pmid: 11320020]. Infrequently used device: outdated devices
Chopra V, Varma R, Francis BA, Wu J, Torres M, Azen SP. Type 2 diabetes mellitus and the risk of open-angle glaucoma the Los Angeles Latino Eye Study. Ophthalmology. 2008;115(2):227-232.e1. [pmid: 17716734]. Does not address any key questions
Christoffersen T, Holtedahl K, Fors T, Ringberg U. Tonometry in the general practice setting (II): Which cut-off point for referral--for which patients?. Acta Ophthalmol (Copenh). 93; 71(1):109-13. Does not address any key questions
Cioffi GA, Mansberger S, Spry P, Johnson C, Van Buskirk EM. Frequency doubling perimetry and the detection of eye disease in the community. Trans Am Ophthalmol Soc. 2000;98:195-9. discussion 199–202. [pmid: 11190023]. Other: not looking only at POAG
Clement CI, Goldberg I, Healey PR, Graham S. Humphrey matrix frequency doubling perimetry for detection of visual-field defects in open-angle glaucoma. Br J Ophthalmol. 2009;93(5):582-8. [pmid: 18669543]. Does not address any key questions
Coffey M, Reidy A, Wormald R, Xian WX, Wright L, Courtney P. Prevalence of glaucoma in the west of Ireland. BR. J. OPHTHALMOL. 93; 77(1):17-21. Does not address any key questions
Comegno PEC, Costa VP, Silva SARF, Kara-Josq N. Perimetria computadorizada em pacientes glaucomatosos com visåo sub-normal. Arq. Bras. Oftalmol. 1995;58(5):346-53. Foreign language
ComparagPo de mqtodos de imagem do disco £ptico e da camada de fibras nervosas da retina para o diagn £stico do glaucoma. SPo Paulo. s.n. 2005. Book Chapter
Congdon NG, Quigley HA, Hung PT, Wang TH, Ho TC, Glovinsky Y. Impact of age, various forms of cataract, and visual acuity on whole-field scotopic sensitivity screening for glaucoma in rural Taiwan. ARCH. OPHTHALMOL. 95; 113(9):1138-1143. Does not address any key questions
Cooper RL, Grose GC, Constable IJ. Mass screening of the optic disc for glaucoma: a follow-up study. Aust N Z J Ophthalmol. 86; 14(1):35-9. Does not address any key questions
Corallo G, Iester M, Scotto R, Calabria G, Traverso CE. Rarebit perimetry and frequency doubling technology in patients with ocular hypertension. Eur J Ophthalmol. 2008;18(2):205-11. [pmid: 18320512]. Infrequently used device
Correnti AJ, Wollstein G, Price LL, Schuman JS. Optic Nerve Head Assessment with Discam, Heidelberg Retina Tomography, and Stereoscopic Disc Photography. American Academy of Ophthalmology. 2002:253. Abstract only
Costa RMdS, Velasco TR, Costa LS, Rodrigues MdLV. Efic bcia da associagPo de mqtodos diagn£sticos no rastreamento do glaucoma. Arq. Bras. Oftalmol. 2004;67(1):37-41. Foreign language
Costa VP, Schimiti RB, Avelino R, Kara-Jose N. Full threshold vs sita in normal individuals undergoing automated perimetry for the first time. American Academy of Ophthalmology. 2001:148. Does not address any key questions
Costa VP, Schimiti RB, Avelino R, Kara-Jose N. Full threshold vs sita in normal individuals undergoing automated perimetry for the first time. American Academy of Ophthalmology. 2001:148. It does not address the adequate population
Costa VP, Medeiros FA, Sample PA, Weinreb RN. Frequency doubling technology perimetry abnormalities as predictors of glaucomatous visual field loss [2] (multple letters). Am. J. Ophthalmol. 2004;138(5):897-899. [pmid: 15531345]. No original data (e.g., systematic review, narrative review, editorial, letter)
Costagliola C, Russo V, Camera A, Scibelli G. The Takagi Automatic Tangent Screen ATS-85 analyzer for the detection of glaucomatous patients. Ann Ophthalmol. 91; 23(1):18-20. Does not examine candidate screening tests for glaucoma
Cubbidge RP, Hosking SL, Hilton EJ, Gibson JM. Regression analysis of ranked segment parameters for optic nerve head classification: a pilot study. Ophthalmic Physiol Opt. 2007;27(2):194-200. [pmid: 17324210]. Non-commercially available analysis of data
Cucevic V, Brooks AM, Strang NT, Klein AG, Nugent KA. Use of a confocal laser scanning ophthalmoscope to detect glaucomatous cupping of the optic disc. Aust N Z J Ophthalmol. 97; 25(3):217-20. Infrequently used device
Da Pozzo S, Fuser M, Vattovani O, Di Stefano G, Ravalico G. GDx-VCC performance in discriminating normal from glaucomatous eyes with early visual field loss. Graefes Arch Clin Exp Ophthalmol. 2006;244(6):689-95. [pmid: 16292656]. Does not use clinical assessment as reference standard
Daboue A, Meda ND, Ahnoux-Zabsonre A. Eye tension and open angle glaucoma in a Burkina Faso hospital. J Fr Ophtalmol. 2002;25(1):39-41. [pmid: 11965116]. Foreign language
Dadaci Z, Bozkurt B, Irkec MT, Orhan M, Arslan U. Relationship between short wavelength perimetry and central corneal thickness values in ocular hypertensive subjects. Eur J Ophthalmol. 2006;16(5):667-73. [pmid: 17061216]. Data not abstractable
Damato BE, Ahmed J, Allan D, McClure E, Jay JL. The detection of glaucomatous visual field defects by oculo-kinetic perimetry: which points are best for screening?. Eye (Lond). 89; 3(Pt 6):727-31. Does not address any key questions
Damms T, Dannheim F. Sensitivity and specificity of optic disc parameters in chronic glaucoma. Invest Ophthalmol Vis Sci. 93; 34(7):2246-50. Abstract only
de la Rosa MG, Gonzalez-Hernandez M, Lozano-Lopez V, Mendez MS, de la Vega RR. Optic disc tomography and perimetry in controls, glaucoma suspects, and early and established glaucomas. Optom Vis Sci. 2007;84(1):33-41. [pmid: 17220776]. Other (specify): data not comparable
de Natale R, Glaab-Schrems E, Krieglstein GK. The prognosis of glaucoma investigated with computerized perimetry. Doc Ophthalmol. 84; 58(4):385-92. Does not address any key questions
de Saint Sardos A, Kamdeu Fansi A, Chagnon M, Harasymowycz PJ. Intraocular pressure adjusted for central corneal thickness as a screening tool for open-angle glaucoma in an at-risk population. Can J Ophthalmol. 2009;44(5):571-5. [pmid: 19789594]. Data not abstractable
DeBry PW, Krishna R, Willoughby TL. Comparison of Intraocular Pressure Measurement by Dynamic Contour Tonometry and Goldmann Applanation Tonometry. IOVS. 2003. ARVO E-abstract 2185. Abstract only
Detry-Morel M, Jamart J, Detry MB, Ledoux A, Pourjavan S. Clinical evaluation of the Pascal dynamic contour tonometer. J Fr Ophtalmol. 2007;30(3):260-70. [pmid: 17417152]. Data not abstractable
Detry-Morel M, Zeyen T, Kestelyn P, Collignon J, Goethals M. Screening for glaucoma in a general population with the non-mydriatic fundus camera and the frequency doubling perimeter. Eur J Ophthalmol. 2004;14(5):387-93. [pmid: 15506600]. Data not abstractable
Devarajan N, Williams GS, Hopes M, O’Sullivan D, Jones D. The Carmarthenshire Glaucoma Referral Refinement Scheme, a safe and efficient screening service. Eye (Lond). 2011;25(1):43-9. [pmid: 20966973]. Data not abstractable
Dielemans I, Vingerling JR, Wolfs RC, Hofman A, Grobbee DE, de Jong PT. The prevalence of primary open-angle glaucoma in a population-based study in The Netherlands. The Rotterdam Study. Ophthalmology. 94; 101(11):1851-5. Does not address any key questions
Doshi A, Kreidl KO, Lombardi L, Sakamoto DK, Singh K. Nonprogressive glaucomatous cupping and visual field abnormalities in young Chinese males. Ophthalmology. 2007;114(3):472-9. [pmid: 17123617]. Does not address any key questions
Doyle CK, Brito CJ, Woodward KR, Johnson CA, Wall M. A Comparison of Catch Trial Methods Used in Conventional Perimetry in Glaucoma Patients. IOVS. 2007;48. ARVO E-Abstract 1627. Abstract only
Drum B, Armaly MF, Huppert W. Scotopic sensitivity loss in glaucoma. Arch Ophthalmol. 86; 104(5):712-7. Does not address any key questions
Dubay HB, Cyrlin MN, Rosenshein JS, Tressler CS. Comparison of Tendency Oriented Perimetry (TOP) Fast Strategy for Program 32 and the Glaucoma Programs (GI, G2) on the Octopus Perimeter Vs. the Humphrey Visual Field Analyzer Program 24-2 in Glaucoma Suspects and Glaucoma Patients. IOVS. 99; 40. ARVO Abstract 4432. Abstract only
Duggan C, Sommer A, Auer C, Burkhard K. Automated differential threshold perimetry for detecting glaucomatous visual field loss. Am J Ophthalmol. 85; 100(3):420-3. Uses single test to diagnose glaucoma
Durmus M, Karadag R, Erdurmus M, Totan Y, Feyzi Hepsen I. Assessment of cup-to-disc ratio with slit-lamp funduscopy, Heidelberg Retina Tomography II, and stereoscopic photos. Eur J Ophthalmol. 2009;19(1):55-60. [pmid: 19123149]. Does not address any key questions
Dzhumova MF, Birich TA. Study of changes in the central visual field in early computer-assisted diagnosis of primary open-angle glaucoma. Vestn Oftalmol. 94; 110(3):3-5. Foreign language
Eddy DM, Sanders LE, Eddy JF. The value of screening for glaucoma with tonometry. Surv Ophthalmol. 83; 28(3):194-205. Does not address any key questions
Eddy DM, Sanders LE, Eddy JF. The value of screening for glaucoma with tonometry. Surv Ophthalmol. 83; 28(3):194-205. No original data (e.g., systematic review, narrative review, editorial, letter)
Eichenbaum KD, Mezej M, Eichenbaum JW. Comparing dynamic contour tonometry to Goldmann and hand-held tonometry in normal, ocular hypertension, and glaucoma populations. Ann Ophthalmol (Skokie). 2007;39(1):41-9. [pmid: 17914204]. Does not address any key questions
Eikelboom RH, Cooper RL, Barry CJ. A study of variance in densitometry of retinal nerve fiber layer photographs in normals and glaucoma suspects. INVEST. OPHTHALMOL. VIS. SCI. 90; 31(11):2373-2383. Infrequently used device
Ekstrom C. Prevalence of open-angle glaucoma in central Sweden. The Tierp Glaucoma Survey. Acta Ophthalmol Scand. 96; 74(2):107-12. Does not address any key questions
Ellish NJ, Higginbotham EJ. Differences between screening sites in a glaucoma screening program. Ophthalmic Epidemiol. 2002;9(4):225-37. [pmid: 12187421]. Does not address any key questions
Erdurmus M, Yagci R. Dynamic contour tonometer versus goldmann applanation tonometer. J Glaucoma. 2006;15(5):471. [pmid: 16988614]. Does not address any key questions
Essock EA, Gunvant P, Zheng Y, Garway-Heath DF, Kotecha A, Spratt A. Predicting visual field loss in ocular hypertensive patients using wavelet-fourier analysis of GDx scanning laser polarimetry. Optom Vis Sci. 2007;84(5):380-7. [pmid: 17502818]. Does not address any key questions
Essock EA, Gunvant P, Zheng Y, Parikh RS, Prabakaran S, Babu JG, Kumar AU, Chandrashekar G, Thomas R. Comparison of Shape-Based Analysis of Retinal Nerve Fiber Layer Data Obtained From OCT and GDX-VCC. IOVS. 2006;47. ARVO E-abstract 3638. Abstract only
Essock EA, Zheng Y, Gunvant P. Analysis of GDx-VCC polarimetry data by Wavelet-Fourier analysis across glaucoma stages. Invest Ophthalmol Vis Sci. 2005;46(8):2838-47. [pmid: 16043858]. Non-commercially available analysis of data
Fabre K, Michiels I, Zeyen T. The sensitivity and specificity of TOP, FDP and GDX in screening for early glaucoma. Bull Soc Belge Ophtalmol. 2000;275:17-23. [pmid: 10853303]. Data not abstractable
Fankhauser F. Kinetic perimetry. Ophthalmologica. 69; 158(5):406-18. Foreign language
Fasolo LR, Mello PAdA, Prata JA J•nior. Novos m qtodos propedWuticos em glaucoma. Rev. Bras. Oftalmol. 2004;63(3):197-207. Foreign language
Ferreras A, Larrosa JM, Polo V, Pajarin AB, Mayoral F, Honrubia FM. Frequency-doubling technology: searching for the optimum diagnostic criteria for glaucoma. Acta Ophthalmol Scand. 2007;85(1):73-9. [pmid: 17244214]. Testing in-house scoring system only
Ferreras A, Pablo LE, Larrosa JM, Polo V, Pajarin AB, Honrubia FM. Discriminating between normal and glaucoma-damaged eyes with the Heidelberg Retina Tomograph 3. Ophthalmology. 2008;115(5):775-781.e2. [pmid: 17870171]. Non-commercially available analysis of data
Ferreras A, Pablo LE, Pajarin AB, Larrosa JM, Polo V, Honrubia FM. Logistic regression analysis for early glaucoma diagnosis using optical coherence tomography. Arch Ophthalmol. 2008;126(4):465-70. [pmid: 18413514]. Non-commercially available analysis of data
Fitoussi Y, Corbe C, Hamard H, Perdriel G. A glaucoma follow-up of 1500 persons over 20 years. J Fr Ophtalmol. 88; 11(2):151-4. Foreign language
FitzSimon JS, Hodge DO, Brubaker RF. Long-term outcome of patients who undergo tonometry as part of a general physical examination. Mayo Clin Proc. 98; 73(4):309-13. Does not address any key questions
Flad M, Paetzold J, Krapp E, Denk PO, Vonthein R, Schiefer U. Follow-up of Visual Field Defects with Fundus-oriented Perimetry (FOP) - a Comparative Pilot Study in Glaucoma Patients with and without Topical Brimonidine Therapy. IOVS. 2003. ARVO E-abstract 5224. Abstract only
Flammer J, Eppler E, Niesel P. Quantitative perimetry in the glaucoma patient without local visual field defects. Graefes Arch Clin Exp Ophthalmol. 82; 219(2):92-4. Foreign language
Fogagnolo P, Mazzolani F, Rossetti L, Orzalesi N. Detecting glaucoma with frequency-doubling technology perimetry: a comparison between N-30 and C-20 screening programs. J Glaucoma. 2005;14(6):485-91. [pmid: 16276282]. Does not use clinical assessment as reference standard
Fontana L, Armas R, Poinoosawmy D, Hitchings RA. P qrdida unilateral del campo visual en pacientes con glaucoma de tensi£n normal: seguimiento longitudinal. Arch. Chil. Oftalmol. 1998;55(1):39-43. Foreign language
Ford BA, Artes PH, McCormick TA, Nicolela MT, LeBlanc RP, Chauhan BC. Comparison of data analysis tools for detection of glaucoma with the Heidelberg Retina Tomograph. Ophthalmology. 2003;110(6):1145-50. [pmid: 12799239]. Data not abstractable
Fortune B, Demirel S, Zhang X, Hood DC, Patterson E, Jamil A, Mansberger SL, Cioffi GA, Johnson CA. Comparing multifocal VEP and standard automated perimetry in high-risk ocular hypertension and early glaucoma. Invest Ophthalmol Vis Sci. 2007;48(3):1173-80. [pmid: 17325161]. Infrequently used device: multifocal visual evoked potentials
Fortune B, Zhang X, Hood DC, Demirel S, Patterson E, Jamil A, Mansberger SL, Cioffi GA, Johnson CA. Effect of recording duration on the diagnostic performance of multifocal visual-evoked potentials in high-risk ocular hypertension and early glaucoma. J Glaucoma. 2008;17(3):175-82. [pmid: 18414101]. Does not address any key questions
Francis BA, Ying-Lai M, Winarko J, Nguyen B, Varma R. Los Angeles Latino Eye Study Group. Screening for Glaucomatous Optic Nerve Damage: The Los Angeles Latino Eye Study. IOVS. 2005;46. ARVO E-abstract 2499. Abstract only
Freitas TG, Freitas FVdJ. Sensibilidade e especificidade do per Æmetro de dupla freqnWncia. Arq. Bras. Oftalmol. 2003;66(4):423-6. Foreign language
Fristrom B. Colour contrast sensitivity in ocular hypertension. A five-year prospective study. Acta Ophthalmol Scand. 2002;80(2):155-62. [pmid: 11952481]. Does not address any key questions
Funaki S, Shirakashi M, Yaoeda K, Abe H, Kunimatsu S, Suzuki Y, Tomita G, Araie M, Yamada N, Uchida H, Yamamoto T, Kitazawa Y. Specificity and sensitivity of glaucoma detection in the Japanese population using scanning laser polarimetry. Br J Ophthalmol. 2002;86(1):70-4. [pmid: 11801507]. Infrequently used device
Gabriele ML, Wollstein G, Bilonick RA, Burgansky-Eliash Z, Ishikawa H, Kagemann LE, Schuman JS. Comparison of parameters from Heidelberg Retina Tomographs 2 and 3. Ophthalmology. 2008;115(4):673-7. [pmid: 17719642]. Does not address any key questions
Galvao Filho RP, Vessani RM, Susanna R Jr. Comparison of retinal nerve fibre layer thickness and visual field loss between different glaucoma groups. Br J Ophthalmol. 2005;89(8):1004-7. [pmid: 16024854]. Other: outdated device
Garas A, Vargha P, Hollo G. Diagnostic accuracy of nerve fibre layer, macular thickness and optic disc measurements made with the RTVue-100 optical coherence tomograph to detect glaucoma. Eye (Lond). 2011;25(1):57-65. [pmid: 20930859]. It does not address the adequate population
Garcia de Blas Gonzalez F, Barajas Gutierrez MA, Beneyto Martin P, Del Cura Gonzalez MI, Sanz Cuesta T, Vello Cuadrado R, Salvador Armendariz C. Usefulness of a glaucoma and ocular hypertension screening strategy in primary care. Aten Primaria. 2007;39(4):181-4. [pmid: 17428421]. Foreign language
Garcia De Blas Gonzalez F, Gutierrez MAB, Martin PB, Gonzalez MIDC, Cuesta TS, Cuadrado RV, Armendariz CS. Usefulness of a glaucoma and ocular hypertension screening strategy in primary care. Utilidad de una estrategia de cribado de hipertension ocular y glaucoma en atencion primaria. Aten. Prim. 2007;39(4):181-184. Foreign language
GarcÆa Arcaya JM. Comparaci£n de hallazgos por campimetrÆa de Humphrey, perimetrÆa de Goldmann y excavaci£n del disco £ptico en pacientes sospechosos de glaucoma primario de bngulo abierto. Rev. Oftalmol. Venez. 1992;48(1):75-88. Foreign language
Gardiner SK, Anderson DR, Fingeret M, McSoley JJ, Johnson CA. Evaluation of decision rules for frequency-doubling technology screening tests. Optom Vis Sci. 2006;83(7):432-7. [pmid: 16840859]. Testing in-house scoring system only
Garzozi H, Chung H, Lang Y, Kageman L, Harri A, Shields MB. IOP and PRK: A comparison of three different tonometers. Evid.-Based Eye Care. 2001;2(3):152-153. Does not address any key questions
Garzozi H, Chung H, Lang Y, Kageman L, Harri A, Shields MB. IOP and PRK: A comparison of three different tonometers. Evid.-Based Eye Care. 2001;2(3):152-153. It does not address the adequate population
Gege X, Lingling W. Application of Heidelberg retina tomography III in glaucoma with unilateral visual field defects. Chin. Ophthalmic Res. 2008;26(6):466-469. Foreign language
Georgopoulos GT, Halkiadakis I, Patsea E, Papakonstantinou D, Alexiou M, Vergados I, Andreanos D, Theodossiadis G, Moschos M. Study of patients with ocular hypertension with scanning laser polarimetry and short-wavelength automatic perimetry. Ophthalmologica. 2006;220(6):361-7. [pmid: 17095880]. Does not address any key questions
Giangiacomo A, Vimolchalao N, Fontana H, Hoffman DC, Caprioli J. Comparison of Frequency Doubling Perimetry (Humphrey Matrix) to Standard Achromatic Perimetry for Glaucoma Patients. IOVS. 2006;47. ARVO E-abstract 3990. Abstract only
Gil MartÆnez TM, Segovia RodrÆguez N, Vieira Navarro JC. Correlaci£n entre la perimetrÆa por tecnologÆa de doble frecuencia y funci£n de sensibilidad al contraste en glaucoma primario de bngulo abierto. Rev. Oftalmol. Venez. 2005;61(4):182-8. Foreign language
Giovannini A, Amato G, Mariotti C. The macular thickness and volume in glaucoma: an analysis in normal and glaucomatous eyes using OCT. Acta Ophthalmol Scand Suppl. 2002;236:34-6. [pmid: 12390129]. Does not address any key questions
Girkin CA, DeLeon-Ortega JE, Xie A, McGwin G, Arthur SN, Monheit BE. Comparison of the Moorfields classification using confocal scanning laser ophthalmoscopy and subjective optic disc classification in detecting glaucoma in blacks and whites. Ophthalmology. 2006;113(12):2144-9. [pmid: 16996609]. Does not use clinical assessment as reference standard
Girkin CA, McGwin G Jr, Long C, DeLeon-Ortega J, Graf CM, Everett AW. Subjective and objective optic nerve assessment in African Americans and whites. Invest Ophthalmol Vis Sci. 2004;45(7):2272-8. [pmid: 15223805]. Uses single test to diagnose glaucoma
Giuffre I. Frequency Doubling Technology vs Standard Automated Perimetry in Ocular Hypertensive Patients. Open Ophthalmol J. 2009;3:6-9. [pmid: 19554222]. Other (specify): not screening
Goldbaum MH, Sample PA, White H, Cote B, Raphaelian P, Fechtner RD, Weinreb RN. Interpretation of automated perimetry for glaucoma by neural network. INVEST. OPHTHALMOL. VIS. SCI. 94; 35(9):3362-3373. Non-commercially available analysis of data
Goni-Foncillas FJ, Guarro-Miralles M, Ondategui JC, Borras R, Peris E, Herrero R, Navarro A. SITA Standard vs Full-Threshold Perimetry: A Prospective Long-Term Comparison. American Academy of Ophthalmology. 2003:224. Abstract only
Gonzales de la Rosa M, Morales J, Dannheim F, Papst E, Papst N, Seiler TJ, Matsumoto C, Lachkar Y, Mermoud A, Prunte C. Multicenter evaluation of tendency-oriented perimetry (TOP) using the G1 grid. Eur J Ophthalmol. 2003;13(1):32-41. [pmid: 12635672]. Does not address any key questions
Gonzalez De La Rosa M, Pareja A. Influence of the ‘fatigue effect’ on the mean deviation measurement in perimetry. EUR. J. OPHTHALMOL. 97; 7(1):29-34. Does not address any key questions
Gonzalez Viejo I, Pablo LE, Pueyo M, Sanchez A, Bueno J, Melcon B, Honrubia FM. Assessment of retinal nerve fibre layer in early glaucoma diagnosis. ANN. OPHTHALMOL. GLAUCOMA. 97; 29(2):122-127. Does not address any key questions
Gonzalez-de-la-Rosa M, Gonzalez-Hernandez M, Aguilar-Estevez J, Diaz-Aleman T, Armas-Plasencia R. Diagnostic capability of PULSAR, FDT y HRT-II in glaucoma suspects. Arch Soc Esp Oftalmol. 2007;82(7):413-22. [pmid: 17647116]. Foreign language
Gottlieb LK, Schwartz B, Pauker SG. Glaucoma screening. A cost-effectiveness analysis. Surv Ophthalmol. 83; 28(3):206-26. Does not address any key questions
Greenfield DS, Knighton RW, Feuer WJ, Schiffman JC, Zangwill L, Weinreb RN. Correction for corneal polarization axis improves the discriminating power of scanning laser polarimetry. Am J Ophthalmol. 2002;134(1):27-33. [pmid: 12095804]. Non-commercially available analysis of data
Greve M, Chisholm IA. Comparison of the oculokinetic perimetry glaucoma screener with two types of visual field analyser. Can J Ophthalmol. 93; 28(5):201-6. Does not address any key questions
Grewal DS, Sehi M, Greenfield DS. Diffuse glaucomatous structural and functional damage in the hemifield without significant pattern loss. Arch Ophthalmol. 2009;127(11):1442-8. [pmid: 19901209]. Does not address any key questions
Grodum K, Heijl A, Bengtsson B. A comparison of glaucoma patients identified through mass screening and in routine clinical practice. Acta Ophthalmol Scand. 2002;80(6):627-31. [pmid: 12485284]. Does not address any key questions
Grodum K, Heijl A, Bengtsson B. Glaucoma and mortality. Graefes Arch Clin Exp Ophthalmol. 2004;242(5):397-401. [pmid: 15029499]. Does not address any key questions
Grolman B, Myers KJ, Lalle P. How reliable is the Goldmann tonometer as a standard?. J Am Optom Assoc. 90; 61(11):857-862. Does not address any key questions
Guedes RA, Guedes VM, Chaoubah A. Focusing on patients at high-risk for glaucoma in Brazil: a pilot study. J Fr Ophtalmol. 2009;32(9):640-5. [pmid: 19854538]. Foreign language
Guedes V, Schuman JS, Hertzmark E, Wollstein G, Correnti A, Mancini R, Lederer D, Voskanian S, Velazquez L, Pakter HM, Pedut-Kloizman T, Fujimoto JG, Mattox C. Optical coherence tomography measurement of macular and nerve fiber layer thickness in normal and glaucomatous human eyes. Ophthalmology. 2003;110(1):177-89. [pmid: 12511364]. Does not address any key questions
Guedes Viviane, Schuman Joel S, Pakter Helena M, Guedes Jaime, Susanna Remo Junior. OCT em glaucoma. Rev. bras. oftalmol. 2001;60(2):152-156. Foreign language
Gulati V, Agarwal HC, Sihota R, Saxena R. Correlation analysis of visual field thresholds and scanning laser ophthalmoscopic optic nerve head measurements in glaucoma. Ophthalmic Physiol. Opt. 2003;23(3):233-242. [pmid: 12753479]. Does not address any key questions
Gulati V, Sihota R, Agarwal H, Saxena R, Sharma A. COMPARATIVE EVALUATION OF ACHROMATIC PERIMETRY AND FREQUENCY DOUBLING TECHNOLOGY AND CORRELATION WITH SCANNING LASER POLARIMETRY. American Academy of Optometry. 2001:128. Abstract only
Gundersen KG, Heijl A, Bengtsson B. Sensitivity and specificity of structural optic disc parameters in chronic glaucoma. Acta Ophthalmol Scand. 96; 74(2):120-5. Does not examine candidate screening tests for glaucoma
Gunvant P, Zheng Y, Essock EA, Parikh RS, Prabakaran S, Babu JG, Shekar CG, Thomas R. Comparison of shape-based analysis of retinal nerve fiber layer data obtained From OCT and GDx-VCC. J Glaucoma. 2009;18(6):464-71. [pmid: 19680055]. Does not use clinical assessment as reference standard
Gunvant P, Zheng Y, Essock EA, Parikh RS, Prabakaran S, Babu JG, Shekar GC, Thomas R. Application of shape-based analysis methods to OCT retinal nerve fiber layer data in glaucoma. J Glaucoma. 2007;16(6):543-8. [pmid: 17873716]. Does not use clinical assessment as reference standard
Gyatsho J, Kaushik S, Gupta A, Pandav SS, Ram J. Retinal nerve fiber layer thickness in normal, ocular hypertensive, and glaucomatous Indian eyes: an optical coherence tomography study. J Glaucoma. 2008;17(2):122-7. [pmid: 18344758]. Does not address any key questions
Hager A, Wiegand W. Methods of measuring intraocular pressure independently of central corneal thickness. Ophthalmologe. 2008;105(9):840-4. [pmid: 18438633]. Does not address any key questions
Halkiadakis I, Kipioti A, Emfietzoglou I, Grigoropoulos V, Katsis A, Alimisi S, Vergados I, Theodossiadis P, Theodossiadis GP. Comparison of optical coherence tomography and scanning laser polarimetry in glaucoma, ocular hypertension, and suspected glaucoma. Ophthalmic Surg Lasers Imaging. 2008;39(2):125-32. [pmid: 18435336]. Does not address any key questions
Hancock S, Wild JM, Cunliffe IA. THE BETWEEN-VISIT REPRODUCIBILITY OF WHITE-ON-WHITE AUTOMATED PERIMETRY, SHORT WAVELENGTH AUTOMATED PERIMETRY AND FREQUENCY DOUBLING PERIMETRY. IOVS. 98:39. ARVO Abstract 112. Abstract only
Harasymowycz PJ, Papamatheakis DG, Fansi AK, Gresset J, Lesk MR. Validity of screening for glaucomatous optic nerve damage using confocal scanning laser ophthalmoscopy (Heidelberg Retina Tomograph II) in high-risk populations: a pilot study. Ophthalmology. 2005;112(12):2164-71. [pmid: 16325710]. Other: not screening
Harizman N, Oliveira C, Chiang A, Tello C, Marmor M, Ritch R, Liebmann JM. The ISNT rule and differentiation of normal from glaucomatous eyes. Arch Ophthalmol. 2006;124(11):1579-83. [pmid: 17102005]. Data not abstractable
Harizman N, Zelefsky JR, Ilitchev E, Tello C, Ritch R, Liebmann JM. Detection of glaucoma using operator-dependent versus operator-independent classification in the Heidelberg retinal tomograph-III. Br J Ophthalmol. 2006;90(11):1390-2. [pmid: 16870651]. Does not address any key questions
Harper R, Reeves B. The sensitivity and specificity of direct ophthalmoscopic optic disc assessment in screening for glaucoma: A multivariate analysis. Graefe’s Arch. Clin. Exp. Ophthalmol. 2000;238(12):949-955. Does not use clinical assessment as reference standard
Hart WM Jr, Becker B. The onset and evolution of glaucomatous visual field defects. Ophthalmology. 82; 89(3):268-79. Does not address any key questions
Hatch WV, Flanagan JG, Etchells EE, Williams-Lyn DE, Trope GE. Laser scanning tomography of the optic nerve head in ocular hypertension and glaucoma. Br J Ophthalmol. 97; 81(10):871-6. Does not address any key questions
Hawker MJ, Edmunds MR, Vernon SA, Hillman JG, MacNab HK. The relationship between central corneal thickness and the optic disc in an elderly population: the Bridlington Eye Assessment Project. Eye (Lond). 2009;23(1):56-62. [pmid: 17948039]. Does not address any key questions
Hawker MJ, Vernon SA, Ainsworth G. Specificity of the Heidelberg Retina Tomograph’s diagnostic algorithms in a normal elderly population: the Bridlington Eye Assessment Project. Ophthalmology. 2006;113(5):778-85. [pmid: 16650673]. Data not abstractable
Hawker MJ, Vernon SA, Tattersall CL, Dua HS. Detecting glaucoma with RADAAR: the Bridlington Eye Assessment Project. Br J Ophthalmol. 2006;90(6):744-8. [pmid: 16714266]. Other: radaar
Hayakawa S, Hamajima N, Yamamoto T, Kitazawa Y. Analysis of therapeutic prognosis of primary open-angle glaucoma by the proportional hazards model and the life-table method. Nippon Ganka Gakkai Zasshi. 94; 98(4):379-84. Foreign language
Haymes SA, Artes PH, Hutchison DM, McCormick TA, Varma DK, Nicolela MT, LeBlanc RP, Chauhan BC. Comparison of Frequency Doubling Technology and Standard Automated Perimetry for Detecting Glaucomatous Visual Field Progression. A Longitudinal Prospective Study. IOVS. 2004;45. ARVO E-abstract 3472. Abstract only
Heeg GP, Jansonius NM. Influence of test reliability on the screening performance of frequency-doubling perimetry. Am J Ophthalmol. 2006;141(3):585-7. [pmid: 16490521]. Data not abstractable
Heeg GP, Jansonius NM. The groningen longitudinal glaucoma study. III. The predictive value of frequency-doubling perimetry and GDx nerve fibre analyser test results for the development of glaucomatous visual field loss. Eye (Lond). 2009;23(8):1647-52. [pmid: 19011607]. Other (specify): GDX alone
Heeg GP, Blanksma LJ, Hardus PL, Jansonius NM. The Groningen Longitudinal Glaucoma Study. I. Baseline sensitivity and specificity of the frequency doubling perimeter and the GDx nerve fibre analyser. Acta Ophthalmol Scand. 2005;83(1):46-52. [pmid: 15715556]. Other (specify): GDX
Heijl A, Drance SM. A clinical comparison of three computerized automatic perimeters in the detection of glaucoma defects. Archives of Ophthalmology. 81; 99(5):832-6. Does not address any key questions
Heijl A, Drance SM. A clinical comparison of three computerized automatic perimeters in the detection of glaucoma defects. Archives of Ophthalmology. 81; 99(5):832-6. Does not examine candidate screening tests for glaucoma
Heijl A, Lundqvist L. The frequency distribution of earliest glaucomatous visual field defects documented by automatic perimetry. Acta Ophthalmol (Copenh). 84; 62(4):658-64. Does not address any key questions
Heijl A. Perimetric point density and detection of glaucomatous visual field loss. Acta Ophthalmol (Copenh). 93; 71(4):445-50. Does not address any key questions
Heijl A. Perimetric point density and detection of glaucomatous visual field loss. Acta Ophthalmol (Copenh). 93; 71(4):445-50. It does not address the adequate population
Henderson PA, Medeiros FA, Zangwill LM, Weinreb RN. Relationship between central corneal thickness and retinal nerve fiber layer thickness in ocular hypertensive patients. Ophthalmology. 2005;112(2):251-6. [pmid: 15691559]. Data not abstractable
Henson DB, Spencer AF, Harper R, Cadman EJ. Community refinement of glaucoma referrals (Brief Record). Eye. 2003;17(1):21-26. [pmid: 12579165]. Does not address any key questions
Herba E Pojda SM Zatorska B Pojda-Wilczek D Makowiecka-Obidzinska K Short wavelength perimetry--the significance in diagnosis of glaucoma in myopic patients Klin Oczna 20041061–2 Suppl 225 7 15510507 Foreign language
Hitzl W, Bunce C, Reitsamer HA, Grabner G, Hornykewycz K. The projected increase in glaucoma due to the aging population in Austria from 2001 to 2031: results based on data of the Salzburg-Moorfields Collaborative Glaucoma Study. Eur J Ophthalmol. 2007;17(1):45-52. [pmid: 17294382]. Does not address any key questions
Hitzl W, Hornykewycz K, Grabner C, Reitsamer HA. On the relationship between age and prevalence and/or incidence of primary open-angle glaucoma in the “Salzburg-Moorfields Collaborative Glaucoma Study”. Uber den zusammenhang zwischen lebensalter und pravalenz sowie inzidenz des primaren offenwinkelglaukoms in der “Salzburg-Moorfields- Collaborative-Glaucoma”-Studie. Klin. Monatsbl. Augenheilkd. 2007;224(2):115-119. [pmid: 17309007]. Duplicate
Hitzl W, Hornykewycz K, Grabner G, Reitsamer HA. On the relationship between age and prevalence and/or incidence of primary open-angle glaucoma in the “Salzburg-Moorfields Collaborative Glaucoma Study”. Klin Monbl Augenheilkd. 2007;224(2):115-9. [pmid: 17309007]. Foreign language
Hitzl W, Hornykewycz K, Grabner G, Reitsamer HA. The ‘cup-to-disc ratio’: a comparison of TopSS, HRT II and subjective findings. Klin Monbl Augenheilkd. 2007;224(5):391-5. [pmid: 17516367]. Foreign language
Hitzl W, Ortner C, Hornykewycz K, Grabner G, Reitsamer HA. Resource use and costs for a glaucoma screening program in Austria: an 8-year review: a cost-consequence analysis based on the Salzburg-Moorfields Collaborative Glaucoma Study. Eur J Ophthalmol. 2006;16(1):92-9. [pmid: 16496251]. Does not address any key questions
Hoffmann EM, Bowd C, Klein N, Stemberger K, Grus FH, Pfeiffer N. Glaucoma detection using the GDx nerve fiber analyzer and the retinal thickness analyzer (RTA). Eur J Ophthalmol. 2006;16(2):251-8. [pmid: 16703543]. Other (specify): GDX
Hoh ST, Greenfield DS, Mistlberger A, Liebmann JM, Ishikawa H, Ritch R. Optical coherence tomography and scanning laser polarimetry in normal, ocular hypertensive, and glaucomatous eyes. Am J Ophthalmol. 2000;129(2):129-35. [pmid: 10682963]. Does not address any key questions
Hoh ST. Preperimetry diagnosis of glaucoma. Asian J. Ophthalmol. 2005;7(2):44. Does not address any key questions
Hollo G, Follmann P, Pap G. A clinical evaluation of XPERT NCT (Reichert) for glaucoma screening by optometrists. Int Ophthalmol. 92; 16(4–5):291-3. Does not address any key questions
Hong S, Moon JW, Ha SJ, Kim CY, Seong GJ, Hong YJ. Evaluation of a new scoring system for retinal nerve fiber layer photography using HRA1 in 964 eyes. Korean J Ophthalmol. 2007;21(4):216-21. [pmid: 18063886]. Data not abstractable
Hood DC, Harizman N, Kanadani FN, Grippo TM, Baharestani S, Greenstein VC, Liebmann JM, Ritch R. Retinal nerve fibre thickness measured with optical coherence tomography accurately detects confirmed glaucomatous damage. Br J Ophthalmol. 2007;91(7):905-7. [pmid: 17301118]. Testing in-house scoring system only
Hood DC, Raza AS, Kay KY, Sandler SF, Xin D, Ritch R, Liebmann JM. A comparison of retinal nerve fiber layer (RNFL) thickness obtained with frequency and time domain optical coherence tomography (OCT). Opt Express. 2009;17(5):3997-4003. [pmid: 19259241]. Does not address any key questions
Hood DC, Raza AS, Kay KY, Sandler SF, Xin D, Ritch R, Liebmann JM. A comparison of retinal nerve fiber layer (RNFL) thickness obtained with frequency and time domain optical coherence tomography (OCT). Opt Express. 2009;17(5):3997-4003. [pmid: 19259241]. Other (specify):
Horn FK, Brenning A, Junemann AG, Lausen B. Glaucoma detection with frequency doubling perimetry and short-wavelength perimetry. J Glaucoma. 2007;16(4):363-371. [pmid: 17570999]. Non-commercially available analysis of data
Horn FK, Jonas JB, Korth M, Junemann A, Grundler A. The full-field flicker test in early diagnosis of chronic open-angle glaucoma. Am J Ophthalmol. 97; 123(3):313-9. Data not abstractable
Horn FK, Mardin CY, Bendschneider D, Junemann AG, Adler W, Tornow RP. Frequency doubling technique perimetry and spectral domain optical coherence tomography in patients with early glaucoma. Eye (Lond). 2010. Non-commercially available analysis of data
Horn FK, Mardin CY, Laemmer R, Baleanu D, Juenemann AM, Kruse FE, Tornow RP. Correlation between local glaucomatous visual field defects and loss of nerve fiber layer thickness measured with polarimetry and spectral domain OCT. Invest. Ophthalmol. Vis. Sci. 2009;50(5):1971-1977. [pmid: 19151389]. Does not address any key questions
Horn FK, Nguyen NX, Mardin CY, Junemann AG. Combined use of frequency doubling perimetry and polarimetric measurements of retinal nerve fiber layer in glaucoma detection. Am J Ophthalmol. 2003;135(2):160-8. [pmid: 12566019]. Does not address any key questions
Horn FK, Velten IM, Junemann A, Korth M. The full-field flicker test in glaucomas: Influence of intraocular pressure and pattern of visual field losses. Graefe’s Arch. Clin. Exp. Ophthalmol. 99; 237(8):621-628. Does not address any key questions
Horn FK, Wakili N, Junemann AM, Korth M. Testing for glaucoma with frequency-doubling perimetry in normals, ocular hypertensives, and glaucoma patients. Graefes Arch Clin Exp Ophthalmol. 2002;240(8):658-65. [pmid: 12192460]. Data not abstractable
Horowitz J, Fishelzon-Arev T, Rath EZ, Segev E, Geyer O. Comparison of optic nerve head topography findings in eyes with non-arteritic anterior ischemic optic neuropathy and eyes with glaucoma. Graefes Arch Clin Exp Ophthalmol. 2010;248(6):845-51. [pmid: 20213479]. Does not address any key questions
Hotchkiss ML, Robin AL, Quigley HA, Pollack IP. A comparison of Peritest automated perimetry and Goldmann perimetry. Arch Ophthalmol. 85; 103(3):397-403. Infrequently used device: peritest
Hougaard JL, Bengtsson B, Ostenfeld C, Heijl A. Comparison of Retinal Nerve Fiber Layer Thickness Measurements Using Different Stratus-OCT Scan Protocols in Patients With Early Glaucoma. IOVS. 2005;46. ARVO E-abstract 4817. Abstract only
Hovding G, Aasved H. Prognostic factors in the development of manifest open angle glaucoma. A long-term follow-up study of hypertensive and normotensive eyes. Acta Ophthalmol (Copenh). 86; 64(6):601-8. Does not address any key questions
Hu CN. An epidemiologic study of glaucoma in Shunyi County, Beijing. Zhonghua Yan Ke Za Zhi. 89; 25(2):115-9. Foreign language
Huang A, Smith S, Quigley H. A COMPARISON OF THE DICON SCREENING FIELD WITH THE HUMPHREY THRESHOLD FIELD IN DETECTING GLAUCOMA. IOVS. 96:37. ARVO Abstract 2324. Abstract only
Huang ML, Chen HY. Development and comparison of automated classifiers for glaucoma diagnosis using Stratus optical coherence tomography. Invest Ophthalmol Vis Sci. 2005;46(11):4121-9. [pmid: 16249489]. Non-commercially available analysis of data
Hufnagl C, Hitzl W, Hornykewycz K, Grabner G, Reitsamer HA. Comparison of central corneal thickness in patients participating in a glaucoma screening programme and those who were examined in the glaucoma unit. Klin Monbl Augenheilkd. 2008;225(2):151-4. [pmid: 18293267]. Does not address any key questions
Hyman L, Wu S-Y, Connell AMS, Schachat A, Nemesure B, Hennis A, Leske M, Cristina. Prevalence and causes of visual impairment in the Barbados Eye Study. Ophthalmology. 2001;108(10):1751-1756. [pmid: 11581045]. Does not examine candidate screening tests for glaucoma
Ianchulev T, Pham P, Makarov V, Francis B, Minckler D. Peristat: a computer-based perimetry self-test for cost-effective population screening of glaucoma. Curr Eye Res. 2005;30(1):1-6. [pmid: 15875358]. Does not address any key questions
Ieong A, Murdoch I, Cousens S, Healey P, Theodossiades J. Sensitivity and specificity of two glaucoma case-finding strategies for optometrists. Ophthalmic Physiol Opt. 2003;23(4):341-6. [pmid: 12828624]. Testing in-house scoring system only
Ieong A, Theodossiades J, Healey P, Murcoch I. A comparison of glaucoma case detection methods. IOVS. 2001;42. ARVO Abstract 828. Abstract only
Iester M, Altieri M, Capris P, Zingirian M, Traverso CE. Comparison between relative dispersion analysis of high-pass resolution perimetry and standard threshold perimetry. Eye (Lond). 2000;14(Pt 5):742-6. [pmid: 11116696]. Does not address any key questions
Iester M, Altieri M, Vittone P, Calabria G, Zingirian M, Traverso CE. Detection of glaucomatous visual field defect by nonconventional perimetry. Am J Ophthalmol. 2003;135(1):35-9. [pmid: 12504694]. Does not address any key questions
Iester M, Broadway DC, Mikelberg FS, Drance SM. A comparison of healthy, ocular hypertensive, and glaucomatous optic disc topographic parameters. J Glaucoma. 97; 6(6):363-70. Does not address any key questions
Iester M, Courtright P, Mikelberg FS. Retinal nerve fiber layer height in high-tension glaucoma and healthy eyes. J Glaucoma. 98; 7(1):1-7. Does not address any key questions
Iester M, De Ferrari R, Zanini M. Topographic analysis to discriminate glaucomatous from normal optic nerve heads with a confocal scanning laser: new optic disk analysis without any observer input. Surv Ophthalmol. 99; 44(Suppl 1):S33-40. Non-commercially available analysis of data
Iester M, Jonas JB, Mardin CY, Budde WM. Discriminant analysis models for early detection of glaucomatous optic disc changes. Br. J. Ophthalmol. 2000;84(5):464-468. [pmid: 10781508]. Does not use clinical assessment as reference standard
Iester M, Mariotti V, Lanza F, Calabria G. The effect of contour line position on optic nerve head analysis by Heidelberg Retina Tomograph. Eur J Ophthalmol. 2009;19(6):942-8. [pmid: 19882584]. Does not address any key questions
Iester M, Mennoud A, Schnyder C. Frequency doubling technology and Octopus visual field. Acta ophthalmologica Scandinavica. Supplement. 2000(232):23-4. Does not address any key questions
Iester M, Mikelberg FS, Drance SM. The effect of optic disc size on diagnostic precision with the Heidelberg retina tomograph. Ophthalmology. 97; 104(3):545-8. Other (specify): outdated
Iester M, Mikelberg FS, Drance SM. The effect of optic disc size on diagnostic precision with the Heidelberg retina tomograph. Ophthalmology. 97; 104(3):545-8. Other (specify): Outdated device
Iester M, Mikelberg FS, Courtright P, Drance SM. Correlation between the visual field indices and Heidelberg retina tomograph parameters. J Glaucoma. 97; 6(2):78-82. Does not address any key questions
Iester M, Mikelberg FS, Swindale NV, Drance SM. ROC analysis of Heidelberg Retina Tomograph optic disc shape measures in glaucoma. Can J Ophthalmol. 97; 32(6):382-8. Infrequently used device: HRT1
Iester M, Perdicchi A, Capris E, Siniscalco A, Calabria G, Recupero SM. Comparison between discriminant analysis models and “glaucoma probability score” for the detection of glaucomatous optic nerve head changes. J Glaucoma. 2008;17(7):535-40. [pmid: 18854729]. Does not use clinical assessment as reference standard
Iester M, Swindale NV, Mikelberg FS. Sector-based analysis of optic nerve head shape parameters and visual field indices in healthy and glaucomatous eyes. J Glaucoma. 97; 6(6):370-6. Does not address any key questions
Iester M, Traverso CE, Capris P, Vittone P, Zingirian M. Different value scales between frequency-doubling technique and standard threshold perimetry. Acta Ophthalmol. Scand. Suppl. 2000;78(232):26-27. [pmid: 11235519]. Does not address any key questions
Iester M, Traverso CE, De Feo F, Sanna G, Altieri M, Vittone P, Calabria G. Correlation between frequency doubling technology and heidelberg retina tomograph. J Glaucoma. 2005;14(5):368-74. [pmid: 16148585]. Data not abstractable
Iester M, Zanini M, Vittone P, Calabria G. Detection of glaucomatous optic nerve head by using Heidelberg topographic maps. Eye (Lond). 2007;21(5):609-13. [pmid: 16485014]. Does not use clinical assessment as reference standard
Ikeji FC, White ET, Shewry JM, Schlottmann PG, Garway-Heath DF. Comparison of the Test-Retest Variability of Neuroretinal Rim Area Measurements in Normal and Glaucoma Patients Using HRT II and OCT3. IOVS. 2005;46. ARVO E-abstract 4820. Abstract only
Ito A, Kawabata H, Fujimoto N, Adachi-Usami E. Effect of myopia on frequency-doubling perimetry. Investigative ophthalmology & visual science. 2001;42(5):1107-10. [pmid: 11274092]. Does not address any key questions
Ivers RQ, Optom B, Macaskill P, Cumming RG, Mitchell P. Sensitivity and specificity of tests to detect eye disease in an older population. Ophthalmology. 2001;108(5):968-75. [pmid: 11320029]. Other: not all subjects received exam for glaucoma
Iwase A, Kitazawa Y, Ohno Y, Ansari I, Chauhan B. COMPARISON OF THE THRESHOLD VALUE OF SITA WITH THAT OF CONVENTIONAL PERIMETRY BY HUMPHREY FIELD ANALYZER IN GLAUCOMA PATIENTS. IOVS. 2000;41. ARVO Abstract 466. Abstract only
Iwase A, Suzuki Y, Araie M, Yamamoto T, Abe H, Shirato S, Kuwayama Y, Mishima HK, Shimizu H, Tomita G, Inoue Y, Kitazawa Y. The prevalence of primary open-angle glaucoma in Japanese: the Tajimi Study. Ophthalmology. 2004;111(9):1641-8. [pmid: 15350316]. Does not address any key questions
Iwase A, Tomidokoro A, Araie M, Shirato S, Shimizu H, Kitazawa Y. Performance of frequency-doubling technology perimetry in a population-based prevalence survey of glaucoma: the Tajimi study. Ophthalmology. 2007;114(1):27-32. [pmid: 17070580]. Does not use clinical assessment as reference standard
Jacob A, Thomas R, Koshi SP, Braganza A, Muliyil J. Prevalence of primary glaucoma in an urban south Indian population. Indian J Ophthalmol. 98; 46(2):81-6. Does not address any key questions
Jacob A, Thomas R, Koshi SP, Braganza A, Muliyil J. Prevalence of primary glaucoma in an urban south Indian population. Indian J Ophthalmol. 98; 46(2):81-6. Other (specify): Prevelance study
James AC, Kolic M, Bedford SM, Maddess T. Stimulus Parameters for Multifocal Pupillographic Objective Perimetry. J Glaucoma. 2011. Does not address any key questions
Januleviciene I, Sliesoraityte I, Siesky B, Harris A. Diagnostic compatibility of structural and haemodynamic parameters in open-angle glaucoma patients. Acta Ophthalmol. 2008;86(5):552-7. [pmid: 18081900]. Does not address any key questions
Jarade EF, Abi Nader FC, Tabbara KF. Intraocular pressure measurement after hyperopic and myopic LASIK. J Refract Surg. 2005;21(4):408-10. [pmid: 16128344]. Does not address any key questions
Jenchitr W, Pongprayoon C, Sothornwit N, Choosri P, Yenjitr C, Tapunya M. Eye health of priests and novices in rural area. J Med Assoc Thai. 2008;91(Suppl 1):S73-80. [pmid: 18672597]. Does not address any key questions
Jenchitr W, Pongprayoon C, Sothornwit N, Choosri P, Yenjitr C, Tapunya M. Eye health of priests and novices in rural area. J Med Assoc Thai. 2008;91(Suppl 1):S73-80. [pmid: 18672597]. Other (specify): More of a prevalence study and complete exam
Jensen JE. Glaucoma screening a 16-year follow-up of ocular normotensives. Acta Ophthalmol (Copenh). 84; 62(2):203-9. Does not address any key questions
Jeoung JW, Park KH, Kim TW, Khwarg SI, Kim DM. Diagnostic ability of optical coherence tomography with a normative database to detect localized retinal nerve fiber layer defects. Ophthalmology. 2005;112(12):2157-63. [pmid: 16290196]. Does not address any key questions
Joffe KM, Raymond JE, Chrichton A. Motion coherence perimetry in glaucoma and suspected glaucoma. Vision Res. 97; 37(7):955-64. Does not address any key questions
Johannesson G, Hallberg P, Eklund A, Linden C. Pascal, ICare and Goldmann applanation tonometry--a comparative study. Acta Ophthalmol. 2008;86(6):614-21. [pmid: 18093261]. Does not address any key questions
Johnson CA, Adams AJ, Casson EJ, Brandt JD. Blue-on-yellow perimetry can predict the development of glaucomatous visual field loss. Arch Ophthalmol. 93; 111(5):645-50. Does not address any key questions
Johnson CA, Adams AJ, Casson EJ, Brandt JD. Progression of early glaucomatous visual field loss as detected by blue-on-yellow and standard white-on-white automated perimetry. Arch Ophthalmol. 93; 111(5):651-6. Does not address any key questions
Johnson CA, Cioffi GA, Van Buskirk EM. Frequency doubling technology perimetry using a 24--2 stimulus presentation pattern. Optom Vis Sci. 99; 76(8):571-81. Does not address any key questions
Johnson CA, Cioffi GA, Drance SM, Gaasterland D, Mills RP, Ashburn F, Hnik P, Van Coevorden RE. A multicenter comparison study of the Humphrey Field Analyzer I and the Humphrey Field Analyzer II. Ophthalmology. 97; 104(11):1910-7. Does not address any key questions
Johnson CA, Sample PA, Cioffi GA, Liebmann JR, Weinreb RN. Structure and function evaluation (SAFE): I. criteria for glaucomatous visual field loss using standard automated perimetry (SAP) and short wavelength automated perimetry (SWAP). Am J Ophthalmol. 2002;134(2):177-85. [pmid: 12140023]. Data not abstractable
Johnson CA, Sample PA, Zangwill LM, Vasile CG, Cioffi GA, Liebmann JR, Weinreb RN. Structure and function evaluation (SAFE): II. Comparison of optic disk and visual field characteristics. Am J Ophthalmol. 2003;135(2):148-54. [pmid: 12566017]. Does not address any key questions
Johnson CA. A COMPARISON OF SWAP AND FDT PERIMETRY IN EARLY GLAUCOMAS AND HIGH RISK OCULAR HYPERTENSIVES. American Academy of Optometry. 98:32. Abstract only
Jonas JB, Konigsreuther KA. Optic disk appearance in ocular hypertensive eyes. Am J Ophthalmol. 94; 117(6):732-40. Does not address any key questions
Jonas JB, Mardin CY, Grundler AE. Comparison of measurements of neuroretinal rim area between confocal laser scanning tomography and planimetry of photographs. Br. J. Ophthalmol. 98; 82(4):362-366. Does not address any key questions
Jonas JB, Stroux A, Velten I, Juenemann A, Martus P, Budde WM. Central corneal thickness correlated with glaucoma damage and rate of progression. Invest Ophthalmol Vis Sci. 2005;46(4):1269-74. [pmid: 15790889]. Does not address any key questions
Jordo MLS, Pedroso De Carvalho Lupinacci A, Ferreira EL, Enomoto IJF, Costa VP. Influence of age, central corneal thickness, and quality score on dynamic contour tonometry. Eye. 2009;23(6):1364-1369. [pmid: 18791544]. Does not address any key questions
Kalaboukhova L, Fridhammar V, Lindblom B. Glaucoma follow-up by the Heidelberg retina tomograph--new graphical analysis of optic disc topography changes. Graefes Arch Clin Exp Ophthalmol. 2006;244(6):654-62. [pmid: 16220279]. Does not address any key questions
Kamal DS, Bunce C, Hitchings RA. Use of the GDx to detect differences in retinal nerve fibre layer thickness between normal, ocular hypertensive and early glaucomatous eyes. Eye (Lond). 2000;14(Pt 3A):367-70. [pmid: 11027002]. Does not address any key questions
Kamal DS, Garway-Heath DF, Hitchings RA, Fitzke FW. Use of sequential Heidelberg retina tomograph images to identify changes at the optic disc in ocular hypertensive patients at risk of developing glaucoma. Br J Ophthalmol. 2000;84(9):993-8. [pmid: 10966952]. Does not address any key questions
Kamantigue MEG, Joson PJ, Chen PP. Prediction of visual field defects on standard automated perimetry by screening C-20–1 frequency doubling technology perimetry. J Glaucoma. 2006;15(1):35-39. [pmid: 16378016]. Does not address any key questions
Kampmeier JM, Eisert B, Lang GK, Lang GE. COMPARISON OF FREQUENCY DOUBLING PERIMETRY VS STANDARD AUTOMATED PERIMETRY IN GLAUCOMA AND AGE-RELATED MACULOPATHY. IOVS. 2000;41. ARVO Abstract 459. Abstract only
Kamppeter BA, Jonas JB. Dynamic contour tonometry for intraocular pressure measurement. Am J Ophthalmol. 2005;140(2):318-20. [pmid: 16086958]. Does not address any key questions
Kanamori A, Nakamura M, Escano MF, Seya R, Maeda H, Negi A. Evaluation of the glaucomatous damage on retinal nerve fiber layer thickness measured by optical coherence tomography. Am J Ophthalmol. 2003;135(4):513-20. [pmid: 12654369]. Infrequently used device: OCT2000
Karickhoff JR. Adding automated perimetry to glaucoma evaluation and treatment. Ann Ophthalmol. 91; 23(12):470-3. Does not address any key questions
Katsanos A, Kothy P, Konstas AG, Vargha P, Hollo G. Correlation between polarimetric retinal nerve fiber layer thickness and retinal sensitivity determined with frequency-doubling technology. Ophthalmic Surg Lasers Imaging. 2005;36(5):394-400. [pmid: 16238038]. Data not abstractable
Katz LJ, Henderer JD, Ten Hulzen RD, Spaeth GL. A COMPARISON OF THE 1% AND 5% SCREENING PROTOCOLS OF THE FREQUENCY DOUBLING PERIMETER WITH THE HUMPHREY SITA FAST AND SITA STANDARD ALGORITHMS IN A GLAUCOMA CLINIC POPULATION. IOVS. 2000;41. ARVO Abstract 462. Abstract only
Kaushik S, Gyatsho J, Jain R, Pandav SS, Gupta A. Correlation between retinal nerve fiber layer thickness and central corneal thickness in patients with ocular hypertension: an optical coherence tomography study. Am J Ophthalmol. 2006;141(5):884-890. [pmid: 16546106]. Data not abstractable
Kee C, Cho C. Evaluation of retinal nerve fiber layer thickness in the area of apparently normal hemifield in glaucomatous eyes with optical coherence tomography. J Glaucoma. 2003;12(3):250-4. [pmid: 12782844]. Does not address any key questions
Kesen MR, Spaeth GL, Henderer JD, Pereira ML, Smith AF, Steinmann WC. The Heidelberg Retina Tomograph vs clinical impression in the diagnosis of glaucoma. Am J Ophthalmol. 2002;133(5):613-6. [pmid: 11992857]. Unspecified diagnosis of Glaucoma
Khandekar R, Al Raisi A. Oman Eye Study 2005: validity of screening tests used in the glaucoma survey. East Mediterr Health J. 2008;14(6):1360-4. [pmid: 19161111]. Other (specify): Only abnormal subjects received clinical exam
Khandekar R, Zutshi R. Glaucoma among Omani diabetic patients: a cross-sectional descriptive study: (Oman diabetic eye study 2002). Eur J Ophthalmol. 2004;14(1):19-25. [pmid: 15005581]. Does not address any key questions
Khandekar R, Zutshi R, Ali M, Raisi AA, Dass H. Influence of diabetes on the validity glaucoma screening by frequency doubling perimetry: a hospital-based study in Oman. Diabetes Technol Ther. 2008;10(4):278-82. [pmid: 18715201]. Other: Not acceptable definition of glaucoma
Kim CS, Seong GJ, Lee NH, Song KC. Prevalence of primary open-angle glaucoma in central South Korea the Namil study. Ophthalmology. 2011;118(6):1024-30. [pmid: 21269703]. Other (specify): prevalence of POAG in screened population only
Kim TW, Park UC, Park KH, Kim DM. Ability of Stratus OCT to identify localized retinal nerve fiber layer defects in patients with normal standard automated perimetry results. Invest Ophthalmol Vis Sci. 2007;48(4):1635-41. [pmid: 17389494]. Data not abstractable
Kim TW, Zangwill LM, Bowd C, Sample PA, Shah N, Weinreb RN. Retinal nerve fiber layer damage as assessed by optical coherence tomography in eyes with a visual field defect detected by frequency doubling technology perimetry but not by standard automated perimetry. Ophthalmology. 2007;114(6):1053-7. [pmid: 17239441]. Data not abstractable
King AJ, Bolton N, Aspinall P, O’Brien CJ. Measurement of peripapillary retinal nerve fiber layer volume in glaucoma. Am J Ophthalmol. 2000;129(5):599-607. [pmid: 10844050]. Data not abstractable
King AJ, Bolton N, Aspinall P, O’Brien CJ. Measurement of peripapillary retinal nerve fiber layer volume in glaucoma. Am J Ophthalmol. 2000;129(5):599-607. [pmid: 10844050]. Does not address any key questions
Kishida A. Mass examination for glaucoma. A 12 year follow up (author’s transl). Nippon Ganka Gakkai Zasshi. 73; 77(10):1578-92. Foreign language
Yoshiaki KITAZAWA, Shiroaki SHIRATO, Takeshi HORIE, Fujin GO, Akira YUMITA. The Effects of 5-Oxin on Intraocular Pressure and Visual Field Defects in Primary Open-Angle Glaucoma: Double Masked Study. Therapeutic Research (Therapeutic Research). 84; 1(3):501-510. Does not address any key questions
Klemm M, Rumberger E, Walter A, Richard G. Quantification of retinal nerve fiber thickness. A comparison of laser scanning ophthalmoscopy, polarimetry and optical coherence tomography in healthy and glaucomatous eyes. Ophthalmologe. 2001;98(9):832-43. [pmid: 11594222]. Foreign language
Klemm M, Rumberger E, Walter A, Richard G. Reproducibility of measuring retinal nerve fiber density. Comparison of optical coherence tomography with the nerve fiber analyzer and the Heidelberg retinal tomography device. Der Ophthalmologe : Zeitschrift der Deutschen Ophthalmologischen Gesellschaft. 2002;99(5):345-51. [pmid: 12043288]. Foreign language
Klemm M, Rumberger E, Winter R, Walter A, Richard G. Reliability and precision of retinal nerve fiber layer thickness measurements: Comparison of OCT to NFA. Spektrum der Augenheilkunde. 2000;14(6):301-305. Foreign language
Kniestedt C, Lin S, Choe J, Nee M, Bostrom A, Sturmer J, Stamper RL. Correlation between intraocular pressure, central corneal thickness, stage of glaucoma, and demographic patient data: prospective analysis of biophysical parameters in tertiary glaucoma practice populations. J Glaucoma. 2006;15(2):91-7. [pmid: 16633220]. Does not address any key questions
Knox PC, Cunningham I, Fisher AC. The Impact of Secondary Auditory Tasks on SITA Standard Perimetry in Glaucoma Patients and Healthy Controls. IOVS. 2006;47. ARVO E-abstract 1122. Abstract only
Ko Y-C, Liu CJI, Hsu W-M. Varying effects of corneal thickness on intraocular pressure measurements with different tonometers. Eye. 2005;19(3):327-332. [pmid: 15258603]. Does not address any key questions
Kogure S, Toda Y, Tsukahara S. Prediction of future scotoma on conventional automated static perimetry using frequency doubling technology perimetry. Br J Ophthalmol. 2006;90(3):347-52. [pmid: 16488960]. Does not address any key questions
Kohler U, Schmoger E. Follow-up of cases of suspected glaucoma (author’s transl). Klin Monbl Augenheilkd. 75; 166(1):11-7. Foreign language
Kook MS, Cho HS, Seong M, Choi J. Scanning laser polarimetry using variable corneal compensation in the detection of glaucoma with localized visual field defects. Ophthalmology. 2005;112(11):1970-8. [pmid: 16185765]. Non-commercially available analysis of data
Korth MJ, Junemann AM, Horn FK, Bergua A, Cursiefen C, Velten I, Budde WM, Wisse M, Martus P. Synopsis of various electrophysiological tests in early glaucoma diagnosis--temporal and spatiotemporal contrast sensitivity, light- and color-contrast pattern-reversal electroretinogram, blue-yellow VEP. Klin Monbl Augenheilkd. 2000;216(6):360-8. [pmid: 10919115]. Foreign language
Korzekwa W, Korzekwa M, Markowska J, Wojcik-Niklewska B, Romaniuk W, Korzekwa A, Michalska-Malecka K. Frequency doubling perimetry in diagnosis of early glaucomatous optic nerve fiber damage. Klin Oczna. 2004;106(1–2 Suppl):222-4. [pmid: 15510506]. Foreign language
Kosoko O, Sommer A, Auer C. Screening with automated perimetry using a threshold-related three-level algorithm. Ophthalmology. 86; 93(7):882-6. Non-commercially available analysis of data
Kozlova LP, Fedorova SM. Results of prolonged dispensarization of persons with suspected glaucoma. Oftalmol Zh. 74; 29(4):285-8. Foreign language
Kruger H, Schittkowski MP, Guthoff RF. Comparing applanation and impression tonometry in Central African Bantu people. Klin Monbl Augenheilkd. 2007;224(9):722-6. [pmid: 17846962]. Does not address any key questions
Kuroedov AV, Zhukov VF, Sol’nov NM, Kushim ZP, Makarova AIu. Efficiency of mass screening system and routine medical check-up of glaucoma patients. Voen Med Zh. 2004;325(4):38-41. [pmid: 15188538]. Foreign language
Kuroedov AV, Zhukov VF, Sol’nov NM, Kushim ZP, Makarova AI. Efficiency of mass screening system and routine medical check-up of glaucoma patients. Effektivnost’ sistemy skriningovogo obsledovaniia i dispansernogo nabliudeniia bol’nykh glaukomoi. Voen Med Zh. 2004;325(4):38-41. [pmid: 15188538]. Foreign language
Kwartz AJ, Henson DB, Harper RA, Spencer AF, McLeod D. The effectiveness of the Heidelberg Retina Tomograph and laser diagnostic glaucoma scanning system (GDx) in detecting and monitoring glaucoma. Health Technol Assess. 2005;9(46):1-132. iii. [pmid: 16303099]. Does not use clinical assessment as reference standard
Lachkar Y, Cohn H. Sensitivity and specificity of optic disc variables and analysis of a new variable (MP/D) for glaucoma diagnosis with the Glaucoma-Scope. Br J Ophthalmol. 97; 81(10):846-51. Infrequently used device: experimental
Lalezary M, Medeiros FA, Weinreb RN, Bowd C, Sample PA, Tavares IM, Tafreshi A, Zangwill LM. Baseline optical coherence tomography predicts the development of glaucomatous change in glaucoma suspects. Am J Ophthalmol. 2006;142(4):576-82. [pmid: 17011848]. Other (specify): Excluded device
Lam A, Chen D, Chiu R, Chui WS. Comparison of IOP measurements between ORA and GAT in normal Chinese. Optom Vis Sci. 2007;84(9):909-14. [pmid: 17873777]. Does not address any key questions
Lam DS, Leung DY, Chiu TY, Fan DS, Cheung EY, Wong TY, Lai JS, Tham CC. Pressure phosphene self-tonometry: a comparison with goldmann tonometry in glaucoma patients. Invest Ophthalmol Vis Sci. 2004;45(9):3131-6. [pmid: 15326131]. Does not address any key questions
Landers JA, Goldberg I, Graham SL. Detection of Early Visual Field Loss in Glaucoma Using Frequency-Doubling Perimetry and Short-Wavelength Automated Perimetry. Arch Ophthalmol. 2003;121(12):1705-1710. [pmid: 14662589]. Does not address any key questions
Landers J, Goldberg I, Graham S. A comparison of short wavelength automated perimetry with frequency doubling perimetry for the early detection of visual field loss in ocular hypertension. Clin. Exp. Ophthalmol. 2000;28(4):248-252. Does not address any key questions
Langerhorst CT, van den Berg TJ, Greve EL. Is there general reduction of sensitivity in glaucoma?. Int Ophthalmol. 89; 13(1–2):31-5. Does not address any key questions
Larrosa JM, Polo V, Perez-Inigo A, Ferreras A, Garcia-Feijoo J, Anton A, Honrubia FM. Optic nerve head parameters as measured by confocal scanning laser (Heidelberg Retina Tomograph II) in normal, ocular hypertensive and glaucomatous subjects. Arch Soc Esp Oftalmol. 2008;83(7):407-15. [pmid: 18592440]. Data not abstractable
Lauande-Pimentel R, Barton K, Poinoosawmy D, Maino A, Heath TG, Hitchings R. Detec gPo de alteragões na camada de fibras nervosas da retina por meio do laser confocal polarizado em hipertens Po ocular antes do surgimento de defeitos perimqtricos. Arq. Bras. Oftalmol. 2004;67(5):703-7. Foreign language
Lauande-Pimentel R, Carvalho RA, Oliveira HC, Goncalves DC, Silva LM, Costa VP. Discrimination between normal and glaucomatous eyes with visual field and scanning laser polarimetry measurements. Br J Ophthalmol. 2001;85(5):586-91. [pmid: 11316722]. Infrequently used device: outdated devices
Lederer DE, Schuman JS, Hertzmark E, Heltzer J, Velazques LJ, Fujimoto JG, Mattox C. Analysis of macular volume in normal and glaucomatous eyes using optical coherence tomography. Am J Ophthalmol. 2003;135(6):838-43. [pmid: 12788124]. Does not address any key questions
Lee PP, Walt JW, Rosenblatt LC, Siegartel LR, Stern LS. Association between intraocular pressure variation and glaucoma progression: data from a United States chart review. Am J Ophthalmol. 2007;144(6):901-907. [pmid: 17919446]. Does not address any key questions
Lee SY, Ha DW, Kook MS. Ability of scanning laser polarimetry (GDx) to discriminate among early glaucomatous, ocular hypertensive and normal eyes in the Korean population. Korean J Ophthalmol. 2004;18(1):1-8. [pmid: 15255230]. Other (specify): outdated device
Lee SY, Ha DW, Kook MS. Ability of scanning laser polarimetry (GDx) to discriminate among early glaucomatous, ocular hypertensive and normal eyes in the Korean population. Korean J Ophthalmol. 2004;18(1):1-8. [pmid: 15255230]. Other (specify): outdated device per specialist
Leighton DA, Phillips CI. Provocative test combining water drinking and homatropine eye drops. Applanation versus tonography. The British journal of ophthalmology. 71; 55(9):619-27. Does not address any key questions
Leske MC, Connell AMS, Schachat AP, Hyman L. The Barbados Eye Study: Prevalence of open angle glaucoma. ARCH. OPHTHALMOL. 94; 112(6):821-829. Does not address any key questions
Leske MC, Connell AMS, Wu S-Y, Hyman LG, Schachat AP. Risk factors for open-angle glaucoma: The Barbados eye study. ARCH. OPHTHALMOL. 95; 113(7):918-924. Does not address any key questions
Leske MC, Connell AMS, Wu S-Y, Hyman LG, Schachat AP. Risk factors for open-angle glaucoma: The Barbados eye study. ARCH. OPHTHALMOL. 95; 113(7):918-924. It does not address the adequate population
Leske MC, Connell AMS, Wu S-Y, Nemesure B, Li X, Schachat A, Hennis A. Incidence of open-angle glaucoma: The Barbados Eye Studies. Arch. Ophthalmol. 2001;119(1):89-95. [pmid: 11146731]. Does not address any key questions
Leske MC, Connell AM, Wu SY, Nemesure B, Li X, Schachat A, Hennis A. Incidence of open-angle glaucoma: the Barbados Eye Studies. The Barbados Eye Studies Group. Arch Ophthalmol. 2001;119(1):89-95. [pmid: 11146731]. Does not address any key questions
Leske MC, Nemesure B, He Q, Wu SY, Fielding Hejtmancik J, Hennis A. Patterns of open-angle glaucoma in the Barbados Family Study. Ophthalmology. 2001;108(6):1015-22. [pmid: 11382622]. Does not address any key questions
Leske MC, Warheit-Roberts L, Wu SY. Open-angle glaucoma and ocular hypertension: the Long Island Glaucoma Case-control Study. Ophthalmic Epidemiol. 96; 3(2):85-96. Does not address any key questions
Leske MC, Wu SY, Hennis A, Honkanen R, Nemesure B. Risk factors for incident open-angle glaucoma: the Barbados Eye Studies. Ophthalmology. 2008;115(1):85-93. [pmid: 17629563]. Does not address any key questions
Leske MC, Wu SY, Honkanen R, Nemesure B, Schachat A, Hyman L, Hennis A. Nine-year incidence of open-angle glaucoma in the Barbados Eye Studies. Ophthalmology. 2007;114(6):1058-64. [pmid: 17397925]. Does not address any key questions
Leske MC, Wu SY, Nemesure B, Hennis A. Incident open-angle glaucoma and blood pressure. Arch Ophthalmol. 2002;120(7):954-9. [pmid: 12096967]. Does not address any key questions
Leung CK, Chan WM, Chong KK, Yung WH, Tang KT, Woo J, Chan WM, Tse KK. Comparative study of retinal nerve fiber layer measurement by StratusOCT and GDx VCC, I: correlation analysis in glaucoma. Invest Ophthalmol Vis Sci. 2005;46(9):3214-20. [pmid: 16123421]. Data not abstractable
Leung CK, Chan WM, Hui YL, Yung WH, Woo J, Tsang MK, Tse KK. Analysis of retinal nerve fiber layer and optic nerve head in glaucoma with different reference plane offsets, using optical coherence tomography. Invest Ophthalmol Vis Sci. 2005;46(3):891-9. [pmid: 15728545]. Non-commercially available analysis of data
Leung CK, Cheung CY, Weinreb RN, Qiu Q, Liu S, Li H, Xu G, Fan N, Huang L, Pang CP, Lam DS. Retinal nerve fiber layer imaging with spectral-domain optical coherence tomography: a variability and diagnostic performance study. Ophthalmology. 2009;116(7):1257-63. 1263.e1. 2. [pmid: 19464061]. Does not use clinical assessment as reference standard
Leung CK, Choi N, Weinreb RN, Liu S, Ye C, Liu L, Lai GW, Lau J, Lam DS. Retinal nerve fiber layer imaging with spectral-domain optical coherence tomography: pattern of RNFL defects in glaucoma. Ophthalmology. 2010;117(12):2337-44. [pmid: 20678802]. Non-commercially available analysis of data
Leung CK, Lam S, Weinreb RN, Liu S, Ye C, Liu L, He J, Lai GW, Li T, Lam DS. Retinal nerve fiber layer imaging with spectral-domain optical coherence tomography: analysis of the retinal nerve fiber layer map for glaucoma detection. Ophthalmology. 2010;117(9):1684-91. [pmid: 20663563]. Other (specify): scoring system unavailable
Leung CK, Ye C, Weinreb RN, Cheung CY, Qiu Q, Liu S, Xu G, Lam DS. Retinal nerve fiber layer imaging with spectral-domain optical coherence tomography a study on diagnostic agreement with Heidelberg Retinal Tomograph. Ophthalmology. 2010;117(2):267-74. [pmid: 19969364]. Does not use clinical assessment as reference standard
Leydhecker W. The reliability of diagnosis of simple glaucoma in the early stage. Doc Ophthalmol. 66; 20:214-29. Foreign language
Li JJ, Xu L, Zhang RX, Sun XY, Yang H, Zou Y, Zhao JL. The value of frequency doubling perimetry in glaucoma screening of aged 40 or more population. Zhonghua Yan Ke Za Zhi. 2005;41(3):221-5. [pmid: 15840362]. Foreign language
Li S, Wang X, Li S, Wu G, Wang N. Evaluation of optic nerve head and retinal nerve fiber layer in early and advance glaucoma using frequency-domain optical coherence tomography. Graefes Arch Clin Exp Ophthalmol. 2010;248(3):429-34. [pmid: 19937335]. Does not use clinical assessment as reference standard
Li Y, Shi J, Duan X, Fan F. Transpalpebral measurement of intraocular pressure using the Diaton tonometer versus standard Goldmann applanation tonometry. Graefe’s Arch. Clin. Exp. Ophthalmol. 2010;248(12):1765-1770. Does not examine candidate screening tests for glaucoma
Libera RD, Moriyama AS, Melo LAS Jr. Comparison Between Swedish Interactive Threshold Algorithm and Full Threshold Strategies in Short Wavelength Automated Perimetry. IOVS. 2008. ARVO E- abstract 1074. Abstract only
Lin HY, Hsu WM, Chou P, Liu CJ, Chou JC, Tsai SY, Cheng CY. Intraocular pressure measured with a noncontact tonometer in an elderly Chinese population: the Shihpai Eye Study. Arch Ophthalmol. 2005;123(3):381-6. [pmid: 15767482]. Does not address any key questions
Linner E, Stromberg U. The course of untreated ocular hypertension. A tonographic study. Acta Ophthalmol (Copenh). 64; 42(4):836-48. Does not address any key questions
Liu CJ, Cheng CY, Hsu WM. Scanning laser polarimetry with variable corneal compensation in primary angle-closure glaucoma. Ophthalmology. 2008;115(8):1334-9. [pmid: 18201763]. Does not address any key questions
Liu X, Liang YB, Ling YL, Huang JJ, Zheng XP. The diagnostic ability of Heidelberg retina tomography to detect glaucomatous optic neuropathy in Chinese. Zhonghua Yan Ke Za Zhi. 2004;40(11):737-40. [pmid: 15634479]. Foreign language
Liu X, Ling Y, Luo R, Ge J, Zheng X. Optical coherence tomography in measuring retinal nerve fiber layer thickness in normal subjects and patients with open-angle glaucoma. Chin Med J (Engl). 2001;114(5):524-9. [pmid: 11780419]. Infrequently used device: old OCT 2000
Liu X, Ling Y, Zheng X, Huang J. Study on stereometric parameters of optic nerve head of normal, big-cupped disk and glaucomatous eyes using Heidelberg retina tomograph. Yan Ke Xue Bao. 2000;16(3):163-167. [pmid: 12579640]. Does not address any key questions
Liu X, Lin YL, Zhou WB, Zheng XP. Qulitative and quantitative measurement of retinal nerve fiber layer in primery open angle glaucoma by optical coherence tomography. Zhonghua yan ke za zhi. Chinese journal of ophthalmology. 2000;36(6):420-425. [pmid: 11853640]. Foreign language
Lleo-Perez A, Ortuno-Soto A, Rahhal MS, Martinez-Soriano F, Sanchis-Gimeno JA. Intraobserver reproducibility of retinal nerve fiber layer measurements using scanning laser polarimetry and optical coherence tomography in normal and ocular hypertensive subjects. Eur J Ophthalmol. 2004;14(6):523-30. [pmid: 15638102]. Does not address any key questions
Lockwood AJ, Kirwan JF, Ashleigh Z. Optometrists referrals for glaucoma assessment: A prospective survey of clinical data and outcomes. Eye. 2010;24(9):1515-1519. [pmid: 20559331]. Does not address any key questions
Lopez-Pena MJ, Ferreras A, Polo V, Larrosa JM, Honrubia FM. Relationship between standard automated perimetry and HRT, OCT and GDx in normal, ocular hypertensive and glaucomatous subjects. Arch Soc Esp Oftalmol. 2007;82(4):197-208. [pmid: 17443424]. Does not address any key questions
Madjlessi F, Marx W, Reinhard T, Althaus C, Sundmacher R. Impression applanation tonometry in irregular corneas. Comparison with intraocular needle tonometry. Ophthalmologe. 2000;97(7):478-81. [pmid: 10959183]. Book Chapter
Madsen B, Sponsel WE, McKinnon S. Evaluation of VisionRx Computer Based Perimetry vs. umphrey Visual Field. IOVS. 2002;43. ARVO E-abstract 2174. Abstract only
Maeda H, Nakaura M, Negi A. New perimetric threshold test algorithm with dynamic strategy and tendency oriented perimetry (TOP) in glaucomatous eyes. Eye (Lond). 2000;14(Pt 5):747-51. [pmid: 11116697]. Non-commercially available analysis of data
Magacho L, Marcondes AM, Costa VP. Correla gPo entre o top£grafo de disco £ptico (TOPSS) e Ændices do campo visual. Arq. Bras. Oftalmol. 2004;67(1):73-8. Foreign language
Magacho L, Marcondes AM, Costa VP. Correlation between optic disc topography and retinal nerve fibre layer measurements in glaucoma. Acta Ophthalmol Scand. 2005;83(3):322-7. [pmid: 15948785]. Does not address any key questions
Magacho L, Marcondes AM, Costa VP. Discrimination between normal and glaucomatous eyes with scanning laser polarimetry and optic disc topography: A preliminary report. Eur. J. Ophthalmol. 2005;15(3):353-359. [pmid: 15945004]. Other (specify): Outdated device
Mai TA, Reus NJ, Lemij HG. Retinal nerve fiber layer measurement repeatability in scanning laser polarimetry with enhanced corneal compensation. J Glaucoma. 2008;17(4):269-74. [pmid: 18552611]. Does not address any key questions
Maino AP, Uddin HJ, Tullo AB. A comparison of clinical performance between disposable and Goldmann tonometers. Eye (Lond). 2006;20(5):574-8. [pmid: 15920568]. Data not abstractable
Malagola R, Motolese ED, De Luca T. Long-term tonometry control of laser therapy of open-angle glaucoma. Fortschr Ophthalmol. 88; 85(4):366-8. Foreign language
Mamikonian VR, Kazarian EE, Gloian NS, Shmeleva-Demir OA. Comparative analysis of several morphometric parameters received using optic coherent tomography and scanning laser ophthalmoscopy in initial glaucoma diagnosis. Vestn Oftalmol. 2011;127(2):18-20. [pmid: 21721266]. Foreign language
Manassakorn A, Nouri-Mahdavi K, Caprioli J. Comparison of retinal nerve fiber layer thickness and optic disk algorithms with optical coherence tomography to detect glaucoma. Am J Ophthalmol. 2006;141(1):105-115. [pmid: 16386983]. Does not use clinical assessment as reference standard
Mansberger SL, Edmunds B, Johnson CA, Kent KJ, Cioffi GA. Community visual field screening: prevalence of follow-up and factors associated with follow-up of participants with abnormal frequency doubling perimetry technology results. Ophthalmic Epidemiol. 2007;14(3):134-40. [pmid: 17613848]. Does not address any key questions
Mansberger SL, Johnson CA, Cioffi GA. The results of screening frequency doubling technology perimetry in different locations of the community. J Glaucoma. 2007;16(1):73-80. [pmid: 17224754]. Does not address any key questions
Mansberger SL, Johnson CA, Cioffi GA, Choi D, Krishnadas SR, Srinivasan M, Balamurugan V, Kim U, Smith SD, Wilkins JH, Gritz DC. Predictive value of frequency doubling technology perimetry for detecting glaucoma in a developing country. J Glaucoma. 2005;14(2):128-34. [pmid: 15741814]. Covered by Burr
Mao LK, Stewart WC, Shields MB. Correlation between intraocular pressure control and progressive glaucomatous damage in primary open-angle glaucoma. Am J Ophthalmol. 91; 111(1):51-5. Does not address any key questions
Mao LK, Stewart WC, Shields MB. Correlation between intraocular pressure control and progressive glaucomatous damage in primary open-angle glaucoma. Am J Ophthalmol. 91; 111(1):51-5. Other (specify): Progression study
Marchini G, Babighian S, Specchia L, Perfetti S. Evaluation of the new Ocuton S tonometer. Acta Ophthalmol Scand. 2002;80(2):167-71. [pmid: 11952483]. Other (specify): reliability
Marchini G, Babighian S, Specchia L, Perfetti S. Evaluation of the new Ocuton S tonometer. Acta Ophthalmol Scand. 2002;80(2):167-71. [pmid: 11952483]. Other (specify): reliability only study
Marcon tM, Goldhart R, CorrWa ZMdS, Loeff RF, Souza RPd, Marcon AS. O campo visual azul-amarelo q mais sensÆvel que o campo visual branco-branco?. Rev. Bras. Oftalmol. 2003;62(6):437-43. Foreign language
Marcon Italo, Mundialino Mello, Augusto de Arruda Paulo, Vacaro Fbbio, Marcon Alexandre Seminoti. Campo visual no glaucoma de Gngulo aberto: estudo comparativo entre o campo visual computadorizado central e perifqrico. Arq. bras. oftalmol. 96; 59(1):69-72. Foreign language
Mardin CY, Horn FK, Jonas JB, Budde WM. Preperimetric glaucoma diagnosis by confocal scanning laser tomography of the optic disc. Br J Ophthalmol. 99; 83(3):299-304. Infrequently used device: HRT1
Mardin CY, Horn F, Viestenz A, Lammer R, Junemann A. Healthy optic discs with large cups--a diagnostic challenge in glaucoma. Klin Monbl Augenheilkd. 2006;223(4):308-14. [pmid: 16639669]. Foreign language
Mardin CY, Hothorn T, Peters A, Junemann AG, Nguyen NX, Lausen B. New glaucoma classification method based on standard Heidelberg Retina Tomograph parameters by bagging classification trees. J Glaucoma. 2003;12(4):340-6. [pmid: 12897579]. Non-commercially available analysis of data
Mardin CY, Hothorn T, Peters A, Junemann AG, Nguyen NX, Lausen B. New glaucoma classification method based on standard Heidelberg Retina Tomograph parameters by bagging classification trees. J Glaucoma. 2003;12(4):340-6. [pmid: 12897579]. Other: reference standard unclear
Marner O. Glaucoma in Munster. Ophthalmologe. 98; 95(1):37-43. Foreign language
Marques DMV, Rehder JRCL. AvaliagPo da viabilidade económica do HRT na prbtica oftalmol£gica dibria. Arq. Mqd. ABC. 2004;29(2):95-8. Foreign language
Marre Khauzmann, Riulle. Condition of the eyes 10 years after detection of increased intraocular pressure. Vestn Oftalmol. 77(1):14-6. [pmid: 14315465]. Foreign language
Martin XD, Fankhauser F, Rabineau PA. Effects of timolol on visual-field mean retinal sensitivity in normal subjects. International ophthalmology. 92; 16(4–5):325-9. It does not address the adequate population
Martin-Boglind L, Wanger P. The effect of treatment on the results of high-pass resolution perimetry in glaucoma. Acta Ophthalmol (Copenh). 94; 72(4):423-8. Does not address any key questions
Martinez GA, Sample PA, Weinreb RN. Comparison of high-pass resolution perimetry and standard automated perimetry in glaucoma. AM. J. OPHTHALMOL. 95; 119(2):195-201. Does not examine candidate screening tests for glaucoma
Martus P, Junemann A, Wisse M, Budde WM, Horn F, Korth M, Jonas JB. Multivariate approach for quantification of morphologic and functional damage in glaucoma. Invest Ophthalmol Vis Sci. 2000;41(5):1099-110. [pmid: 10752947]. Does not address any key questions
Martus P, Korth M, Nguyen NX. The value of blue-on yellow VEP for the early diagnosis of glaucoma. Biostatistical considerations and results. Wertigkeit des Blau-auf-Gelb-VEP fur die Fruhdiagnose bei Glaukomverdacht. Biostatistische Uberlegungen und Ergebnisse. OPHTHALMOLOGE. 97; 94(4):277-281. Foreign language
Mason RP, Kosoko O, Wilson MR, Martone JF, Cowan CL Jr, Gear JC, Ross-Degnan D. National survey of the prevalence and risk factors of glaucoma in St. Lucia, West Indies. Part I. Prevalence findings. Ophthalmology. 89; 96(9):1363-8. Does not address any key questions
Mason RP, Kosoko O, Wilson MR, Martone JF, Cowan CL Jr, Gear JC, Ross-Degnan D. National survey of the prevalence and risk factors of glaucoma in St. Lucia, West Indies. Part I. Prevalence findings. Ophthalmology. 89; 96(9):1363-8. It does not address the adequate population
Mastropasqua L, Brusini P, Carpineto P, Ciancaglini M, Di Antonio L, Zeppieri MW, Parisi L. Humphrey matrix frequency doubling technology perimetry and optical coherence tomography measurement of the retinal nerve fiber layer thickness in both normal and ocular hypertensive subjects. J Glaucoma. 2006;15(4):328-35. [pmid: 16865011]. It does not address the adequate population
Mathai A, Thomas R, Braganza A, Maharajan S, George T, Muliyil J. VISTECH contrast sensitivity testing in primary open angle glaucoma. Indian J Ophthalmol. 97; 45(2):99-103. Does not address any key questions
Mathai A, Thomas R, Braganza A, Maharajan S, George T, Muliyil J. VISTECH contrast sensitivity testing in primary open angle glaucoma. Indian J Ophthalmol. 97; 45(2):99-103. Does not examine candidate screening tests for glaucoma
Mattern A, Stodtmeister R, Pillunat LE, Abel T. Leydhecker tonography and Ulrich ocular pressure tonometry in probands with healthy eyes and glaucoma patients. Fortschr Ophthalmol. 89; 86(4):411-5. Foreign language
Mattos TdCL, Kasahara N, Paolera MD, Cohen R, Mandia C Junior, Almeida GVd. Sensibilidade do est Æmulo de tamanho I na perimetria computadorizada acrombtica para a detecgPo de defeitos glaucomatosos no campo visual: anblise comparativa com as perimetrias de ondas curtas e acrombtica convencional (SITA). Arq. Bras. Oftalmol. 2008;71(2):142-8. [pmid: 18516409]. Foreign language
de Mattos TC, Kasahara N, Della Paolera M, Cohen R, Mandia C Junior, Almeida GV. Sensitivity of size I stimulus in achromatic automated perimetry for detection of glaucomatous visual field defects: a comparative analysis with short wavelength automated perimetry and standard automated perimetry (SITA). Arq Bras Oftalmol. 2008;71(2):142-8. [pmid: 18516409]. Foreign language
Maul de la Puente E, G£mez P. CampimetrÆa y eco-doppler en glaucoma. Arch. Chil. Oftalmol. 1997;54(2):59-62. Foreign language
Maul de la Puente E. La perimetrÆa computada en el glaucoma. Arch. Chil. Oftalmol. 1997;54(2):25-41. Foreign language
Mayoral F, Polo V, Ferreras A, Larrosa JM, Pueyo V, Honrubia F. Diagnostic ability of stratus optical coherence tomography (OCT) in pre-perimetric glaucoma diagnosis. Arch Soc Esp Oftalmol. 2006;81(9):537-44. [pmid: 17016786]. Foreign language
McKean-Cowdin R, Wang Y, Wu J, Azen SP, Varma R. Impact of visual field loss on health-related quality of life in glaucoma: the Los Angeles Latino Eye Study. Ophthalmology. 2008;115(6):941-948.e1. [pmid: 17997485]. Does not address any key questions
Medeiros FA, Sample PA, Weinreb RN. Frequency doubling technology perimetry abnormalities as predictors of glaucomatous visual field loss. Am J Ophthalmol. 2004;137(5):863-71. [pmid: 15126151]. Data not abstractable
Medeiros FA, Sample PA, Zangwill LM, Liebmann JM, Girkin CA, Weinreb RN. A statistical approach to the evaluation of covariate effects on the receiver operating characteristic curves of diagnostic tests in glaucoma. Invest Ophthalmol Vis Sci. 2006;47(6):2520-7. [pmid: 16723465]. Does not address any key questions
Medeiros FA, Weinreb RN, Zangwill LM, Alencar LM, Sample PA, Vasile C, Bowd C. Long-term intraocular pressure fluctuations and risk of conversion from ocular hypertension to glaucoma. Ophthalmology. 2008;115(6):934-40. [pmid: 17936908]. Does not address any key questions
Medeiros FA, Zangwill LM, Bowd C, Bernd AS, Weinreb RN. Fourier analysis of scanning laser polarimetry measurements with variable corneal compensation in glaucoma. Invest Ophthalmol Vis Sci. 2003;44(6):2606-12. [pmid: 12766063]. Non-commercially available analysis of data
Medeiros FA, Zangwill LM, Bowd C, Sample PA, Weinreb RN. Use of progressive glaucomatous optic disk change as the reference standard for evaluation of diagnostic tests in glaucoma. Am J Ophthalmol. 2005;139(6):1010-8. [pmid: 15953430]. Does not address any key questions
Medeiros FA, Zangwill LM, Bowd C, Vasile C, Sample PA, Weinreb RN. Agreement between stereophotographic and confocal scanning laser ophthalmoscopy measurements of cup/disc ratio: effect on a predictive model for glaucoma development. J Glaucoma. 2007;16(2):209-14. [pmid: 17473732]. Data not abstractable
Medical Services Advisory Committee (MSAC). Macular optical coherence tomography (OCT) for glaucoma (Project Record). Canberra. Medical Services Advisory Committee (MSAC). 2007. Project Record
Medved N, Cvenkel B. Diagnostic accuracy of the Moorfields Regression Analysis using the Heidelberg Retina Tomograph in glaucoma patients with visual field defects. Eur J Ophthalmol. 2007;17(2):216-22. [pmid: 17415695]. Does not examine candidate screening tests for glaucoma
Melo GB, Libera RD, Barbosa AS, Pereira LM, Doi LM, Melo LA Jr. Comparison of optic disk and retinal nerve fiber layer thickness in nonglaucomatous and glaucomatous patients with high myopia. Am J Ophthalmol. 2006;142(5):858-60. [pmid: 17056370]. Data not abstractable
Merle H, Renard A, Donnio A, Richer R, Ayeboua L, Ensfelder G, Ventura E. Glaucoma screening in Martinique. Results in 813 hospital employees. J Fr Ophtalmol. 2004;27(2):136-42. [pmid: 15029040]. Foreign language
Metheetrairut A, Singalavanija A, Ruangvaravate N, Tuchinda R. Evaluation of screening tests and prevalence of glaucoma: integrated health research program for the Thai elderly. J Med Assoc Thai. 2002;85(2):147-53. [pmid: 12081112]. Does not examine candidate screening tests for glaucoma
Miglior S, Albe E, Guareschi M, Rossetti L, Orzalesi N. Intraobserver and interobserver reproducibility in the evaluation of optic disc stereometric parameters by Heidelberg Retina Tomograph. Ophthalmology. 2002;109(6):1072-7. [pmid: 12045046]. Does not address any key questions
Miglior S, Albe E, Guareschi M, Rossetti L, Orzalesi N. Intraobserver and interobserver reproducibility in the evaluation of optic disc stereometric parameters by Heidelberg Retina Tomograph. Ophthalmology. 2002;109(6):1072-7. [pmid: 12045046]. Other (specify): reliability study only
Miglior S, Casula M, Guareschi M, Marchetti I, Iester M, Orzalesi N. Clinical ability of Heidelberg Retinal Tomograph examination to detect glaucomatous visual field changes. Ophthalmology. 2001;108(9):1621-1627. [pmid: 11535460]. Other (specify): HRT1
Miglior S, Guareschi M, Albe’ E, Gomarasca S, Vavassori M, Orzalesi N. Detection of glaucomatous visual field changes using the Moorfields regression analysis of the Heidelberg retina tomograph. Am J Ophthalmol. 2003;136(1):26-33. [pmid: 12834666]. Other (specify): HRT1
Miglior S, Guareschi M, Romanazzi F, Albe E, Torri V, Orzalesi N. the impact of definition of primary open-angle glaucoma on the cross-sectional assessment of diagnostic validity of Heidelberg retinal tomography. Am J Ophthalmol. 2005;139(5):878-87. [pmid: 15860294]. Does not address any key questions
Miglior S, Riva I, Guareschi M, Di Matteo F, Romanazzi F, Buffagni L, Rulli E. Retinal sensitivity and retinal nerve fiber layer thickness measured by optical coherence tomography in glaucoma. Am J Ophthalmol. 2007;144(5):733-740. [pmid: 17707327]. Does not address any key questions
Milla E, Duch S, Buchacra O, Masuet C. Poor agreement between Goldmann and Pascal tonometry in eyes with extreme pachymetry. Eye (Lond). 2009;23(3):536-42. [pmid: 18369376]. Data not abstractable
Mills RP, Barnebey HS, Migliazzo CV, Li Y. Does saving time using FASTPAC or suprathreshold testing reduce quality of visual fields?. Ophthalmology. 94; 101(9):1596-603. Does not address any key questions
Mills RP, Barnebey HS, Migliazzo CV, Li Y. Does saving time using FASTPAC or suprathreshold testing reduce quality of visual fields?. Ophthalmology. 94; 101(9):1596-603. Does not examine candidate screening tests for glaucoma
Mistlberger A, Liebmann JM, Greenfield DS, Pons ME, Hoh ST, Ishikawa H, Ritch R. Heidelberg retina tomography and optical coherence tomography in normal, ocular-hypertensive, and glaucomatous eyes. Ophthalmology. 99; 106(10):2027-32. Does not address any key questions
Mitchell P, Leung H, Wang JJ, Rochtchina E, Lee AJ, Wong TY, Klein R. Retinal vessel diameter and open-angle glaucoma: the Blue Mountains Eye Study. Ophthalmology. 2005;112(2):245-50. [pmid: 15691558]. Does not address any key questions
Mocan MC, Bozkurt B, Irkec M, Orhan M, Karabulut E. The evaluation of retinal nerve fiber layer in pigment dispersion syndrome and pigmentary glaucoma using scanning laser polarimetry. Eur J Ophthalmol. 2003;13(4):377-82. [pmid: 12872795]. Does not address any key questions
Mohammadi K, Bowd C, Weinreb RN, Medeiros FA, Sample PA, Zangwill LM. Retinal nerve fiber layer thickness measurements with scanning laser polarimetry predict glaucomatous visual field loss. Am J Ophthalmol. 2004;138(4):592-601. [pmid: 15488786]. Does not address any key questions
Mok KH, Lee VW. Nerve fiber analyzer and short-wavelength automated perimetry in glaucoma suspects: a pilot study. Ophthalmology. 2000;107(11):2101-4. [pmid: 11054341]. Does not address any key questions
Mok KH, Lee VW, So KF. Retinal nerve fiber layer measurement by optical coherence tomography in glaucoma suspects with short-wavelength perimetry abnormalities. J Glaucoma. 2003;12(1):45-9. [pmid: 12567111]. Does not address any key questions
Mok KH, Lee VW, So KF. Retinal nerve fiber loss in high- and normal-tension glaucoma by optical coherence tomography. Optom Vis Sci. 2004;81(5):369-72. [pmid: 15181362]. Data not abstractable
Mok KH, Lee VW, So KF. Retinal nerve fiber loss pattern in high-tension glaucoma by optical coherence tomography. J Glaucoma. 2003;12(3):255-9. [pmid: 12782845]. Does not address any key questions
Molina N, Milla E, Bitrian E, Larena C, Martinez L. Comparison of Goldmann tonometry, pneumotonometry and the effect of the central corneal thickness. Arch Soc Esp Oftalmol. 2010;85(10):325-8. [pmid: 21168056]. Foreign language
Moosavi R, Ho TA, Verdon-Roe GM, Murdoch IE, Garway-Heath DF. Pilot Study to Assess the Acceptability and Reliability of Diagnostic Instruments for Glaucoma Case-Findings. IOVS. 2006;47. ARVO E-abstract 3425. Abstract only
Morales J, Weitzman ML, Gonzalez de la Rosa M. Comparison between Tendency-Oriented Perimetry (TOP) and octopus threshold perimetry. Ophthalmology. 2000;107(1):134-42. [pmid: 10647732]. Other (specify): no glaucoma subjects
Moreno-Montanes J, Alvarez-Vidal A, Sainz Gomez C, Rodriguez Conde R. Retinal nerve fiber layer thickness in glaucomatous eyes. A comparative study between OCT and visual field. Arch Soc Esp Oftalmol. 2002;77(8):435-41. [pmid: 12185619]. Foreign language
Moreno-Montanes J, Maldonado MJ, Garcia N, Mendiluce L, Garcia-Gomez PJ, Segui-Gomez M. Reproducibility and clinical relevance of the ocular response analyzer in nonoperated eyes: corneal biomechanical and tonometric implications. Invest Ophthalmol Vis Sci. 2008;49(3):968-74. [pmid: 18326720]. Does not address any key questions
Morgan-Davies J, King AJ, Aspinall P, O’Brien CJ. Measurement of a novel optic disc topographic parameter, "spikiness", in glaucoma. Graefes Arch Clin Exp Ophthalmol. 2000;238(8):669-76. [pmid: 11011687]. Does not address any key questions
Morgan-Davies J, Taylor N, Hill AR, Aspinall P, O’Brien CJ, Azuara-Blanco A. Three dimensional analysis of the lamina cribrosa in glaucoma. Br J Ophthalmol. 2004;88(10):1299-304. [pmid: 15377555]. Does not address any key questions
Mosaed S, Chamberlain WD, Liu JH, Medeiros FA, Weinreb RN. Association of central corneal thickness and 24-hour intraocular pressure fluctuation. J Glaucoma. 2008;17(2):85-8. [pmid: 18344752]. Does not address any key questions
Mota FJ, Shafranoy G. COMPARISON OF FREQUENCY DOUBLING TECHNOLOGY AND SWEDISH INTERACTIVE TECHNOLOGY ALGORTHM PERIMETRY. IOVS. 2000;41. ARVO Abstract 1505. Abstract only
Moura CRd, Mello PAdA, Prata JA J•nior. Scanning laser polarimetry in glaucomatous and nonglaucomatous Brazilian subjects. Arq. Bras. Oftalmol. 2003;66(6):749-54. Foreign language
Mukesh BN, McCarty CA, Rait JL, Taylor HR. Five-year incidence of open-angle glaucoma: the visual impairment project. Ophthalmology. 2002;109(6):1047-51. [pmid: 12045042]. Does not address any key questions
Mwanza JC, Oakley JD, Budenz DL, Anderson DR. Ability of cirrus HD-OCT optic nerve head parameters to discriminate normal from glaucomatous eyes. Ophthalmology. 2011;118(2):241-8.e1. [pmid: 20920824]. It does not address the adequate population
Nakano T, Tatemichi M, Miura Y, Sugita M, Kitahara K. Long-term physiologic changes of intraocular pressure: a 10-year longitudinal analysis in young and middle-aged Japanese men. Ophthalmology. 2005;112(4):609-16. [pmid: 15808252]. Does not address any key questions
Nam YP, Park SB, Kang SY, Sung KR, Kook MS. Glaucoma diagnostic performance of humphrey matrix and standard automated perimetry. Jpn J Ophthalmol. 2009;53(5):482-5. [pmid: 19847602]. Other (specify): non standard analysis of data
Nazemi P, Fink W, Sadun AA, Minckler DS, Francis BA. EARLY DETECTION OF GLAUCOMA BY A NOVEL COMPUTER AUTOMATED 3-D VISUAL FIELD TEST. American Academy of Ophthalmology. 2001:159-60. Does not address any key questions
Nemesure B, Honkanen R, Hennis A, Wu SY, Leske MC. Incident open-angle glaucoma and intraocular pressure. Ophthalmology. 2007;114(10):1810-5. [pmid: 17583352]. Does not address any key questions
Nesterov AP, Dzhafarli TB, Illarionova AR. Use of transpalpebral tonometry in the estimation of intraocular pressure in patients with refractory anomaly before and after keratophotorefraction interventions. Vestn Oftalmol. 2007;123(6):41-3. [pmid: 18225526]. Foreign language
Ng D, Zangwill LM, Racette L, Bowd C, Pascual JP, Bourne RR, Boden C, Weinreb RN, Sample PA. Agreement and repeatability for standard automated perimetry and confocal scanning laser ophthalmoscopy in the diagnostic innovations in glaucoma study. Am J Ophthalmol. 2006;142(3):381-6. [pmid: 16935580]. Data not abstractable
Nguyen NX, Horn FK, Hayler J, Wakili N, Junemann A, Mardin CY. Retinal nerve fiber layer measurements using laser scanning polarimetry in different stages of glaucomatous optic nerve damage. Graefes Arch Clin Exp Ophthalmol. 2002;240(8):608-14. [pmid: 12192453]. Does not address any key questions
Nguyen RL, Raja SC, Traboulsi EI. Screening relatives of patients with familial chronic open angle glaucoma. Ophthalmology. 2000;107(7):1294-7. [pmid: 10889100]. Does not address any key questions
Nicolela MT, Martinez-Bello C, Morrison CA, LeBlanc RP, Lemij HG, Colen TP, Chauhan BC. Scanning laser polarimetry in a selected group of patients with glaucoma and normal controls. Am J Ophthalmol. 2001;132(6):845-54. [pmid: 11730647]. Non-commercially available analysis of data
Niessen AG, Langerhorst CT, Geijssen HC, Greve EL. Design of low cost glaucoma screening. Doc Ophthalmol. 97; 93(4):293-315. Does not address any key questions
Nirmalan PK, Katz J, Robin AL, Ramakrishnan R, Krishnadas R, Thulasiraj RD, Tielsch JM. Female reproductive factors and eye disease in a rural south Indian population: The Aravind Comprehensive Eye Survey. Invest. Ophthalmol. Vis. Sci. 2004;45(12):4273-4276. [pmid: 15557432]. Does not examine candidate screening tests for glaucoma
Nirmalan PK, Katz J, Robin AL, Ramakrishnan R, Krishnadas R, Thulasiraj RD, Tielsch JM. Female reproductive factors and eye disease in a rural south Indian population: The Aravind Comprehensive Eye Survey. Invest. Ophthalmol. Vis. Sci. 2004;45(12):4273-4276. [pmid: 15557432]. Other (specify): prevalence study
Nishimura K, Iwase A, Tomita G, Yamamoto T, Kitazawa Y. Temporal modulation transfer function in normal-tension glaucoma patients. Jpn J Ophthalmol. 98; 42(2):146-51. Does not address any key questions
Nizankowska MH Kaczmarek R Prevalance of open angle glaucoma and ocular hypertension as a risk factor for primary open angle glaucoma in Wroclaw population. Wroclaw Epidemiology Study Klin Oczna 20041061–2 Suppl 147 52 15510479 Foreign language
Nizankowska MH, Kaczmarek R. Prevalence of glaucoma in the wroclaw population. The wroclaw epidemiological study. Ophthalmic Epidemiol. 2005;12(6):363-71. [pmid: 16283988]. Does not address any key questions
Nizankowska MH, Kaczmarek R, Jakubaszko J. Detection level of glaucoma and ocular hypertension in Wroclaw population - Wroclaw Epidemiological Study. Poziom wykrywalnosci jaskry i nadcisnienia ocznego w populacji wroclawskiej - Wroclawskie Badania Epidemiologiczne. Adv. Clin. Exp. Med. 2004;13(4):607-613. Foreign language
de Carvalho Nogueira Nilce Maria. Perimetria manual e perimetria autombtica (Perimetron) no glaucoma: estudo comparativo. Rev. bras. oftalmol. 89; 48(5):338-47. [pmid: 14330514]. Foreign language
Nolan WP, Ganzorig S, Undraa A, Uranchimeg D, Baasanhu J, Johnson GJ. ANDOMIZED CONTROLLED TRIAL OF SCREENING FOR PRIMARY ANGLE-CLOSURE IN MONGOLIA. IOVS. 2000:41. ARVO Abstract 2530. Abstract only
Nomoto H, Matsumoto C, Takada S, Hashimoto S, Arimura E, Okuyama S, Shimomura Y. Detectability of glaucomatous changes using SAP, FDT, flicker perimetry, and OCT. J Glaucoma. 2009;18(2):165-71. [pmid: 19225357]. Data not abstractable
Nordmann JP, Brion F, Hamard P, Mouton-Chopin D. Evaluation of the SITA Standard and SITA Fast perimetric algorithms in normals and glaucoma patients. Journal Francais D’Ophtalmologie. 98; 21(8):549-554. Foreign language
Nordmann JP, Mesbah M, Berdeaux G. Scoring of visual field measured through Humphrey perimetry: principal component varimax rotation followed by validated cluster analysis. Invest Ophthalmol Vis Sci. 2005;46(9):3169-76. [pmid: 16123416]. Data not abstractable
Norskov K. Glaucoma screening. II. A five-year follow-up carried through in relation to a glaucoma screening among members of the volunteer donor corps of the Island of Falster (Denmark). Acta Ophthalmol (Copenh). 70; 48(3):418-33. Does not address any key questions
Norskov K. Routine tonometry for detection of glaucoma in in-patients, with a five-year follow-up. Acta Ophthalmol (Copenh). 67; 45(4):536-45. Does not address any key questions
Norskov K. Routine tonometry in ophthalmic practice. II. Five-year follow-up. Acta Ophthalmol (Copenh). 70; 48(5):873-95. Does not address any key questions
North RV, Jones AL, Hunter E, Morgan JE, Wild JM. Evaluation of the high specificity Screening Program (C-20–1) of the Frequency Doubling Technology (FDT) perimeter in clinical practice. Eye (Lond). 2006;20(6):681-7. [pmid: 15999135]. Does not address any key questions
Nouri-Mahdavi K, Hoffman D, Tannenbaum DP, Law SK, Caprioli J. Identifying early glaucoma with optical coherence tomography. Am J Ophthalmol. 2004;137(2):228-35. [pmid: 14962410]. Other: OCT II
Ntim-Amponsah CT, Amoaku WM, Ofosu-Amaah S, Ewusi RK, Idirisuriya-Khair R, Nyatepe-Coo E, Adu-Darko M. Prevalence of glaucoma in an African population. Eye (Lond). 2004;18(5):491-7. [pmid: 15131680]. Does not address any key questions
Nukada M, Hangai M, Mori S, Nakano N, Nakanishi H, Ohashi-Ikeda H, Nonaka A, Yoshimura N. Detection of localized retinal nerve fiber layer defects in glaucoma using enhanced spectral-domain optical coherence tomography. Ophthalmology. 2011;118(6):1038-48. [pmid: 21514958]. Is a case series of less than 100 participants/eyes
Oddone F, Centofanti M, Rossetti L, Iester M, Fogagnolo P, Capris E, Manni G. Exploring the Heidelberg Retinal Tomograph 3 diagnostic accuracy across disc sizes and glaucoma stages: a multicenter study. Ophthalmology. 2008;115(8):1358-65. 1365.e1. 3. [pmid: 18321579]. Non-commercially available analysis of data
Odland M, Aasved H. Follow-up of initially nonglaucomatous patients with fibrillopathia epitheliocapsularis (so-called senile exfoliation of the anterior lens capsule). Acta Ophthalmol Suppl. 73; 120:77-81. Does not address any key questions
O’Donoghue E, Hitchings R, et al. The pattern of electroretinogram (PERG) and glaucoma screening [abstract]. Ir-J-Med-Sci. 91; 160(10):323. Abstract only
Onal S, Yenice O, Cakir S, Temel A. FACT contrast sensitivity as a diagnostic tool in glaucoma: FACT contrast sensitivity in glaucoma. Int Ophthalmol. 2008;28(6):407-12. [pmid: 18000646]. Does not address any key questions
Ong LS, Mitchell P, Healey PR, Cumming RG. Asymmetry in optic disc parameters: the Blue Mountains Eye Study. Invest Ophthalmol Vis Sci. 99; 40(5):849-57. Does not address any key questions
Osaki TH, Kasahara N, Paolera MD, Cohen R, Nishiwaki-Dantas MC. Presentation of glaucoma in an urban tertiary care hospital in South America: Legal blindness and prevalence. Int. Ophthalmol. 2010;30(4):361-366. [pmid: 20182768]. Does not address any key questions
Oshitari T, Fujimoto N, Hanawa K, Adachi-Usami E, Roy S. Effect of chronic hyperglycemia on intraocular pressure in patients with diabetes. Am J Ophthalmol. 2007;143(2):363-5. [pmid: 17258539]. Does not address any key questions
Ourgaud M. Static circular perimetry in open-angle glaucoma. LA PERIMETRIE CIRCULAIRE STATIQUE DANS LE GLAUCOME CHRONIQUE A ANGLE OUVERT. J. FR. OPHTALMOL. 82; 5(6–7):387-391. Foreign language
Ozdek SC, Onol M, Hasanreisoglu B. Nerve fiber layer assessment with scanning laser polarimetry in glaucoma patients and glaucoma suspects. Eur J Ophthalmol. 2001;11(2):139-44. [pmid: 11456014]. Does not address any key questions
Ozturk F, Yavas GF, Kusbeci T, Ermis SS. A comparison among Humphrey field analyzer, Microperimetry, and Heidelberg Retina Tomograph in the evaluation of macula in primary open angle glaucoma. J Glaucoma. 2008;17(2):118-21. [pmid: 18344757]. Does not address any key questions
Pablo LE, Ferreras A, Schlottmann PG. Retinal nerve fibre layer evaluation in ocular hypertensive eyes using optical coherence tomography and scanning laser polarimetry in the diagnosis of early glaucomatous defects. Br J Ophthalmol. 2011;95(1):51-5. [pmid: 20576777]. It does not address the adequate population
Pache M, Wilmsmeyer S, Lautebach S, Funk J. Dynamic contour tonometry versus Goldmann applanation tonometry: a comparative study. Graefes Arch Clin Exp Ophthalmol. 2005;243(8):763-7. [pmid: 15756572]. Data not abstractable
Paczka JA, Friedman DS, Quigley HA, Barron Y, Vitale S. Diagnostic capabilities of frequency-doubling technology, scanning laser polarimetry, and nerve fiber layer photographs to distinguish glaucomatous damage. Am J Ophthalmol. 2001;131(2):188-97. [pmid: 11228294]. Does not examine candidate screening tests for glaucoma
Pankow LJ, Pryor JL, Luchins DJ. Glaucoma screening of patients with and without dementia. J Evid Based Soc Work. 2009;6(1):29-39. [pmid: 19199135]. Does not address any key questions
Pankow LJ, Pryor JL, Luchins DJ. Glaucoma screening of patients with and without dementia. J Evid Based Soc Work. 2009;6(1):29-39. [pmid: 19199135]. Other: not a screening device
Papadia M, Sofianos C, Iester M, Bricola G, Mete M, Traverso CE. Corneal thickness and visual field damage in glaucoma patients. Eye (Lond). 2007;21(7):943-7. [pmid: 16645628]. Does not address any key questions
Parikh RS, Parikh SR, Thomas R. Diagnostic capability of macular parameters of Stratus OCT 3 in detection of early glaucoma. Br J Ophthalmol. 2010;94(2):197-201. [pmid: 19493860]. Uses single test to diagnose glaucoma
Parikh R, Muliyil J, George R, Bhat S, Thomas R. Repeatability of frequency doubling technology perimetry (20–1 screening program) and the effect of pupillary dilatation on interpretation. Ophthalmic Epidemiol. 2008;15(1):42-6. [pmid: 18300088]. Does not address any key questions
Park HJ, Caprioli J. Circumferential profiles of peripapillary surface height with confocal scanning laser ophthalmoscopy. Korean J Ophthalmol. 97; 11(1):7-14. Infrequently used device: outdated
Park HJ, Caprioli J. Circumferential profiles of peripapillary surface height with confocal scanning laser ophthalmoscopy. Korean J Ophthalmol. 97; 11(1):7-14. Other: outdated device
Patel A, Wollstein G, Ishikawa H, Schuman JS. Comparison of Glaucomatous Visual Field Defects Using Matrix Perimetry and Swedish Interactive Thresholding Algorithm (SITA) Perimetry. IOVS. 2005;46. ARVO E-abstract 3721. Abstract only
Paterson G. A nine-year follow-up of studies on first-degree relatives of patients with glaucoma simplex. Trans Ophthalmol Soc U K. 70; 90:515-25. Does not address any key questions
Paterson G. A nine-year follow-up of studies on first-degree relatives of patients with glaucoma simplex. Trans Ophthalmol Soc U K. 70; 90:515-25. No original data (e.g., systematic review, narrative review, editorial, letter)
Peeters A, Schouten JSAG, Webers CAB, Prins MH, Hendrikse F, Severens JL. Cost-effectiveness of early detection and treatment of ocular hypertension and primary open-angle glaucoma by the ophthalmologist. Eye. 2008;22(3):354-362. [pmid: 17128205]. Does not address any key questions
Peeters H, Debeer Ph, Groenen P, Van Esch H, Vanderlinden G, Eyskens B, Mertens L, Gewillig M, Van De Ven W, Fryns JP, Devriendt K. Inheritance of open-angle glaucoma in the Barbados family study. Am. J. Med. Genet. 2001;103(1):36-43. [pmid: 11562932]. Does not address any key questions
Peeters H, Debeer Ph, Groenen P, Van Esch H, Vanderlinden G, Eyskens B, Mertens L, Gewillig M, Van De Ven W, Fryns JP, Devriendt K. Inheritance of open-angle glaucoma in the Barbados family study. Am. J. Med. Genet. 2001;103(1):36-43. [pmid: 11562932]. Does not examine candidate screening tests for glaucoma
Pennebaker GE, Stewart WC. Temporal visual field in glaucoma: a re-evaluation in the automated perimetry era. Graefes Arch Clin Exp Ophthalmol. 92; 230(2):111-4. Does not address any key questions
Perez-Inigo A, Polo V, Larrosa JM, Ferreras A, Sanchez-Cano A, Martinez-de-la-Casa JM, Honrubia FM. Correlation between standard automated perimetry global indices and Heidelberg Retina Tomograph II parameters. Arch Soc Esp Oftalmol. 2007;82(7):401-11. [pmid: 17647115]. Does not address any key questions
Perkins ES. The Bedford glaucoma survey. I. Long-term follow-up of borderline cases. Br J Ophthalmol. 73; 57(3):179-85. Does not address any key questions
Perkins ES. The Bedford glaucoma survey. I. Long-term follow-up of borderline cases. Br J Ophthalmol. 73; 57(3):179-85. It does not address the adequate population
Perkins ES. The Bedford glaucoma survey. II. Rescreening of normal population. Br J Ophthalmol. 73; 57(3):186-92. Does not address any key questions
Perkins ES. The Bedford glaucoma survey. II. Rescreening of normal population. Br J Ophthalmol. 73; 57(3):186-92. Other (specify): REscreeniing
Perls E, Borrass R, Ondategui JC, Goqi J. SITA VS STANDARD PERIMETRY IN GLAUCOMA: A COMPARATIVE STUDY. American Academy of Optometry. 97:114. Abstract only
Pierre Filho PTP, Schimiti RB, Vasconcellos JP, Costa VP. Sensitivity and Specificity of Frequency Doubling Technology, Tendency Oriented Perimetry, SITA Standard, and SITA Fast in Patients Undergoing Automated Perimetry for the First Time. IOVS. 2005;46. ARVO E-abstract 3723. Abstract only
Pitz S, Kramann C, Krummenauer F, Pitz A, Trabert G, Pfeiffer N. Is homelessness a risk factor for eye disease? Results of a German screening study. Ophthalmologica. 2005;219(6):345-349. [pmid: 16286793]. Does not address any key questions
Plange N, Remky A, Huber K, Hendricks S, Arend O. Contrast sensitivity, blue-yellow-perimetry and retinal hemodynamic during the treatment of glaucoma. Ophthalmologe. 2001;98(Suppl 1):S138-9. Foreign language
Plummer DJ, Lopez A, Azen SP, LaBree L, Bartsch DU, Sadun AA, Freeman WR. Correlation between static automated and scanning laser entoptic perimetry in normal subjects and glaucoma patients. Ophthalmology. 2000;107(9):1693-701. [pmid: 10964832]. Infrequently used device: entoptic perimetry
Poli A, Strouthidis NG, Ho TA, Garway-Heath DF. Analysis of HRT images: comparison of reference planes. Invest Ophthalmol Vis Sci. 2008;49(9):3970-5. [pmid: 18469180]. Does not address any key questions
Polo Llorens V, Pablo Julvez LE, Pinilla Lozano I, Larrosa Poves JM, Ruiz Moreno O, Honrubia Lopez FM. Short-wavelength automated perimetry (SWAP) in patients with suspected glaucoma (II): correlation with a probabilistic multifactorial model of risk for developing glaucomatous damage. Arch Soc Esp Oftalmol. 2000;75(2):97-102. [pmid: 11151127]. It does not address the adequate population
Polo Llorens V, Pablo Julvez LE, Pinilla Lozano I, Larrosa Poves JM, Ruiz Moreno O, Honrubia Lopez FM. Short-wavelength automated perimetry (SWAP) in patients with suspected glaucoma (II): correlation with a probabilistic multifactorial model of risk for developing glaucomatous damage. Arch Soc Esp Oftalmol. 2000;75(2):97-102. [pmid: 11151127]. Other (specify): All subjects abnormal- no normal controls
Polo V, Abecia E, Pablo LE, Pinilla I, Larrosa JM, Honrubia FM. Functional and structural measurements in a multifactorial glaucoma risk model. Acta Ophthalmol Scand. 2001;79(1):10-4. [pmid: 11167278]. Does not address any key questions
Polo V, Abecia E, Pablo LE, Pinilla I, Larrosa JM, Honrubia FM. Short-wavelength automated perimetry and retinal nerve fiber layer evaluation in suspected cases of glaucoma. Arch Ophthalmol. 98; 116(10):1295-8. Does not address any key questions
Polo V, Larrosa JM, Pinilla I, Pablo L, Honrubia FM. Optimum criteria for short-wavelength automated perimetry. Ophthalmology. 2001;108(2):285-9. [pmid: 11158800]. Non-commercially available analysis of data
Pons ME, Ishikawa H, Gurses-Ozden R, Liebmann JM, Dou HL, Ritch R. Assessment of retinal nerve fiber layer internal reflectivity in eyes with and without glaucoma using optical coherence tomography. Arch Ophthalmol. 2000;118(8):1044-7. [pmid: 10922196]. Does not address any key questions
Postaire JG, Hache JC, Diaf M. Fully automated screening procedure for early detection of visual field defects. J Biomed Eng. 86; 8(2):156-61. Infrequently used device
Pueyo V, Larrosa JM, Polo V, Perez-Inigo A, Ferreras A, Honrubia FM. Sector-based analysis of the distribution of the neuroretinal rim by confocal scanning laser in the diagnosis of glaucoma. Arch Soc Esp Oftalmol. 2006;81(3):135-40. [pmid: 16572356]. Foreign language
Pueyo V, Polo V, Larrosa JM, Ferreras A, Martinez-de-la-Casa JM, Honrubia FM. Diagnostic usefulness of optical coherence tomography (OCT), scanning laser tomography (HRT-II) and laser polarimetry (GDx) in open-angle glaucoma. Arch Soc Esp Oftalmol. 2006;81(12):693-700. [pmid: 17199163]. Foreign language
Punjabi OS, Stamper RL, Bostrom AG, Han Y, Lin SC. Topographic comparison of the visual function on multifocal visual evoked potentials with optic nerve structure on heidelberg retinal tomography. Ophthalmology. 2008;115(3):440-6. [pmid: 18096233]. Does not address any key questions
Qi S, Jiang Y. Short-wavelength perimetry in diagnosis of early glaucoma: comparison with standard automated perimetry. Zhonghua Yan Ke Za Zhi. 2002;38(1):31-5. [pmid: 11955298]. Foreign language
Quigley HA, West SK, Rodriguez J, Munoz B, Klein R, Snyder R. The prevalence of glaucoma in a population-based study of Hispanic subjects: Proyecto VER. Arch Ophthalmol. 2001;119(12):1819-26. [pmid: 11735794]. Does not address any key questions
Rabin S, Kolesar P, Podos SM, Wilensky JT. A visual field screening protocol for glaucoma. Am J Ophthalmol. 81; 92(4):630-5. Does not use clinical assessment as reference standard
Ramakrishnan R, Nirmalan PK, Krishnadas R, Thulasiraj RD, Tielsch JM, Katz J, Friedman DS, Robin AL. Glaucoma in a rural population of southern India: the Aravind comprehensive eye survey. Ophthalmology. 2003;110(8):1484-90. [pmid: 12917161]. Does not address any key questions
Ramirez AM, Chaya CJ, Gordon LK, Giaconi JA. A comparison of semiautomated versus manual Goldmann kinetic perimetry in patients with visually significant glaucoma. J Glaucoma. 2008;17(2):111-7. [pmid: 18344756]. Does not address any key questions
Ramrattan RS, Wolfs RC, Panda-Jonas S, Jonas JB, Bakker D, Pols HA, Hofman A, de Jong PT. Prevalence and causes of visual field loss in the elderly and associations with impairment in daily functioning: the Rotterdam Study. Arch Ophthalmol. 2001;119(12):1788-94. [pmid: 11735788]. Does not address any key questions
Rao HL, Babu GJ, Sekhar GC. Comparison of the diagnostic capability of the Heidelberg Retina Tomographs 2 and 3 for glaucoma in the Indian population. Ophthalmology. 2010;117(2):275-81. [pmid: 19969365]. Testing in-house scoring system only
Rasmussen KE, Jorgensen HA. Diagnostic value of the water-drinking test in early detection of simple glaucoma. Acta Ophthalmol (Copenh). 76; 54(2):160-6. Does not address any key questions
Raulli A, Johnston R, Petherick E, Hollingsworth B. Multifocal multichannel objective perimetry (Structured abstract). Medical Services Advisory Committee. 2002:51. No original data (e.g., systematic review, narrative review, editorial, letter)
Raychaudhuri A, Lahiri SK, Bandyopadhyay M, Foster PJ, Reeves BC, Johnson GJ. A population based survey of the prevalence and types of glaucoma in rural West Bengal: the West Bengal Glaucoma Study. Br J Ophthalmol. 2005;89(12):1559-64. [pmid: 16299129]. Does not address any key questions
Realini T, Lai MQ, Barber L. Impact of diabetes on glaucoma screening using frequency-doubling perimetry. Ophthalmology. 2004;111(11):2133-6. [pmid: 15522382]. Does not address any key questions
Regan D, Neima D. Balance between pattern and flicker sensitivities in the visual fields of ophthalmological patients. Br J Ophthalmol. 84; 68(5):310-5. Does not address any key questions
Regiec P, Nizankowska MH. Evaluation of acquired color vision defects by means of the two equation method in primary open-angle glaucoma with normal pressure and in patients from the risk group. Klinika oczna. 97; 99(4):245-8. Does not address any key questions
Regine F, Scuderi GL, Cesareo M, Ricci F, Cedrone C, Nucci C. Validity and limitations of the Nidek NT-4000 non-contact tonometer: A clinical study. Ophthalmic Physiol. Opt. 2006;26(1):33-39. [pmid: 16390480]. Does not address any key questions
Ren B-C, He Y, Chen L, Yang J-G, Sun N-X. Epidemiology of glaucoma in a rural population in Shaanxi Province. Int. J. Ophthalmol. 2005;5(5):1037-1042. Foreign language
Reus NJ, Lemij HG. Scanning laser polarimetry of the retinal nerve fiber layer in perimetrically unaffected eyes of glaucoma patients. Ophthalmology. 2004;111(12):2199-203. [pmid: 15582074]. Does not address any key questions
Robin TA, Muller A, Rait J, Keeffe JE, Taylor HR, Mukesh BN. Performance of community-based glaucoma screening using Frequency Doubling Technology and Heidelberg Retinal Tomography. Ophthalmic Epidemiol. 2005;12(3):167-78. [pmid: 16036475]. Data not abstractable
Rodriguez-Maimon EB, Ferreras A, Polo V, Larrosa JM, Alias E, Honrubia FM. Evaluation of four new discriminant functions for HRT II in glaucoma diagnosis. Evaluacion de cuatro nuevas funciones discriminantes del HRT II para el diagnostico del glaucoma. Arch. Soc. Esp. Oftalmol. 2008;83(6):349-356. [pmid: 18521767]. Foreign language
Rohrschneider K, Burk RO, Kruse FE, Volcker HE. Reproducibility of the optic nerve head topography with a new laser tomographic scanning device. Ophthalmology. 94; 101(6):1044-9. Does not address any key questions
Rosenthal AR, Perkins ES. Family studies in glaucoma. Br J Ophthalmol. 85; 69(9):664-7. Does not address any key questions
Rossetti L, Fogagnolo P, Mazzolani F, Incarnato N, Orzalesi N. Detection of Early Glaucoma With FDT and SWAP: The Results of a Longitudinal Study. IOVS. 2005;46. ARVO E-abstract 2486. Abstract only
Rouhiainen H, Terasvirta M. Incidence of open-angle glaucoma and screening of the intraocular pressure with a non-contact tonometer. Acta Ophthalmol (Copenh). 90; 68(3):344-6. Does not address any key questions
Rowe FJ, Sueke H, Gawley SD. Comparison of Damato campimetry and Humphrey automated perimetry results in a clinical population. Br J Ophthalmol. 2010;94(6):757-62. [pmid: 20447958]. Infrequently used device: Damato campimetry
Ruben ST, Arden GB, O’Sullivan F, Hitchings RA. Pattern electroretinogram and peripheral colour contrast thresholds in ocular hypertension and glaucoma: Comparison and correlation of results. BR. J. OPHTHALMOL. 95; 79(4):326-331. Does not examine candidate screening tests for glaucoma
Sah RP, Badhu BP, Pokharel PK, Thakur SK, Das H, Panda A. Prevalence of glaucoma in Sunsari district of eastern Nepal. Kathmandu Univ Med J (KUMJ). 2007;5(3):343-8. [pmid: 18604052]. Does not address any key questions
Sakata K, Sakata LM, Sakata VM, Santini C, Hopker LM, Bernardes R, Yabumoto C, Moreira ATR. Prevalence of glaucoma in a South Brazilian population: Projeto glaucoma. Invest. Ophthalmol. Vis. Sci. 2007;48(11):4974-4979. [pmid: 17962447]. Does not address any key questions
Sakata LM, DeLeon JO, Arthur SN, Girkin CA. Detecting Visual Function Abnormalities in Patients With Glaucomatous Optic Neuropathy Using Matrix Frequency-Doubling Perimetry and SITA-Standard Perimetry. IOVS. 2006;47. ARVO E-abstract 1125. Abstract only
Salgarello T, Colotto A, Valente P, Petrocelli G, Galan ME, Scullica L, Falsini B. Posterior pole retinal thickness in ocular hypertension and glaucoma: early changes detected by hemispheric asymmetries. J Glaucoma. 2005;14(5):375-83. [pmid: 16148586]. Data not abstractable
Sampaolesi R, Sampaolesi JR. Correlation between the intraocular pressure according to daily pressure curves and optic disc changes in patients with open-angle glaucoma with normal visual fields. Lasers Light Ophthalmol. 98; 8(3):179-185. Does not address any key questions
Sample PA, Weinreb RN. Color perimetry for assessment of primary open-angle glaucoma. Invest Ophthalmol Vis Sci. 90; 31(9):1869-75. Does not address any key questions
Sample PA, Bosworth CF, Weinreb RN. Short-wavelength automated perimetry and motion automated perimetry in patients with glaucoma. ARCH. OPHTHALMOL. 97; 115(9):1129-1133. Does not address any key questions
Sample PA, Bosworth CF, Blumenthal EZ, Girkin C, Weinreb RN. Visual function-specific perimetry for indirect comparison of different ganglion cell populations in glaucoma. Invest Ophthalmol Vis Sci. 2000;41(7):1783-90. [pmid: 10845599]. Data not abstractable
Samson D, Aronson N. Retinal nerve fiber layer analysis for the diagnosis and management of glaucoma (Provisional abstract). Blue Cross and Blue Shield Association, Technology Evaluation Center. 2003:32. No library is able to supply this item
Sanchez-Cano A, Baraibar B, Pablo LE, Honrubia F. Scanning laser polarimetry with variable corneal compensation to detect preperimetric glaucoma using logistic regression analysis. Ophthalmologica. 2009;223(4):256-62. [pmid: 19299907]. Infrequently used device
Sanchez-Galeana C, Bowd C, Blumenthal EZ, Gokhale PA, Zangwill LM, Weinreb RN. Using optical imaging summary data to detect glaucoma. Ophthalmology. 2001;108(10):1812-8. [pmid: 11581054]. Other: HRT-GDX
Sanfilippo PG, Cardini A, Sigal IA, Ruddle JB, Chua BE, Hewitt AW, Mackey DA. A geometric morphometric assessment of the optic cup in glaucoma. Exp Eye Res. 2010;91(3):405-14. [pmid: 20599965]. Does not use clinical assessment as reference standard
Santos RMO, Cronemberger S, Vieira Filho HM, Calixto N. Estudo comparativo das diferen gas entre as estratqgias dinGmica e normal com o perÆmetro Octopus 1-2-3. Arq. Bras. Oftalmol. 1999;62(6):727-30. Foreign language
Sato S, Hirooka K, Baba T, Yano I, Shiraga F. Correlation between retinal nerve fibre layer thickness and retinal sensitivity. Acta Ophthalmol. 2008;86(6):609-13. [pmid: 18162063]. Does not address any key questions
Schappert-Kimmijser J. A five-year follow-up of subjects with intra-ocular pressure of 22–30 mm Hg without anomalies of optic nerve and visual field typical for glaucoma at first investigation. Ophthalmologica. 71; 162(4):289-95. Does not address any key questions
Scherrer M, Fleischhauer JC, Helbig H, Johann Auf Der Heide K, Sutter FKP. Comparison of tendency-oriented perimetry and dynamic strategy in octopus perimetry as a screening tool in a clinical setting: A prospective study. Klin. Monatsbl. Augenheilkd. 2007;224(4):252-254. [pmid: 17458786]. Does not use clinical assessment as reference standard
Schiefer U, Pascual J, Sample P, Edmunds B, Weleber R, Johnson C, Staubach F, Lagreze W, Vonthein R, Paetzold J. Comparison of the New "German Adaptive Threshold Estimation" (GATE) Strategy With Conventional Static Threshold Estimating Perimetry and With the SITA Procedure. IOVS. 2007;48. ARVO E-Abstract 4452. Does not address any key questions
Schimiti Rui Barroso, Arcieri Enyr Saran, Avelino Rodrigo Rezende, Matsuo Tiemi, Costa Vital Paulino. Full threshold vs. Swedish interactive threshold algorithm (SITA) em pacientes glaucomatosos submetidos a perimetria computadorizada pela primeira vez. Arq. bras. oftalmol. 2006;69(2):145-150. [pmid: 16699660]. Foreign language
Schlote T, Landenberger H. Intraocular pressure difference in Goldmann applanation tonometry versus a transpalpebral tonometer TGDc-01"PRA" in glaucoma patients. Klin Monbl Augenheilkd. 2005;222(2):123-31. [pmid: 15719316]. Does not address any key questions
Schlottmann PG, Shewry JM, White ET, Ikeji FC. Garway-Heath. Comparison of the GDx VCCc, HRT II, Stratus OCT, RTA and Discam for the Detection of Glaucomatous Visual Field Defects. IOVS. 2006;47. ARVO E-abstract 3627. Abstract only
Schmeisser ET, Smith TJ. Flicker visual evoked potential differentiation of glaucoma. Optom Vis Sci. 92; 69(6):458-62. Does not address any key questions
Schneider E, Grehn F. Intraocular pressure measurement-comparison of dynamic contour tonometry and goldmann applanation tonometry. J Glaucoma. 2006;15(1):2-6. [pmid: 16378009]. Data not abstractable
Schulzer M, Drance SM, Douglas GR. A comparison of treated and untreated glaucoma suspects. Ophthalmology. 91; 98(3):301-7. Does not address any key questions
Schulzer M, Mikelberg FS, Drance SM. Some observations on the relation between intraocular pressure reduction and the progression of glaucomatous visual loss. Br J Ophthalmol. 87; 71(7):486-8. Does not address any key questions
Schulzer M. Errors in the diagnosis of visual field progression in normal-tension glaucoma. Ophthalmology. 9. 94; 101(1589):94. discussion 1595. Does not address any key questions
Schuman JS, Wollstein G, Farra T, Hertzmark E, Aydin A, Fujimoto JG, Paunescu LA. Comparison of optic nerve head measurements obtained by optical coherence tomography and confocal scanning laser ophthalmoscopy. Am J Ophthalmol. 2003;135(4):504-12. [pmid: 12654368]. Unspecified diagnosis of Glaucoma
Schwartz R, Draeger J, Wirt H, Rumberger E, Dauper J, Deutsch C. Clinical value of new tonometers. Fortschr Ophthalmol. 90; 87(1):41-4. Foreign language
Screening for glaucoma. Br Med J. 73; 3(5879):511-2. Does not address any key questions
Screening for glaucoma. Br Med J. 73; 3(5879):511-2. No original data (e.g., systematic review, narrative review, editorial, letter)
Sehi M, Pinzon-Plazas M, Feuer WJ, Greenfield DS. Relationship between pattern electroretinogram, standard automated perimetry, and optic nerve structural assessments. J Glaucoma. 2009;18(8):608-17. [pmid: 19826390]. Does not address any key questions
Seitzman G, Katz J, Robin AL. COMPARING OCULUS EASYFIELD PERIMETRY WITH FREQUENCY DOUBLING TEST AND HUMPHREY SITA-STANDARD PERIMETRY. American Academy of Ophthalmology. 2001:160. Abstract only
Shaikh A, Salmon JF. The role of scanning laser polarimetry using the GDx variable corneal compensator in the management of glaucoma suspects. Br J Ophthalmol. 2006;90(12):1454-7. [pmid: 16885189]. Does not address any key questions
Shehzad MS, Ashraf KM, Siddique M, Qazi ZA, Khan MT. Comparison between Clinical Evaluations, Stereoscopic Photographic analysis and Confocal Scanning Laser Ophthalmoscope in estimating Cup/Disc Ratio. J. Pak. Med. Assoc. 2003;53(6):225-228. Does not address any key questions
Shewry JM, Ikeji FC, White ET, Schlottmann PG, Garway-Heath DF. Comparison of the Test-Retest Variability of Neuroretinal Rim Area Measurements in Normal and Glaucoma Patients Using RTA and OCT3. IOVS. 2005;46. ARVO E-abstract 4821. Abstract only
Shin IH, Kang SY, Hong S, Kim SK, Seong GJ, Tak MK, Kim CY. Comparison of OCT and HRT findings among normal, normal tension glaucoma, and high tension glaucoma. Korean J Ophthalmol. 2008;22(4):236-41. [pmid: 19096240]. Does not address any key questions
Shiose Y, Kitazawa Y, Tsukahara S, Akamatsu T, Mizokami K, Futa R, Katsushima H, Kosaki H. Epidemiology of glaucoma in Japan--a nationwide glaucoma survey. Jpn J Ophthalmol. 91; 35(2):133-55. Does not address any key questions
Shiose Y, Kitazawa Y, Tsukahara S, Akamatsu T, Mizokami K, Futa R, Katsushima H, Kosaki H. Epidemiology of glaucoma in Japan--a nationwide glaucoma survey. Jpn J Ophthalmol. 91; 35(2):133-55. Other (specify): prevalence
Shirakashi M, Iwata K, Sawaguchi S, Abe H, Nanba K. Intraocular pressure-dependent progression of visual field loss in advanced primary open-angle glaucoma: a 15-year follow-up. Ophthalmologica. 93; 207(1):1-5. Does not address any key questions
Shunmugam M, Azuara-Blanco A. The quality of reporting of diagnostic accuracy studies in glaucoma using the Heidelberg retina tomograph. Invest Ophthalmol Vis Sci. 2006;47(6):2317-23. [pmid: 16723439]. No original data (e.g., systematic review, narrative review, editorial, letter)
Siebert M, Gramer E, Serguhn S. High mean pallor value--a risk factor for deterioration of the visual field in glaucoma and ocular hypertension. A pilot study using the optic nerve head analyzer. Der Ophthalmologe : Zeitschrift der Deutschen Ophthalmologischen Gesellschaft. 95; 92(4):506-10. Foreign language
Sihota R, Sony P, Gupta V, Dada T, Singh R. Comparing glaucomatous optic neuropathy in primary open angle and chronic primary angle closure glaucoma eyes by optical coherence tomography. Ophthalmic Physiol Opt. 2005;25(5):408-15. [pmid: 16101946]. It does not address the adequate population
Sihota R, Srinivasan G, Dada T, Gupta V, Ghate D, Sharma A. Is the ISNT rule violated in early primary open-angle glaucoma--a scanning laser tomography study. Eye (Lond). 2008;22(6):819-24. [pmid: 17435693]. Testing in-house scoring system only
Sim DH, Goh LG, Ho T. Glaucoma pattern amongst the elderly Chinese in Singapore. Ann Acad Med Singapore. 98; 27(6):819-23. Does not address any key questions
Singh GD, Kavanaugh J, Paris GR, McKinnon SJ. COMPARISON OF CHROMATIC FREQUENCY DOUBLING PERIMETRY AND THE SITA-STANDARD HUMPHREY VISUAL FIELD. American Academy of Ophthalmology. 2001:159. Abstract only
Skorin L Jr, Multack RF, Holtzman JN. Health fair glaucoma screening: follow-up evaluation. J Am Osteopath Assoc. 91; 91(7):671-4. Does not address any key questions
Skorkovska K, Skorkovska S, Michalek J, Koci J, Synek S. Structural analysis of the optic nerve head in healthy eyes and in eyes with glaucoma. Cesk Slov Oftalmol. 2004;60(6):400-7. [pmid: 15745408]. Foreign language
Skorkovska S, Michalek J, Sedlacik M, Maskova Z, Koci J. Correlation of the Heidelberg retinal tomograph, evaluation of the retinal nerve fiber layer and perimetry in the diagnosis of glaucoma. Cesk Slov Oftalmol. 2007;63(6):403-14. [pmid: 18062164]. Foreign language
Smith DA, Trope GE. New-generation portable tonometers: comparison of the Keta and Goldmann tonometers. Can J Ophthalmol. 89; 24(7):308-10. Does not address any key questions
Soliman MA, de Jong LA, Ismaeil AA, van den Berg TJ, de Smet MD. Standard achromatic perimetry, short wavelength automated perimetry, and frequency doubling technology for detection of glaucoma damage. Ophthalmology. 2002;109(3):444-54. [pmid: 11874745]. Data not abstractable
Soliman MA, Van Den Berg TJ, Ismaeil AA, De Jong LA, De Smet MD. Retinal nerve fiber layer analysis: relationship between optical coherence tomography and red-free photography. Am J Ophthalmol. 2002;133(2):187-95. [pmid: 11812421]. Infrequently used device: OLD OCT 2000
Sommer A, Katz J, Quigley HA, Miller NR, Robin AL, Richter RC, Witt KA. Clinically detectable nerve fiber atrophy precedes the onset of glaucomatous field loss. Arch Ophthalmol. 91; 109(1):77-83. Does not address any key questions
Sommer A, Miller NR, Pollack I, Maumenee AE, George T. The nerve fiber layer in the diagnosis of glaucoma. Arch Ophthalmol. 77; 95(12):2149-56. Does not address any key questions
Sommer A, Miller NR, Pollack I, Maumenee AE, George T. The nerve fiber layer in the diagnosis of glaucoma. Arch Ophthalmol. 77; 95(12):2149-56. Other (specify): is not screening
Sommer A, Pollack I, Maumenee AE. Optic disc parameters and onset of glaucomatous field loss. II. Static screening criteria. Arch Ophthalmol. 79; 97(8):1449-54. Does not address any key questions
Sommer A. Glaucoma screening: too little, too late?. J Gen Intern Med. 90; 5(5 Suppl):S33-7. Does not address any key questions
Sommer A. Glaucoma screening: too little, too late?. Gen Intern Med. 90; 5(5 Suppl):S33-7. Other (specify): ***REFERENCE*Summary no new data
Sorensen PN, Nielsen NV, Norskov K. Ocular hypertension. A 15-year follow-up. Acta Ophthalmol (Copenh). 78; 56(3):363-72. Does not address any key questions
Sponsel WE, Orcutt JC, Heuer DK, Brennan MW, Trigo Y. AAO/VFW Screening Results 1998–2001: Frequency Doubling vs Tonometry for Detection of Glaucomatous Field Loss and Optic Neuropathy. American Academy of Ophthalmology. 2002:139. Abstract only
Sponsel WE, Paris G, Trigo Y, Pena M. IOP, POBF, and Visual Responses to Unoprostone and Latanoprost in Open Angle Glaucoma. American Glaucoma Society. 2002:57. Abstract only
Spry PG, Henson DB, Sparrow JM, North RV. Quantitative comparison of static perimetric strategies in early glaucoma: test-retest variability. Journal of glaucoma. 2000;9(3):247-53. [pmid: 10877376]. Does not address any key questions
Spry PG, Hussin HM, Sparrow JM. Clinical evaluation of frequency doubling technology perimetry using the Humphrey Matrix 24–2 threshold strategy. Br J Ophthalmol. 2005;89(8):1031-5. [pmid: 16024860]. Does not address any key questions
Stefan C, Dumitrica DM, Tebeanu E, Cristea I, Sapundgieva A, Dragomir L, Cerbulescu B, Gheorghieva V. Macular involvement in glaucoma. Oftalmologia. 2008;52(3):98-101. [pmid: 19149127]. Foreign language
Stein DM, Ishikawa H, Hariprasad R, Wollstein G, Noecker RJ, Fujimoto JG, Schuman JS. A new quality assessment parameter for optical coherence tomography. Br J Ophthalmol. 2006;90(2):186-90. [pmid: 16424531]. Does not address any key questions
Stein J, Girkin CA, Harizman N, Arthur S, Chiang A, Ortega JD, Liebmann JM, Tello C, Ritch R. A Comparison of False-Positive Test Results Between the Stratus OCT III and the GDx-VCC. IOVS. 2005;46. ARVO E-abstract 3635. Abstract only
Stoutenbeek R, Jansonius NM. Glaucoma screening during regular optician visits: can the population at risk of developing glaucoma be reached?. Br J Ophthalmol. 2006;90(10):1242-4. [pmid: 16854829]. Does not address any key questions
Stoutenbeek R, de Voogd S, Wolfs RC, Hofman A, de Jong PT, Jansonius NM. The additional yield of a periodic screening programme for open-angle glaucoma: a population-based comparison of incident glaucoma cases detected in regular ophthalmic care with cases detected during screening. Br J Ophthalmol. 2008;92(9):1222-6. [pmid: 18723743]. Other (specify):
Strouthidis NG, Scott A, Peter NM, Garway-Heath DF. Optic disc and visual field progression in ocular hypertensive subjects: detection rates, specificity, and agreement. Invest Ophthalmol Vis Sci. 2006;47(7):2904-10. [pmid: 16799032]. Does not address any key questions
Stroux A, Martus P, Budde W, Horn F, Junemann A, Korth M, Jonas JB. Sequential classification in glaucoma diagnosis. Graefes Arch Clin Exp Ophthalmol. 2003;241(4):277-83. [pmid: 12719988]. Data not abstractable
Su DH, Wong TY, Wong WL, Saw SM, Tan DT, Shen SY, Loon SC, Foster PJ, Aung T. Diabetes, hyperglycemia, and central corneal thickness: the Singapore Malay Eye Study. Ophthalmology. 2008;115(6):964-968.e1. [pmid: 17964654]. Does not address any key questions
Sugimoto M, Ito K, Goto R, Uji Y. Symmetry analysis for detecting early glaucomatous changes in ocular hypertension using optical coherence tomography. Jpn J Ophthalmol. 2004;48(3):281-6. [pmid: 15175923]. Data not abstractable
Sugimoto M, Ito K, Goto R, Uji Y. Symmetry analysis for detecting early glaucomatous changes in ocular hypertension using optical coherence tomography. Jpn J Ophthalmol. 2004;48(3):281-6. [pmid: 15175923]. Does not address any key questions
Sung VC, Koppens JM, Vernon SA, Pawson P, Rubinstein M, King AJ, Tattersall CL. Longitudinal glaucoma screening for siblings of patients with primary open angle glaucoma: the Nottingham Family Glaucoma Screening Study. Br J Ophthalmol. 2006;90(1):59-63. [pmid: 16361669]. Does not address any key questions
Suzanna R J•nior, Takahashi WY, Almada AT, Hirai A. Degrau nasal de roenne. Seu estudo no glaucoma cronico simples. Rev. Bras. Oftalmol. 1981;40(4):290-3. Foreign language
Suzuki Y, Yamamoto T, Araie M, Iwase A, Tomidokoro A, Abe H, Shirato S, Kuwayama Y, Mishima HK, Shimizu H, Tomita G, Inoue Y, Kitazawa Y. Tajimi Study review. Nippon Ganka Gakkai Zasshi. 2008;112(12):1039-58. [pmid: 19157025]. Foreign language
Swamy B, Cumming RG, Ivers R, Clemson L, Cullen J, Hayes MF, Tanzer M, Mitchell P. Vision screening for frail older people: a randomised trial. The British journal of ophthalmology. 2009;93(6):736-41. [pmid: 18614568]. Does not address any key questions
Swamy B, Cumming RG, Ivers R, Clemson L, Cullen J, Hayes MF, Tanzer M, Mitchell P. Vision screening for frail older people: a randomised trial. The British journal of ophthalmology. 2009;93(6):736-41. [pmid: 18614568]. It does not address the adequate population
Tafreshi A, Racette L, Weinreb RN, Sample PA, Zangwill LM, Medeiros FA, Bowd C. Pattern electroretinogram and psychophysical tests of visual function for discriminating between healthy and glaucoma eyes. Am J Ophthalmol. 2010;149(3):488-95. [pmid: 20172073]. Infrequently used device: electroretinogram
Takahashi G, Aoki Y, Koike T, Nakano T, Kitahara K, Demirel S, Johnson CA. The Influence of Instruction on Frequency Doubling Technology Perimetry and Humphrey Matrix Results in Normals and Early Glaucoma Patients. IOVS. 2005;46. ARVO E-abstract 2482. Abstract only
Takahashi H, Goto T, Shoji T, Tanito M, Park M, Chihara E. Diabetes-associated retinal nerve fiber damage evaluated with scanning laser polarimetry. Am J Ophthalmol. 2006;142(1):88-94. [pmid: 16815255]. Data not abstractable
Tan JC, Hitchings RA. Optimizing and validating an approach for identifying glaucomatous change in optic nerve topography. Invest Ophthalmol Vis Sci. 2004;45(5):1396-403. [pmid: 15111594]. Does not address any key questions
Tan JC, Poinoosawmy D, Hitchings RA. Tomographic identification of neuroretinal rim loss in high-pressure, normal-pressure, and suspected glaucoma. Invest Ophthalmol Vis Sci. 2004;45(7):2279-85. [pmid: 15223806]. Does not address any key questions
Tan O, Chopra V, Lu AT, Schuman JS, Ishikawa H, Wollstein G, Varma R, Huang D. Detection of macular ganglion cell loss in glaucoma by Fourier-domain optical coherence tomography. Ophthalmology. 14.e1. 2009;116(12):2305-2. [pmid: 19744726]. Does not address any key questions
Tan O, Li G, Lu AT, Varma R, Huang D. Mapping of macular substructures with optical coherence tomography for glaucoma diagnosis. Ophthalmology. 2008;115(6):949-56. [pmid: 17981334]. Does not address any key questions
Tatemichi M, Nakano T, Tanaka K, Hayashi T, Nawa T, Miyamoto T, Hiro H, Sugita M. Possible association between heavy computer users and glaucomatous visual field abnormalities: a cross sectional study in Japanese workers. J Epidemiol Community Health. 2004;58(12):1021-7. [pmid: 15547065]. Does not address any key questions
Tatemichi M, Nakano T, Tanaka K, Hayashi T, Nawa T, Miyamoto T, Hiro H, Iwasaki A, Sugita M. Performance of glaucoma mass screening with only a visual field test using frequency-doubling technology perimetry. Am J Ophthalmol. 2002;134(4):529-37. [pmid: 12383809]. Data not abstractable
Tchabi S, Doutetien C, Amoussouga A, Babagbeto M, Lawani R, Deguenon J, Bassabi SK. Intraocular pressure in the Benin: screening for primary open-angle glaucoma. J Fr Ophtalmol. 2005;28(6):623-6. [pmid: 16141927]. Foreign language
Teesalu P, Airaksinen PJ, Tuulonen A. Blue-on-yellow visual field and retinal nerve fiber layer in ocular hypertension and glaucoma. Ophthalmology. 98; 105(11):2077-81. Does not address any key questions
Teesalu P, Vihanninjoki K, Airaksinen PJ, Tuulonen A. Hemifield association between blue-on-yellow visual field and optic nerve head topographic measurements. Graefes Arch Clin Exp Ophthalmol. 98; 236(5):339-45. Does not address any key questions
Teesalu P, Vihanninjoki K, Airaksinen PJ, Tuulonen A, Laara E. Correlation of blue-on-yellow visual fields with scanning confocal laser optic disc measurements. Invest Ophthalmol Vis Sci. 97; 38(12):2452-9. Does not address any key questions
Teixeira RMB, Satyro U, Almeida HGd. Reprodutibilidade da topografia do disco £ptico. Rev. Bras. Oftalmol. 2003;62(6):430-5. Foreign language
Teixeira Roberto MB, de Almeida Homero GusmPo, Garcia Danielle CS. Perimetria de FreqnWncia Dobrada (Frequency Doubling Technology - FDT) e o Campo Visual Computadorizado (Humphrey Field Analiser - HFA). Rev. bras. oftalmol. 2004;63(4):251-257. Foreign language
Thomas R, Bhat S, Muliyil JP, Parikh R, George R. Frequency doubling perimetry in glaucoma. J Glaucoma. 2002;11(1):46-50. [pmid: 11821689]. It does not address the adequate population
Thomas R, Parikh R, George R, Kumar RS, Muliyil J. Five-year risk of progression of ocular hypertension to primary open angle glaucoma. A population-based study. Indian J Ophthalmol. 2003;51(4):329-33. [pmid: 14750621]. Does not address any key questions
Thomas R, Parikh R, Muliyil J, Bhat S, George R. Validation of test duration as a screening criterion for frequency doubling perimetry. Am J Ophthalmol. 2004;137(3):562-3. [pmid: 15013885]. Infrequently used device: duration of test
Thulasiraj RD, Nirmalan PK, Ramakrishnan R, Krishnadas R, Manimekalai TK, Baburajan NP, Katz J, Tielsch JM, Robin AL. Blindness and vision impairment in a rural south Indian population: the Aravind Comprehensive Eye Survey. Ophthalmology. 2003;110(8):1491-8. [pmid: 12917162]. Does not address any key questions
Tielsch JM, Sommer A, Katz J, Royall RM, Quigley HA, Javitt J. Racial variations in the prevalence of primary open-angle glaucoma: The Baltimore eye survey. J. AM. MED. ASSOC. 91; 266(3):369-374. Does not address any key questions
Tjon-Fo-Sang MJ, De Vries J, Lemij HG. Measurement by nerve fiber analyzer of retinal nerve fiber layer thickness in normal subjects and patients with ocular hypertension. AM. J. OPHTHALMOL. 96; 122(2):220-227. Does not address any key questions
Toker MI, Vural A, Erdogan H, Topalkara A, Arici MK. Central corneal thickness and Diaton transpalpebral tonometry. Graefes Arch Clin Exp Ophthalmol. 2008;246(6):881-9. [pmid: 18286299]. Does not address any key questions
Tong LT, Lai MM, Azen SP, Varma R. Screening for glaucoma and other ocular disease using SITA standard and full threshold Humphrey visual field tests: The Los Angeles Latino Eye Study (LALES). IOVS. 2002;43. ARVO E-abstract 2177. Abstract only
Tonkin D. The early diagnosis of glaucoma. Med J Aust. 66; 2(23):1112-5. Data not abstractable
Topouzis F, Harris A, Wilson MR, Koskosas A, Founti P, Yu F, Anastasopoulos E, Pappas T, Coleman AL. Increased likelihood of glaucoma at the same screening intraocular pressure in subjects with pseudoexfoliation: the Thessaloniki Eye Study. Am J Ophthalmol. 2009;148(4):606-613.e1. [pmid: 19427989]. Does not address any key questions
Topouzis F, Wilson MR, Harris A, Anastasopoulos E, Yu F, Mavroudis L, Pappas T, Koskosas A, Coleman AL. Prevalence of open-angle glaucoma in Greece: the Thessaloniki Eye Study. Am J Ophthalmol. 2007;144(4):511-9. [pmid: 17893012]. Does not address any key questions
Toth M, Kothy P, Hollo G. Accuracy of scanning laser polarimetry, scanning laser tomography, and their combination in a glaucoma screening trial. J Glaucoma. 2008;17(8):639-46. [pmid: 19092459]. Other (specify): normal population was not evaluated with complete exam
Toth M, Kothy P, Vargha P, Hollo G. Accuracy of combined GDx-VCC and matrix FDT in a glaucoma screening trial. J Glaucoma. 2007;16(5):462-70. [pmid: 17700289]. Data not abstractable
Touboul D, Roberts C, Kerautret J, Garra C, Maurice-Tison S, Saubusse E, Colin J. Correlations between corneal hysteresis, intraocular pressure, and corneal central pachymetry. J Cataract Refract Surg. 2008;34(4):616-22. [pmid: 18361984]. Does not address any key questions
Townsend KA, Wollstein G, Danks D, Sung KR, Ishikawa H, Kagemann L, Gabriele ML, Schuman JS. Heidelberg Retina Tomograph 3 machine learning classifiers for glaucoma detection. Br J Ophthalmol. 2008;92(6):814-8. [pmid: 18523087]. Non-commercially available analysis of data
Trapani LF. OCT y nuevas tqcnicas diagn£sticas en la evaluaci£n del glaucoma. OSL, Oftalmol. St. LucÆa. 2009;8(2):38-52. Foreign language
Troost A, Grunz C, Troost R, Grus FH, Pfeiffer N, Schwenn O. Agreement between clinical evaluation, Heidelberg-Retina-Tomograph (HRT) and Nerve Fiber Analyzer (GDx) in glaucoma diagnosis. Klin Monbl Augenheilkd. 2004;221(9):757-61. [pmid: 15459843]. Foreign language
Tuck MW, Crick RP. Efficiency of referral for suspected glaucoma. BMJ. 91; 302(6783):998-1000. Does not examine candidate screening tests for glaucoma
Tuck MW, Crick RP. Relative effectiveness of different modes of glaucoma screening in optometric practice. Ophthalmic Physiol Opt. 93; 13(3):227-32. Does not examine candidate screening tests for glaucoma
Tuck MW, Crick RP. Screening for glaucoma: age and sex of referrals and confirmed cases in England and Wales. Ophthalmic Physiol Opt. 92; 12(4):400-4. Does not address any key questions
Tuck MW, Crick RP. Screening for glaucoma: the time taken by primary examiners to conduct visual field tests in practice. Ophthalmic Physiol Opt. 94; 14(4):351-5. Does not address any key questions
Turno-Krecicka A, Nizankowska MH, Pacholska D. Results of screening for primary glaucoma from data in materials from the Medical Diagnostic Center DOLMED in Wroclaw. Klin Oczna. 97; 99(3):179-83. Foreign language
Tzamalis A, Kynigopoulos M, Schlote T, Haefliger I. Improved reproducibility of retinal nerve fiber layer thickness measurements with the repeat-scan protocol using the Stratus OCT in normal and glaucomatous eyes. Graefes Arch Clin Exp Ophthalmol. 2009;247(2):245-52. [pmid: 18810480]. Does not address any key questions
Ugurlu S, Hoffman D, Garway-Heath DF, Caprioli J. Relationship between structural abnormalities and short-wavelength perimetric defects in eyes at risk of glaucoma. Am J Ophthalmol. 2000;129(5):592-8. [pmid: 10844049]. Does not address any key questions
Vajaranant TS, Price MO, Price FW, Wilensky JT, Edward DP. Intraocular pressure measurements following Descemet stripping endothelial keratoplasty. Am J Ophthalmol. 2008;145(5):780-6. [pmid: 18329627]. Does not address any key questions
Varma DK, Artes PH, Nicolela MT, LeBlanc RP, Chauhan BC. Comparison of Three Psychophysical Tests for Detecting Glaucomatous Visual Field Progression. IOVS. 2003. ARVO E-abstract 43. Abstract only
Ventura MP, Vianna RNG, Solari HP, Yamane R. Eletrorretinograma com est Æmulo padrPo (PERG) no diagn£stico do glaucoma inicial. Rev. Bras. Oftalmol. 2002;61(10):703-13. Foreign language
Ventura MP, Solari HP, Alonso RS, Ambrosio R Jr. Standard Achromatic Perimetry, Short Wavelength Automated Perimetry, and Pattern Electroretinography in the Diagnosis of Early Glaucoma. IOVS. 2006;47. ARVO E-abstract 4013. Abstract only
Vernon SA, Ghosh G. Do locally agreed guidelines for optometrists concerning the referral of glaucoma suspects influence referral practice?. Eye. 2001;15(4):458-463. [pmid: 11767019]. Does not address any key questions
Vernon SA, Ghosh G. Do locally agreed guidelines for optometrists concerning the referral of glaucoma suspects influence referral practice?. Eye. 2001;15(4):458-463. [pmid: 11767019]. Does not examine candidate screening tests for glaucoma
Vernon SA, Henry DJ, Cater L, Jones SJ. Screening for glaucoma in the community by nonophthalmologically trained staff using semi automated equipment. EYE. 90; 4(1):89-97. Other: not all subjects clinically evaluated
Vernon SA, Henry DJ, Cater L, Jones SJ. Screening for glaucoma in the community by nonophthalmologically trained staff using semi automated equipment. EYE. 90; 4(1):89-97. Other: Not all subjects evaluated with exam
Vihanninjoki K, Teesalu P, Burk RO, Laara E, Tuulonen A. Airaksinen PJSearch for an optimal combination of structural and functional parameters for the diagnosis of glaucoma. Multivariate analysis of confocal scanning laser tomograph, blue-on-yellow visual field and retinal nerve fiber layer data. Graefes Arch Clin Exp Ophthalmol. 2000;238(6):477-81. [pmid: 10943670]. Non-commercially available analysis of data
Vijaya L, George R, Baskaran M, Arvind H, Raju P, Ramesh SV, Kumaramanickavel G, McCarty C. Prevalence of primary open-angle glaucoma in an urban south Indian population and comparison with a rural population. The Chennai Glaucoma Study. Ophthalmology. 2008;115(4):648-654.e1. [pmid: 17664010]. Does not address any key questions
Vimolchalao N, Fontana H, Hoffman DC, Caprioli J. Comparison of Frequency Doubling Perimetry (Humphrey Matrix) to Short Wave Length Automated Perimetry for the Early Detection of Glaucoma. IOVS. 2006;47. ARVO E-abstract 3992. Abstract only
Vistamehr S, Shelsta HN, Palmisano PC, Filardo G, Bashford K, Chaudhri K, Forster SH, Shafranov G, Bruce Shields M. Glaucoma screening in a high-risk population. J Glaucoma. 2006;15(6):534-40. [pmid: 17106368]. Data not abstractable
Vitale S, Smith TD, Quigley T, Kerrigan-Baumrind TA, Pease TE, Varma R, Friedman TS, Katz J, Tielsch JM. Screening performance of functional and structural measurements of neural damage in open-angle glaucoma: a case-control study from the Baltimore Eye Survey. J Glaucoma. 2000;9(5):346-56. [pmid: 11039735]. Does not examine candidate screening tests for glaucoma
Vodovozov AM, Boriskina LN. Significance of intolerance indicators in glaucoma. Oftalmol Zh. 85(1):36-8. Foreign language
Vulsteke C, Stalmans I, Fieuws S, Zeyen T. Correlation between ocular pulse amplitude measured by dynamic contour tonometer and visual field defects. Graefes Arch Clin Exp Ophthalmol. 2008;246(4):559-65. [pmid: 18193267]. Data not abstractable
Wadood AC, Azuara-Blanco A, Taguri A, King AJW, Aspinall P. Sensitivity and specificity of program C-20 of frequency doubling technology (FDT), tendency oriented perimetry (TOP) and SITA-Fast (HSF) in glaucoma. IOVS. 2001;42. ARVO Abstract 794. Non-commercially available analysis of data
Wadood AC, Azuara-Blanco A, Aspinall P, Taguri A, King AJ. Sensitivity and specificity of frequency-doubling technology, tendency-oriented perimetry, and Humphrey Swedish interactive threshold algorithm-fast perimetry in a glaucoma practice. Am J Ophthalmol. 2002;133(3):327-32. [pmid: 11860968]. It does not address the adequate population
Wakakura M, Kageyama M, Hamanaka T, Shimizu K, Joshita H, Shimizu T, Baba H, Kisara M, Miyata M. Application of oculokinetic perimetry in examination of the eye. Nippon Ganka Gakkai Zasshi. 96; 100(7):551-7. Foreign language
Walker WM. Ocular hypertension. Follow-up of 109 cases from 1963 to 1974. Trans Ophthalmol Soc U K. 74; 94(2):525-34. Does not address any key questions
Wall M, Jennisch CS. Random dot motion stimuli are more sensitive than light stimuli for detection of visual field loss in ocular hypertension patients. Optom Vis Sci. 99; 76(8):550-7. Does not address any key questions
Wall M, Ketoff KM. Random dot motion perimetry in patients with glaucoma and in normal subjects. Am J Ophthalmol. 95; 120(5):587-96. Does not address any key questions
Wang N, Lai M, Cheng X, Ye T. Ultrasound biomicroscopic dark room provocative test. Zhonghua yan ke za zhi. Chinese journal of ophthalmology. 98; 34(3):183-6. 12. Foreign language
Wang YX, Xu L, Zhang RX, Jonas JB. Frequency-doubling threshold perimetry in predicting glaucoma in a population-based study: The Beijing Eye Study. Arch Ophthalmol. 2007;125(10):1402-6. [pmid: 17923550]. Does not use clinical assessment as reference standard
Wang Y, Xu L, Jonas JB. Prevalence and causes of visual field loss as determined by frequency doubling perimetry in urban and rural adult Chinese. Am J Ophthalmol. 2006;141(6):1078-1086. [pmid: 16765676]. Does not address any key questions
Wanger P, Persson HE. Pattern-reversal electroretinograms and high-pass resolution perimetry in suspected or early glaucoma. OPHTHALMOLOGY. 87; 94(9):1098-1103. Does not address any key questions
Wanger P, Persson HE. Pattern-reversal electroretinograms and high-pass resolution perimetry in suspected or early glaucoma. OPHTHALMOLOGY. 87; 94(9):1098-1103. Does not examine candidate screening tests for glaucoma
Weih LM, Nanjan M, McCarty CA, Taylor HR. Prevalence and predictors of open-angle glaucoma: results from the visual impairment project. Ophthalmology. 2001;108(11):1966-72. [pmid: 11713063]. Does not address any key questions
Weinreb RN, Shakiba S, Zangwill L. Scanning laser polarimetry to measure the nerve fiber layer of normal and glaucomatous eyes. Am J Ophthalmol. 95; 119(5):627-36. Does not address any key questions
Weinreb RN, Zangwill L, Berry CC, Bathija R, Sample PA. Detection of glaucoma with scanning laser polarimetry. Arch Ophthalmol. 98; 116(12):1583-9. Other (specify): outdated device
Weinreb RN, Zangwill L, Berry CC, Bathija R, Sample PA. Detection of glaucoma with scanning laser polarimetry. Arch Ophthalmol. 98; 116(12):1583-9. Other (specify): Outdated device
Wells AP, Garway-Heath DF, Poostchi A, Wong T, Chan KC, Sachdev N. Corneal hysteresis but not corneal thickness correlates with optic nerve surface compliance in glaucoma patients. Invest Ophthalmol Vis Sci. 2008;49(8):3262-8. [pmid: 18316697]. Does not address any key questions
Werner DL, Field S. A mammoth vision screening--public relations and public service. J Am Optom Assoc. 82; 53(9):731-7. Does not address any key questions
Westcott MC, Fitzke FW, Hitchings RA. Abnormal motion displacement thresholds are associated with fine scale luminance sensitivity loss in glaucoma. Vision Res. 98; 38(20):3171-80. Does not address any key questions
Wild JM, Moss ID, Whitaker D, O’Neill EC. The statistical interpretation of blue-on-yellow visual field loss. Invest Ophthalmol Vis Sci. 95; 36(7):1398-410. Does not address any key questions
Wild JM, Pacey IE, Hancock SA, Cunliffe IA. Between-algorithm, between-individual differences in normal perimetric sensitivity: Full Threshold, FASTPAC, and SITA. Investigative Ophthalmology & Visual Science. 99; 40(6):1152-1161. Does not address any key questions
Wild JM, Pacey IE, Hancock SA, Cunliffe IA. Between-algorithm, between-individual differences in normal perimetric sensitivity: Full Threshold, FASTPAC, and SITA. Investigative Ophthalmology & Visual Science. 99; 40(6):1152-1161. It does not address the adequate population
Wilensky JT, Gieser DK, Dietsche ML, Mori MT, Zeimer R. Individual variability in the diurnal intraocular pressure curve. Ophthalmology. 93; 100(6):940-4. Does not address any key questions
Wilensky JT, Podos SM, Becker B. Prognostic indicators in ocular hypertension. Arch Ophthalmol. 74; 91(3):200-2. Does not address any key questions
Wilson MR. Progression of visual field loss in untreated glaucoma patients and suspects in St Lucia, West Indies. Trans Am Ophthalmol Soc. 2002;100:365-410. [pmid: 12545702]. Does not address any key questions
Wishart PK, Wardrop DR, Kosmin AS. Is visual field evaluation using multiple correlations and linear regressions useful? An evaluation of Delphi perimetry. Graefes Arch Clin Exp Ophthalmol. 98; 236(7):493-500. Non-commercially available analysis of data
Wolfs RCW, Borger PH, Ramrattan RS, Klaver CCW, Hulsman CAA, Hofman A, Vingerling JR, Hitchings RA, De Jong PTVM. Changing views on open-angle glaucoma: Definitions and prevalences - The Rotterdam study. Invest. Ophthalmol. Vis. Sci. 2000;41(11):3309-3320. [pmid: 11006219]. Does not address any key questions
Wolfs RCW, Dielemans I, Klaver CCW, Vingerling JR, Hofman A, De Jong PTVM. Prevalence of primary open-angle glaucoma among elderly people: The Rotterdam study. PREVALENTIE VAN PRIMAIR OPEN-KAMERHOEKGLAUCOOM BIJ OUDEREN: HET ERGO-ONDERZOEK. NED. TIJDSCHR. GENEESKD. 95; 139(44):2246-2251. Foreign language
Wollstein G, Garway-Heath DF, Hitchings RA. Identification of early glaucoma cases with the scanning laser ophthalmoscope. Ophthalmology. 98; 105(8):1557-63. Non-commercially available analysis of data
Wroblewski D, Francis BA, Chopra V, Kawji AS, Quiros P, Dustin L, Massengill RK. Glaucoma detection and evaluation through pattern recognition in standard automated perimetry data. Graefe’s Arch. Clin. Exp. Ophthalmol. 2009;247(11):1517-1530. Non-commercially available analysis of data
Wu JS, Wang DB, Wang JH. Reliability of successive automated static perimetry. Zhonghua Yan Ke Za Zhi. 2003;39(12):731-5. [pmid: 14769224]. Foreign language
Xu L, Chen PP, Chen YY, Takahashi Y, Wang L, Mills RP. Quantitative nerve fiber layer measurement using scanning laser polarimetry and modulation parameters in the detection of glaucoma. J Glaucoma. 98; 7(4):270-7. Does not address any key questions
Xu L, Zhang L, Xia CR, Li JJ, Hu LN, Ma K, Chen YJ, Fan GZ, Song WX, Shi YY, Zhang SY, Sun BC. The prevalence and its effective factors of primary angle-closure glaucoma in defined populations of rural and urban in Beijing. Zhonghua Yan Ke Za Zhi. 2005;41(1):8-14. [pmid: 15774106]. Foreign language
Yagci R, Eksioglu U, Midillioglu I, Yalvac I, Altiparmak E, Duman S. Central corneal thickness in primary open angle glaucoma, pseudoexfoliative glaucoma, ocular hypertension, and normal population. Eur J Ophthalmol. 2005;15(3):324-8. [pmid: 15944999]. Data not abstractable
Yalvac IS, Altunsoy M, Cansever S, Satana B, Eksioglu U, Duman S. The correlation between visual field defects and focal nerve fiber layer thickness measured with optical coherence tomography in the evaluation of glaucoma. J Glaucoma. 2009;18(1):53-61. [pmid: 19142136]. Does not use clinical assessment as reference standard
Yalvac IS, Kulacoglu DN, Satana B, Eksioglu U, Duman S. Correlation between optical coherence tomography results and the Scoring Tool for Assessing Risk (STAR) score in patients with ocular hypertension. Eur J Ophthalmol. 2010;20(6):1018-25. [pmid: 20544677]. Does not address any key questions
Yamada N, Chen PP, Mills RP, Leen MM, Lieberman MF, Stamper RL, Stanford DC. Screening for glaucoma with frequency-doubling technology and Damato campimetry. Arch Ophthalmol. 99; 117(11):1479-84. Infrequently used device campimetry
Yamada N, Chen PP, Mills RP, Leen MM, Stamper RL, Lieberman MF, Xu L, Stanford DC. Glaucoma screening using the scanning laser polarimeter. J Glaucoma. 2000;9(3):254-61. [pmid: 10877377]. Other: gdx
Yamazaki S, Baba H, Inoue Y. Study of follow-up period and provocative tests for diagnosis of primary open-angle glaucoma. Nippon Ganka Gakkai Zasshi. 91; 95(7):692-7. Foreign language
Yamazaki Y, Mizuki K, Hayamizu F, Tanaka C. Correlation of blue chromatic macular sensitivity with optic disc change in early glaucoma patients. Jpn J Ophthalmol. 2002;46(1):89-94. [pmid: 11853721]. Does not address any key questions
Yamazaki Y, Tanaka C, Hayamizu F, Mizuki K. Correlation between blue chromatic macular sensitivity and optic disc change in early glaucoma patients. Nippon Ganka Gakkai Zasshi. 2001;105(11):776-80. [pmid: 11758347]. Does not address any key questions
Yang CC, Wang IJ, Chang YC, Lin LL, Chen TH. A predictive model for postoperative intraocular pressure among patients undergoing laser in situ keratomileusis (LASIK). Am J Ophthalmol. 2006;141(3):530-536. [pmid: 16490501]. Does not address any key questions
Yip LW, Mikelberg FS. A comparison of the glaucoma probability score to earlier heidelberg retina tomograph data analysis tools in classifying normal and glaucoma patients. J Glaucoma. 2008;17(7):513-6. [pmid: 18854725]. Non-commercially available analysis of data
Yoshiyama KK, Johnson CA. WHICH METHOD OF FLICKER PERIMETRY IS MOST EFFECTIVE FOR DETECTION OF GLAUCOMATOUS VISUAL FIELD LOSS?. American Academy of Optometry. 96:25. Infrequently used device
Young IM, Rait JL, Guest CS, Carson CA, Taylor HR. Comparison between Fastpac and conventional Humphrey perimetry. Aust N Z J Ophthalmol. 94; 22(2):95-9. Does not address any key questions
Zafar S, Makornwattana M, Gurses-Ozden R, Vessani RM, Liebmann JM, Tello C, Ritch R. Scanning Protocol Choice Affects Optical Coherence Tomography (OCT-3) Measurements. IOVS. 2003. ARVO E-abstract 3361. Abstract only
Zangwill LM, Weinreb RN, Beiser JA, Cioffi GA, Coleman AL, Trick G, Liebmann JM, Kass MA, Gordon MO. OHTS CSLO. Ancillary Study Group. Baseline Topographic Optic Disc Measurements Are Associated With the Development of Primary Open Angle Glaucoma: The Confocal Scanning Laser Ophthalmoscopy Ancillary Study to the OHTS. IOVS. 2005;46. ARVO E-abstract 3631. Does not address any key questions
Zangwill LM, Berry CC, Weinreb RN. Optic disc topographic measurements after pupil dilation. Ophthalmology. 99; 106(9):1751-5. Does not address any key questions
Zangwill LM, Bowd C, Berry CC, Williams J, Blumenthal EZ, Sanchez-Galeana CA, Vasile C, Weinreb RN. Discriminating between normal and glaucomatous eyes using the Heidelberg Retina Tomograph, GDx Nerve Fiber Analyzer, and Optical Coherence Tomograph. Arch Ophthalmol. 2001;119(7):985-93. [pmid: 11448320]. Infrequently used device: outdated devices
Zangwill LM, Chan K, Bowd C, Hao J, Lee TW, Weinreb RN, Sejnowski TJ, Goldbaum MH. Heidelberg retina tomograph measurements of the optic disc and parapapillary retina for detecting glaucoma analyzed by machine learning classifiers. Invest Ophthalmol Vis Sci. 2004;45(9):3144-51. [pmid: 15326133]. Non-commercially available analysis of data
Zangwill LM, van Horn S, de Souza Lima M, Sample PA, Weinreb RN. Optic nerve head topography in ocular hypertensive eyes using confocal scanning laser ophthalmoscopy. Am J Ophthalmol. 96; 122(4):520-5. Does not address any key questions
Zangwill LM, Weinreb RN, Beiser JA, Berry CC, Cioffi GA, Coleman AL, Trick G, Liebmann JM, Brandt JD, Piltz-Seymour JR, Dirkes KA, Vega S, Kass MA, Gordon MO. Baseline topographic optic disc measurements are associated with the development of primary open-angle glaucoma: The Confocal Scanning Laser Ophthalmoscopy Ancillary Study to the Ocular Hypertension Treatment Study. Arch. Ophthalmol. 2005;123(9):1188-1197. [pmid: 16157798]. Does not address any key questions
Zangwill LM, Weinreb RN, Berry CC, Smith AR, Dirkes KA, Liebmann JM, Brandt JD, Trick G, Cioffi GA, Coleman AL, Piltz-Seymour JR, Gordon MO, Kass MA. The confocal scanning laser ophthalmoscopy ancillary study to the ocular hypertension treatment study: study design and baseline factors. Am J Ophthalmol. 2004;137(2):219-27. [pmid: 14962409]. Does not address any key questions
Zangwill LM, Williams J, Berry CC, Knauer S, Weinreb RN. A comparison of optical coherence tomography and retinal nerve fiber layer photography for detection of nerve fiber layer damage in glaucoma. Ophthalmology. 2000;107(7):1309-15. [pmid: 10889104]. Does not address any key questions
Zangwill LM, Williams J, Berry CC, Knauer S, Weinreb RN. A comparison of optical coherence tomography and retinal nerve fiber layer photography for detection of nerve fiber layer damage in glaucoma. Ophthalmology. 2000;107(7):1309-15. [pmid: 10889104]. Other (specify): reliability only
Zelefsky JR, Harizman N, Mora R, Ilitchev E, Tello C, Ritch R, Liebmann JM. Assessment of a race-specific normative HRT-III database to differentiate glaucomatous from normal eyes. J Glaucoma. 2006;15(6):548-51. [pmid: 17106370]. Does not use clinical assessment as reference standard
Zeppieri M, Brusini P, Miglior S. Corneal thickness and functional damage in patients with ocular hypertension. Eur J Ophthalmol. 2005;15(2):196-201. [pmid: 15812759]. Does not address any key questions
Zhang H, Xu L, Chen C, Jonas JB. Central corneal thickness in adult ChineseAssociation with ocular and general parameters. The Beijing Eye Study. Graefes Arch Clin Exp Ophthalmol. 2008;246(4):587-92. [pmid: 18196258]. Does not address any key questions
Zhang MZ, Fu ZF, Liu XR, Zheng C. A comparison study of pulsitile ocular blood flow in normal eyes and primary open angle glaucoma. Zhonghua Yan Ke Za Zhi. 2004;40(4):250-3. [pmid: 15268833]. Foreign language
Zhang Y, Wu LL, Yang YF. Potential of stratus optical coherence tomography for detecting early glaucoma in perimetrically normal eyes of open-angle glaucoma patients with unilateral visual field loss. J Glaucoma. 2010;19(1):61-5. [pmid: 20075675]. Other (specify): Not useful data
Zhao J, Sui R, Jia L, Ellwein LB. Prevalence of glaucoma and normal intraocular pressure among adults aged 50 years or above in Shunyi county of Beijing. Zhonghua Yan Ke Za Zhi. 2002;38(6):335-9. [pmid: 12139808]. Foreign language
Zhong Y, Ye W, Gao J, Yu F, Wang K. Comparitive study of the threshold variability between blue-on-yellow perimetry and white-on-white perimetry. Yan Ke Xue Bao. 2002;18(2):87-91. [pmid: 15510643]. Foreign language
Zubareva TV, Zaretskaya RB. Value of some functional and tonometric methods of study for the early diagnosis of glaucoma. Vestn Oftalmol. 71; 4:26-9. Foreign language