# ICD-9 Classification

Definition | Snellen Fractions/Decimals | Visual Fields | Clinical Assessment; Count Fingers, Hand Movement, Light Perception
NORMAL VISION | 20/10 20/13 20/16 20/20 20/25 2.0 1.6 1.25 1.0 0.8
NEAR-NORMAL VISION | 20/30 20/40 20/50 20/60 0.7 0.6 0.5 0.4 0.3
MODERATE VISUAL IMPAIRMENT | 20/70 20/80 20/100 20/125 20/160 0.25 0.20 0.16 0.12
SEVERE VISUAL IMPAIRMENT | 20/200 20/250 20/320 20/400 0.10 0.08 0.06 0.05 | Visual field: 20 degrees or less
PROFOUND VISUAL IMPAIRMENT BLINDNESS | 20/500 20/630 20/800 20/1000 0.04 0.03 0.025 0.02 | Visual field: 10 degrees or less | Count fingers at less than 3m (10 ft)
NEAR-TOTAL VISUAL IMPAIRMENT | Visual acuity: less than 0.02 | Visual field: 5 degrees or less (One or both eyes) | Both eyes: Count fingers: 1m (3 ft) or less Hand movements: 5m (15 ft) or less Light projection, light perception
TOTAL VISUAL IMPAIRMENT | | | Total blindness No light perception (NLP)

Visual acuity refers to best achievable acuity with correction.

Non-listed Snellen fractions may be classified by converting to the nearest decimal equivalent, e.g. 10/200 = 0.05, 6/30 = 0.20.

CF (count fingers) without designation of distance, may be classified to profound impairment.

HM (hand motion) without designation of distance, may be classified to near-total impairment.

Visual field measurements refer to the largest