# Search Strategy

## Glaucoma Screening 10-06-11

### PUBMED

(“Ocular Hypertension”[mh] OR “ocular hypertension”[tiab] OR “Intraocular Pressure”[mh] OR “intraocular pressure”[tiab] OR “glaucoma, open-angle” [mh] OR “Open angle glaucoma” [tiab] OR “low tension glaucoma” [tiab] OR “normal tension glaucoma” [tiab] OR “pseudoexfoliative glaucoma” [tiab] OR “pseudoexfoliative syndrome” [tiab]) AND (screening[tiab] OR “early diagnosis”[mh] OR “tomography, optical coherence”[mh] OR tomography[tiab] OR OCT OR “tonometry, ocular” [mh] OR perimetry[tiab] OR HRT[tiab] OR “Heidelberg retina tomograph” [tiab] OR “scanning laser polarimetry”[tiab]) AND (“Cohort Studies”[Mesh] OR “Case-Control Studies”[Mesh] OR randomized controlled trial [pt] OR controlled clinical trial [pt] OR randomized [tiab] OR placebo [tiab] OR drug therapy [sh] OR randomly [tiab] OR trial [tiab] OR groups [tiab]) NOT (animals [mh] NOT humans [mh]) 3147 titles

### EMBASE

(‘intraocular hypertension’/exp OR ‘ocular hypertension’:ab,ti OR ‘intraocular pressure’/exp OR ‘intraocular pressure’:ab,ti OR ‘open angle glaucoma’/exp OR ‘open angle glaucoma’:ti,ab OR ‘low tension glaucoma’:ti,ab OR ‘normal tension glaucoma’:ti,ab OR ‘pseudoexfoliative glaucoma’:ti,ab OR ‘pseudoexfoliative syndrome’:ab,ti) AND (‘screening’:ab,ti OR ‘early diagnosis’/exp OR ‘optical coherence tomography’/exp OR ‘tomography’:ab,ti OR ‘oculoplethysmography’/exp OR perimetry:ab,ti OR hrt:ab,ti OR ‘Heidelberg retina tomograph ‘:ti,ab OR ‘scanning laser polarimetry’:ti,ab OR oct:ab,ti) AND (‘randomized controlled trial’:pt OR ‘controlled clinical trial’:pt OR randomized:ab OR placebo:ab OR ‘clinical trial’/exp OR randomly:ab OR trial:ti OR ‘cohort analysis’/exp OR ‘case control study’/exp) NOT (animals/exp NOT humans/exp) 810 titles

### LILACS

glaucoma$ AND (‘screening’$ OR ‘early diagnosis’$ OR ‘optical coherence tomography’$ OR ‘tomography’$ OR ‘oculoplethysmography’$ OR perimetry$ OR hrt$ OR ‘Heidelberg retina tomograph ‘$ OR ‘scanning laser polarimetry’$ OR oct) 60 titles

### COCHRANE

glaucoma AND (‘screening’ OR ‘early diagnosis’ OR ‘optical coherence tomography’ OR ‘tomography’ OR ‘oculoplethysmography’ OR perimetry OR hrt OR ‘Heidelberg retina tomograph ‘ OR ‘scanning laser polarimetry’ OR oct) 410 titles