# Appendixes

Appendix A Search Strategy

Appendix B Screening and Data Abstraction Forms

Appendix C Evidence Tables

Appendix D ICD-9 Classification

Appendix E Excluded Articles

Appendix F Included Devices