# Acknowledgments

The Evidence-based Practice Center thanks Bradley Hickey, Anna Diller, and Yohalakshami Chelladurai for their assistance with reviewing articles.