# Abbreviations

AHRQ: Agency for Healthcare Research and Quality
AUC: Area under the receiver operating characteristic curve
COAG: Chronic OAG
EPC: Evidence-based Practice Center
FDT: Frequency doubling technology
GAT: Goldmann applanation tonometry
GDx: Glaucoma diagnosis
HFA: Humphrey field analyzer
HRT: Heidelberg retina tomography
IOP: Intraocular pressure
ITT: Intention to treat
logMAR: Logarithm of the minimum angle of resolution
MRA: Moorfields regression analysis
MD: Mean deviation
NEI-VQF: National Eye Institute Visual Functioning Questionnaire
NFI: Nerve fiber indicator
NCT: Noncontact tonometry
NOS: Newcastle-Ottawa Scale
OAG: Open-angle glaucoma
OCT: Optical coherence tomography
OHT: Ocular hypertension
PSD: Pattern standard deviation
QOL: Quality of life
RCT: Randomized controlled trial
RNFL: Retinal nerve fiber layer
RR: Relative risk
SAP: Standard automated perimetry
SD: Standard deviation
SITA: Swedish interactive threshold algorithm
SLP: Scanning laser polarimetry
SLT: Selective laser trabeculoplasty
SR: Systematic review
SWAP: Short wavelength automated perimetry
TSNIT: Temporal, superior, nasal, inferior, temporal
USPSTF: U.S. Preventive Services Task Force
VAS: Visual analogue scale
VCC: Variable corneal compensation
VCDR: Vertical cup to disc ratio
VF: Visual field