# Technical Expert Panel

Matthew J. Budoff, M.D.

Professor of Medicine

University of California, Los Angeles

Los Angeles, CA

Javed Butler, M.D., M.P.H.

Associate Professor of Medicine

Emory University

Atlanta, GA

Stacie Daugherty, M.D., M.S.P.H.

Assistant Professor of Cardiology

University of Colorado

Aurora, CO

John F. Heitner, M.D.

Director of Noninvasive Imaging

New York Methodist Hospital

Brooklyn, NY

Mark Hlatky, M.D.

Director, Stanford-Kaiser Cardiovascular Outcomes Research Center

Stanford University

Stanford, CA

Neil Jensen, M.B.A., M.H.A.

Director, Cardiology Networks

United HealthCare

Edina, MN

Marcel Salive, M.D., M.P.H.

Director, Division of Medical and Surgical Services

Centers for Medicare and Medicaid

Bethesda, MD

Subha V. Raman, M.D., M.S.

Cardiovascular Imaging Research Center

Ohio State University Medical Center

Columbus, OH

Malissa J. Wood, M.D.

Assistant Professor Medicine

Harvard Medical School

Boston, MA