# Summary and Discussion

For this report, we conducted a systematic review of the peer-reviewed medical literature to evaluate the accuracy of different NIT modalities for diagnosing CAD in women with symptoms suspicious for CAD.

## KQ 1: Diagnostic Accuracy of NITs

For diagnostic accuracy, we identified the following number of studies for each NIT modality:

- ECG: 41 studies (13 good quality, 22 fair, 6 poor)
- ECHO: 22 studies (8 good, 13 fair, 1 poor)
- SPECT: 30 studies (10 good, 15 fair, 5 poor)
- CMR: 6 studies (5 good quality, 1 fair)
- Coronary CTA: 8 studies (4 good, 4 fair)

We analyzed the results by study population (no known CAD and mixed CAD populations) and by study quality (good quality rating). Table 19 and Figure 41 show the summary sensitivities and specificities for each NIT modality.

Table 19 Summary of accuracy of NITs for diagnosing CAD in women

Modality | Population | Quality of Included Studies | Number of Studies | Number of Women | Summary Sensitivity (95% CI) | Summary Specificity (95% CI)
ECG | No known CAD | All | 29 | 3392 | 62% (55%–68%) | 68% (63%–73%)
ECG | No known CAD | Good | 10 | 1410 | 70% (58%–79%) | 62% (53%–69%)
ECG
ECG | Mixed population | All | 41 | 4879 | 61% (54%–67%) | 65% (58%–72%)
ECG | Mixed population | Good | 13 | 1679 | 65% (52%–76%) | 60% (52%–68%)
ECHO | No known CAD | All | 14 | 1286 | 79% (74%–83%) | 83% (74%–89%)
ECHO | No known CAD | Good | 5 | 561 | 79% (69%–87%) | 85% (68%–94%)
ECHO
ECHO | Mixed population | All | 22 | 1873 | 78% (73%–83%) | 86% (79%–91%)
ECHO | Mixed population | Good | 8 | 807 | 77% (65%–85%) | 89% (76%–95%)
SPECT | No known CAD | All | 14 | 1000 | 81% (76%–86%) | 78% (69%–84%)
SPECT | No known CAD | Good | 4 | 394 | 83% (52%–95%) | 72% (37%–92%)
SPECT
SPECT | Mixed population | All | 30 | 2146 | 82% (77%–87%) | 81% (74%–86%)
SPECT | Mixed population | Good | 10 | 982 | 82% (72%–88%) | 79% (66%–87%)
CMR | No known CAD | All | 5 | 501 | 72% (55%–85%) | 84% (69%–93%)
CMR | No known CAD | Good | 5 | 501 | 72% (55%–85%) | 84% (69%–93%)
CMR
CMR | Mixed population | All | 6 | 778 | 78% (61%–89%) | 84% (74%–90%)
CMR | Mixed population | Good | 5 | 610 | 76% (55%–89%) | 84% (72%–91%)
Coronary CTA | No known CAD | All | 5 | 474 | 93% (69%–99%) | 77% (54%–91%)
Coronary CTA | No known CAD | Good | 3 | 124 | 85% (26%–99%) | 73% (17%–97%)
Coronary CTA
Coronary CTA | Mixed population | All | 8 | 690 | 94% (81%–98%) | 87% (68%–96%)
Coronary CTA | Mixed population | Good | 4 | 201 | 83% (58%–94%) | 77%% (40%–94%)

Abbreviations: CAD = coronary artery disease; CI = confidence interval; CMR =cardiac magnetic resonance; CTA = computed tomography angiography; ECG = exercise/stress electrocardiogram; ECHO = echocardiogram; SPECT = single proton emission computed tomography

Figure 41 Summary of accuracy of NITs for diagnosing CAD in women with no known CAD (all studies)

Figure 41 shows the summary of the diagnostic accuracy of ECG, ECHO, SPECT, CMR, and coronary CTA modalities in women with no known CAD. It appeared that the diagnostic accuracy of detecting CAD in women was better (in descending order) for coronary CTA, SPECT, ECHO, CMR, and ECG. For the newer technologies (i.e., coronary CTA and CMR), more studies in women would be needed to support these findings since the 95% CIs were quite wide.

Overall, within a given modality, the summary sensitivities and specificities were similar for both types of populations (known and no known CAD) and for all studies when compared with good-quality studies. When accounting for only the good-quality studies, it appears that the diagnostic accuracy of detecting CAD in women was better (in descending order) for coronary CTA, SPECT, ECHO, CMR, and ECG. For the newer technologies (i.e., coronary CTA and CMR), more studies in women would be needed to support these findings since the 95% CIs were quite wide. In testing for a statistically significant difference between the diagnostic accuracy of testing modalities in women, our analyses determined that for women with no previously known CAD, there were differences between the performance of the available modalities (p < 0.001). The sensitivity of ECHO and SPECT was significantly greater than that of ECG. Specificity of ECG was less than that of CMR (borderline) and of ECHO. In the subset of studies that were good-quality and where there was no known CAD in the included population, our analyses again demonstrated differences between performance of tests (p = 0.006) with the specificity of ECG being less than that of CMR and ECHO.

To minimize the risk of spectrum bias, our primary analysis focused on women with no known CAD. We also explored mixed populations of women with known and no known CAD in sensitivity analyses. These analyses did not demonstrate a significant difference in terms of the sensitivities and specificities from our primary analysis. We also explored the prevalence of CAD across the different NIT modality studies. The mean prevalences and 95% CIs for ECG, SPECT, ECHO, CMR, and coronary CTA with the population of women with no previously known CAD was 0.41 (0.36 to 0.46), 0.44 (0.34 to 0.55), 0.43 (0.37 to 0.50), 0.26 (0.14 to 0.44), and 0.29 (0.13 to 0.54), respectively. We evaluated whether these prevalences were different across modalities using a random-effects model and did not find a statistically significant difference (p = 0.17).

We assessed the risk of verification bias by exploring the studies in our analysis that did not complete a coronary catheterization in all of the patients who underwent the NIT. In the population of women with no previously known CAD, this represented one study of SPECT,52 one study of ECHO,79 three studies of ECG,29,52,58 and no studies of CMR or coronary CTA. Given the small number of total studies with this potential bias, we felt confident that our primary results were minimized for verification bias. We explored the potential for publication bias across the different modalities in our four populations of interest (studies of women with no known CAD, good-quality studies of women with no known CAD, studies of women from mixed populations, and good-quality studies of women from mixed populations). Our analyses did not provide evidence for publication bias, with our p values ranging from 0.093 to 0.95.

Table 20 shows the GRADE for the accuracy of all the NIT modalities in women with no known CAD. The number of observational studies, summary sensitivity/specificity results, and starting grade are listed for each modality. The change in the GRADE score—based on the risk of bias, consistency, directness, precision, and publication bias—is designated as “0” for no change and “−1” for a decrease due to inconsistency or imprecision. The overall strength of evidence was then determined for each modality.

Table 20 GRADE table for accuracy of NIT modalities in women with no known CAD

NIT and Outcome | Quantity and Type of Evidence | Finding | Starting Grade | Decrease GRADE | | | | | GRADE of Evidence for Outcome | Overall GRADE
NIT and Outcome | Quantity and Type of Evidence | Finding | Starting Grade | Risk of Bias | Consistency | Directness | Precision | Publication Bias | GRADE of Evidence for Outcome | Overall GRADE
CMR | 5 | | | | | | | | | Low
Sensitivity | 5 | 72% | High | 0 | −1 | 0 | −1 | 0 | Low | Low
Specificity | 5 | 84% | High | 0 | −1 | 0 | −1 | 0 | Low | Low
Coronary CTA | 5 | | | | | | | | | Low
Sensitivity | 5 | 93% | High | 0 | −1 | 0 | −1 | 0 | Low | Low
Specificity | 5 | 77% | High | 0 | −1 | 0 | −1 | 0 | Low | Low
ECG | 29 | | | | | | | | | High
Sensitivity | 29 | 62% | High | 0 | 0 | 0 | 0 | 0 | High | High
Specificity | 29 | 68% | High | 0 | 0 | 0 | 0 | 0 | High | High
ECHO | 14 | | | | | | | | | High
Sensitivity | 14 | 79% | High | 0 | 0 | 0 | 0 | 0 | High | High
Specificity | 14 | 83% | High | 0 | 0 | 0 | 0 | 0 | High | High
SPECT | 14 | | | | | | | | | High
Sensitivity | 14 | 81% | High | 0 | 0 | 0 | 0 | 0 | High | High
Specificity | 14 | 78% | High | 0 | 0 | 0 | 0 | 0 | High | High

Abbreviations: CAD = coronary artery disease; CMR =cardiac magnetic resonance; CTA = computed tomography angiography; ECG = exercise/stress electrocardiogram; ECHO = echocardiogram; SPECT = single proton emission computed tomography

## KQ 2: Predictors of Diagnostic Accuracy

The predictors of diagnostic accuracy of the various NIT modalities in women were seldom reported. From 11 studies (4 good quality, 5 fair, and 2 poor), the predictors assessed included (1) postmenopausal women ages 55 to 64 (1 study), (2) race/ethnicity (2 studies), (3) heart size (4 studies), (4) pretest probability (3 studies), and (5) use of beta blocker medications (1 study). Despite widespread acknowledgment that patient variables can affect the accuracy of NITs, we identified no studies examining the influence of age alone, functional status, or body size on diagnostic accuracy in women. In terms of the NIT modality, we found four studies of stress ECHO, six studies of stress ECG, two studies of CMR, and four studies of SPECT that reported these predictors. There was significant variability in diagnostic accuracy as well as significant heterogeneity in the types of the predictors reported in the NIT literature. From a limited number of studies, it appeared that (1) the presence of LVH reduced the specificity of stress ECG, SPECT, and ECHO,28 (2) the use of beta blocker agents reduced the specificity of stress ECG and the sensitivity and specificity of SPECT,50 and (3) the positive predictive value increased as the pretest probability rose for ECG and ECHO.55

## KQ 3: Improving Risk Stratification, Decisionmaking, and Outcomes

An essential clinical question in the management of women with suspected CAD is whether NITs have the ability to provide risk stratification (low, medium, or high risk) and prognostic information (good, fair, or poor); inform decisionmaking about treatment options (medical therapy or revascularization); and affect clinical outcomes (MI, angina, quality of life, hospitalization, and death). From 13 comparative studies (3 good quality, 9 fair, 1 poor), we found 8 studies assessing risk stratification and prognostic information, 2 studies assessing decisionmaking for treatment options, and 4 studies that provided comparative clinical outcomes. Most of these findings came from subpopulations of the WISE study and assessed the prognosis and outcomes of women with normal coronary arteries on coronary angiography who underwent CMR and exercise/stress ECG. Women with normal coronary arteries by angiography and abnormal CMR or exercise ECG were more likely to have future cardiac events when compared with women with normal CMR or stress ECG findings.108,109 Therefore, the study authors speculated that microvascular coronary disease could be the cause of the abnormal NIT findings and an increase in cardiovascular events. One study found that an abnormal SPECT resulted in a lower event-free survival rate. One study found that a negative stress ECG and diagnosis of noncardiac chest pain translated into lower event rates.52 Another study found that a positive stress ECHO had higher prognosis of worse cardiovascular events than a positive stress ECG.22 However, all these findings would require significant confirmation and replication in larger studies with women. Overall, the level of evidence was insufficient to make any conclusions about the relative utility of different NITs to provide risk stratification and prognostic information, inform decisionmaking, or impact clinical outcomes.

## KQ 4: Safety Concerns

The safety concerns and risks to women undergoing NIT procedures were underreported in the literature. We identified 13 studies (9 good quality, 4 fair) with safety data on the following modalities: (1) stress ECG (4 studies), (2) ECHO (6 studies), (3) SPECT (3 studies), (4) CMR (2 studies), and (5) coronary CTA (5 studies). One study35 showed a significantly lower rate of SVT in women undergoing dobutamine ECHO. A study of adenosine thallium SPECT showed higher rates of ST depression in women.89 Four studies showed higher mean effective radiation dose or higher lifetime attributable risk of cancer incidence in women compared with men.103,105,113,114 However, recent advancements in technology and revised testing protocols have reduced the radiation exposure for coronary CTA. Radiation safety issues were not discussed in other NIT modalities that employ radiation exposure (i.e., SPECT, PET, MIBI scans). The remaining studies did not show any significant adverse events in women compared with men. However, we did not find data specific to women on access site complications, contrast-agent induced nephropathy, nephrogenic systemic fibrosis, or anaphylaxis.

## Discussion

In summary, the findings of this comparative effectiveness review provide evidence for the accuracy of exercise/stress ECG, ECHO, SPECT, CMR, and coronary CTA used for diagnosing CAD in women. The diagnostic accuracy appears to be consistent over time except for the sensitivity of CMR, which appears to be increasing over time (although the large confidence intervals reflect the underlying uncertainty in this measure). We are confident that the summary statistics for ECG, ECHO, and SPECT are robust and unlikely to change with the addition of new studies based on both the number of good-quality studies comparing these modalities with coronary angiography and the tight confidence intervals. More good-quality studies comparing CMR or coronary CTA with coronary angiography in the no-known CAD population and reporting sex-based results are needed to strengthen the summary statistics for those modalities. Of note, this report focused on clinical comparative effectiveness, and so the cost of the various diagnostic strategies was not evaluated.

Decisions around performing tests (either noninvasive or invasive) in patients with symptoms suspicious for CAD revolve around first understanding the pretest probability and testing/action thresholds for patients from the AHA/ACC stable angina guidelines and appropriate use criteria for the various NIT modalities.116–119 Pretest probability is classically defined by age, sex, and type of chest pain (e.g., Diamond-Forrester or CASS study), or the Duke database criteria, which adds risk factors/comorbidities.120 Specifically, clinicians faced with patients who have a guideline-defined low-to-intermediate pretest probability of CAD may decide to obtain a noninvasive test, ideally with a high negative predictive value in this population and low risk of adverse events, in order to “rule out” disease. These may be patients with atypical chest pain (e.g., reflux or musculoskeletal disease) who are concerned about a heart problem and who require reassurance that their symptoms are not cardiac in origin. In contrast, in patients with high pretest probability of CAD (greater than 90 percent chance), a test with very high positive predictive value in this population and potentially more risk may be chosen since the disease of interest is thought to be present; in these cases, invasive angiography—the gold standard—is recommended by the current clinical practice guidelines. Finally, it is the spectrum of intermediate probability between 10 and 90 percent for which the clinicians must choose noninvasive tests that provide the right balance of sensitivity, specificity, and clinical risk to warrant testing. The choice of NIT may differ by clinician preference, availability, or setting (outpatient versus chest pain unit of an emergency department).

It is in this context that the findings of this report on the effectiveness of NITs in women must be considered. First, women are thought to be at lower pretest probability of CAD when evaluated in comparison with men of the same age. When comorbidities or risk factors are taken into account, the pretest likelihood increases with a higher number of comorbidities. Second, women susceptible to some of the adverse effects of testing may have poor test performance or have higher rates of complication from invasive arterial access. Third, because of body shape and limited functional capacity, women may not obtain the same test performance that men do from noninvasive testing. Finally, because of the lack of full representation of women across the spectrum of disease, the available literature may not provide data on performance at the ends of the probability spectrum. Spectrum bias may be present since the studies we evaluated had potentially varied populations and varied disease definitions. However, this review has made a step forward in reducing the risk of spectrum bias for women by focusing on the no-known CAD subpopulation. By requiring coronary angiography as the gold standard, the pretest probability may be higher in the study population than in a routine clinical population that has a mixture of low-, intermediate-, and high-risk populations.

While readers may assume that requiring coronary angiography as the comparator would bias this report toward a higher risk CAD population, we found that the mean CAD prevalence ranged from 0.26 to 0.44; thus there was a broad spectrum of CAD prevalence in these studies. In fact, the range of CAD prevalence in this review is similar to a recent analysis of a large administrative database of patients referred for coronary angiography in which the prevalence of significant obstructive disease was 38 to 40 percent.121 The patient population that does not require coronary angiography can be characterized as having symptoms with low suspicion for CAD or pretest probability of less than 10 percent (note that all included studies enrolled patients with “suspected CAD”). Thus, results from this review would not apply to patients with low pretest probability of disease (e.g., gastroesophageal reflux, musculoskeletal pain, or panic attacks) where an NIT may be performed for clinical reassurance that their symptoms are noncardiac in origin.

In general, because there are few patients with high pretest probability, most clinicians would prefer to have patients undergo one NIT prior to determining a treatment choice or referral to coronary angiography. Circumstances where patients may require more than one NIT include the detection of lesions suspicious for obstructive CAD on coronary CTA with a need to assess for ischemia from stress ECHO or SPECT prior to revascularization. Our review did not identify studies that discussed the order in which different NITs were used for evaluating CAD. In fact, multiple testing or layered-testing strategies are areas where significant research is needed.

The current data suggest that NITs with higher sensitivity include coronary CTA and SPECT, and stress ECHO may represent an NIT with higher specificity. Stress CMR shows emerging data that may be in the upper range for both sensitivity and specificity. Additionally, the findings also demonstrate that NIT performance in women is not as good as in men, likely due to the reasons addressed above. The accuracy may also be location or operator dependent, and thus the results of published studies conducted at highly specialized centers may not uniformly apply to those seen in routine practice. Choice of NIT—and whether to use exercise or pharmacological stress imaging—may be influenced by functional capacity, which tends to be lower in women compared with men. Of note, the accuracy data for NIT modalities in men appeared a little higher than expected, which is likely because the published literature combined the accuracy data for men and women. Taken in context, these findings support the current ACC/AHA recommendations and studies on noninvasive testing in women.

Women are more likely than men to have false positive stress tests; i.e., abnormal stress imaging with nonobstructive CAD on coronary angiography. In fact, up to 9 percent of women presenting with acute coronary syndrome will not have obstructive CAD when they undergo coronary angiography for potential PCI.122 Some experts suggest that these phenomena are due to the presence of microvascular obstruction, the incidence of which is hard to determine since there is no clear diagnostic test used to establish the diagnosis.

Currently, there is debate on whether NITs that measure heart function abnormalities (ECG abnormalities, wall motion abnormality, ischemia), including exercise ECG, stress ECHO, and cardiac nuclear imaging, are equivalent or inferior to NITs that measure anatomic abnormalities (detection of CAD) by CMR or coronary CTA. Will knowing the coronary anatomy (nonobstructive or obstructive) in symptomatic patients lead to better implementation of secondary measures—control of blood pressure, diabetes, and hyperlipidemia—to reduce future cardiac events? Or is it more important to intervene with medications and/or revascularization when ischemia is present? Though this review does not answer these important questions, we describe this evidence gap in the Future Research section.

## Limitations of This Review

Despite identifying 104 studies (110 articles) that met the inclusion criteria, this systematic review has several limitations. First, our search focused on comparator studies of the various NITs with a gold standard of coronary angiography for establishing the diagnosis of CAD in symptomatic patients. While this focus was adequate for identifying studies to assess the diagnostic accuracy of the NIT modalities in women, we found very few comparative studies that reported the influence of clinical characteristics or patient demographics on diagnostic accuracy. Few comparative studies (NIT versus coronary angiography, or NIT versus NIT) provided information on incremental risk stratification, prognostic information, or meaningful information regarding decisionmaking, and few reported the significant risks in women. Study results on these issues were reported for the total patient population and did not separate the effects by sex. Many of the included studies were single-sex (women) studies and limited our ability to fully evaluate sex differences. Also, by focusing on symptomatic patients, this report did not review the use of coronary artery calcium scoring for asymptomatic, high-risk populations.

We are aware that there are several noncomparator studies of each of the NIT modalities that address these issues in women since routine clinical care does not require two NIT modalities or an NIT modality plus coronary angiography for the diagnostic workup of suspected CAD. Given the focus on comparative effectiveness, we did not include these noncomparator studies in our review. By focusing the review on comparative studies, however, we are reducing the bias that is inherent in noncomparative studies. Noncomparative studies have selection, spectrum, and intervention biases for the following reasons: the choice of NIT is determined by the treating provider; a subset of patients with indeterminate or positive results are referred for further NIT testing or coronary angiography; and the clinical outcomes may be influenced by the medical treatments or revascularization options that are offered. Second, the sample size and low representation of women in most of the comparator studies may affect the authors’ ability to analyze the results by sex, therefore reducing the number of studies reporting these findings separately. Third, most studies lacked long-term followup of the patient population, which affected our ability to find studies that reported prognostic information on how the different NITs influenced clinical outcomes. Finally, our summary of the harms and risks of NITs is limited by the lack of disclosure of periprocedural and postprocedural complications in most of the studies.

## Conclusions

This systematic review has provided evidence for the summary sensitivities and specificities of exercise/stress ECG, ECHO, SPECT, CMR, and coronary CTA compared with coronary angiography in women. There was limited or insufficient evidence on the influence of clinical and demographic factors on comparative diagnostic accuracy, risk stratification, prognostic information, treatment decisions, clinical outcomes, and harms from different NITs specifically in women. Modifying the search criteria to include noncomparator studies of NIT modalities may increase the number of studies that address this limitation. Table 21 summarizes the strength of supporting evidence for each KQ.

Table 21 Summary of key findings

Key Question | Strength of Evidence | Conclusions
KQ 1: Diagnostic accuracy of NITs in women | ECG: High ECHO: High SPECT: High CMR: Low Coronary CTA: Low | 94 studies described the diagnostic accuracy of NITs in comparison to another NIT or coronary angiography in women. Of these 94 studies, 78 studies included sufficient data to estimate the sensitivity and specificity of the NIT compared with coronary angiography. Summary from all studies with no known CAD: 41 studies (13 good quality, 22 fair, 6 poor) of exercise ECG showed a summary sensitivity of 62% and specificity of 68% 22 studies (8 good quality, 13 fair, 1 poor) of exercise/stress ECHO showed a summary sensitivity of 79% and specificity of 83% 30 studies (10 good quality, 15 fair, 5 poor) of exercise/stress radionuclide perfusion imaging (SPECT, PET) showed a summary sensitivity of 81% and specificity of 78% 6 studies (5 good quality, 1 fair) of CMR imaging showed a summary sensitivity of 72% and specificity of 84% 8 studies (4 good quality, 4 fair) of coronary CTA showed a summary sensitivity of 93% and specificity 77% Overall, within a given modality, the summary sensitivities and specificities were similar for both types of populations (mixed populations of known and unknown CAD and no known CAD) and for all studies when compared with good-quality studies. When accounting for only the good-quality studies, it appeared that the diagnostic accuracy of detecting CAD in women with unknown CAD was better (in descending order) for coronary CTA, SPECT, ECHO, CMR, and ECG. For the newer technologies (i.e., coronary CTA and CMR), more studies in women would be needed to support these findings since the 95% CIs were quite wide. In testing for a statistically significant difference between the diagnostic accuracy of testing modalities in women, our analyses determined that for women with no previously known CAD, there were differences between the performance of the available modalities (p < 0.001). The sensitivity of ECHO and SPECT was significantly higher than that of ECG. Specificity of ECG was less than that of CMR (borderline) and of ECHO. In the subset of studies that were good-quality and where there was no known CAD in the included population, our analyses again demonstrated differences between performance of tests (p = 0.006) with the specificity of ECG being less than that of CMR and ECHO. Sensitivity analyses exploring mixed populations of women with known and no known CAD showed no statistically significant difference in the sensitivities and specificities from our primary analysis. An analysis exploring the prevalence of CAD across the different NIT modality studies also showed no statistically significant difference. In addition, there were very few studies (1 SPECT, 1 ECHO, and 3 ECG) that did not complete a coronary angiography in all patients who underwent the NIT; therefore the results are minimized for verification bias. Finally we found no evidence of publication bias across the different modalities in our 4 populations of interest (studies of women with no known CAD, good-quality studies of women with no known CAD, studies of women from mixed populations, and good-quality studies of women from mixed populations).
KQ 2: Predictors of diagnostic accuracy in women | Insufficient | 11 studies (4 good quality, 5 fair, 2 poor) described diagnostic accuracy, and 9 of these examined predictors of diagnostic accuracy of different NITs in women. Summary: The predictors assessed included (1) postmenopausal women ages 55 to 64 (1 study), (2) race/ethnicity (2 studies), (3) heart size (4 studies), (4) pretest probability (3 studies), and (5) use of beta blocker medications (1 study). We identified no studies examining the influence of age alone, functional status, or body size on diagnostic accuracy in women. In terms of the NIT modality, we found four studies of stress ECHO, six studies of stress ECG, two studies of CMR, and four studies of SPECT that reported these predictors. Insufficient evidence was available to draw definitive conclusions about predictors given the small number of studies for each predictor and for each modality, as well as the combination of predictor by modality.
KQ 3: Improving risk stratification, decisionmaking, and outcomes in women | Insufficient | 13 studies (3 good quality, 9 fair, 1 poor) reported prognostic, outcome, or decisionmaking data comparing one NIT with another NIT or with coronary angiography in women with symptoms suspicious for CAD. Summary: We found 8 studies assessing risk stratification and prognostic information, 2 studies assessing decisionmaking for treatment options, and 4 studies that provided comparative clinical outcomes. There were insufficient data to demonstrate that the use of specific NITs (compared with coronary angiography) routinely provided incremental risk stratification, prognostic information, or other meaningful information to improve decisionmaking and improve patient outcomes. Most findings reported in the literature would require significant confirmation and replication in larger studies with women.
KQ 4: Safety concerns | Insufficient | 13 studies (9 good quality, 4 fair) reported data pertinent to safety concerns or risks associated with the use of NITs to diagnose CAD in women with symptoms suspicious for CAD. Summary: Safety data were reported on the following modalities: (1) stress ECG (4 studies), (2) ECHO (6 studies), (3) SPECT (3 studies), (4) CMR (2 studies), and (5) coronary CTA (4 studies). Data specific to women on access site complications, contrast agent-induced nephropathy, nephrogenic systemic fibrosis, or anaphylaxis associated with NITs were not reported in any of the studies included in this report. Other than higher mean effective radiation doses for coronary CTA studies for women compared with men (from 3 out of 4 studies reporting radiation exposure levels), the extant literature does not provide sufficient evidence to conclude whether safety concerns, risks, or radiation exposure associated with different NITs to diagnose CAD in patients with suspected CAD differ significantly between women and men.