# References

1 Mieres JH, Shaw LJ, Arai A, et al. Role of noninvasive testing in the clinical evaluation of women with suspected coronary artery disease: Consensus statement from the Cardiac Imaging Committee, Council on Clinical Cardiology, and the Cardiovascular Imaging and Intervention Committee, Council on Cardiovascular Radiology and Intervention, American Heart Association. Circulation. 2005;111(5):682-96. [pmid: 15687114].
2 Lloyd-Jones D, Adams RJ, Brown TM, et al. Heart disease and stroke statistics—2010 update: a report from the American Heart Association. Circulation. 2010;121(7):e46-e215. [pmid: 20019324].
3 Stangl V, Witzel V, Baumann G, et al. Current diagnostic concepts to detect coronary artery disease in women. European Heart Journal. 2008;29(6):707-17. [pmid: 18272503].
4 Matchar DB, Mark DB, Patel MR, et al. Non-invasive imaging for coronary artery disease. Technology Assessment. Rockville, MD. Agency for Healthcare Research and Quality. October. 2006. http://www.cms.gov/determinationprocess/downloads/id34TA.pdf. Accessed December 7, 2010.
5 Gibbons RJ, Balady GJ, Bricker JT, et al. ACC/AHA 2002 guideline update for exercise testing: summary article: a report of the American College of Cardiology/American Heart Association. Task Force on Practice Guidelines (Committee to Update the 1997 Exercise Testing Guidelines). Circulation. 2002;106(14):1883-92. [pmid: 12356646].
6 Strobeck JE, Shen JT, Singh B, et al. Comparison of a two-lead, computerized, resting ECG signal analysis device, the MultiFunction-CardioGram or MCG (a.k.a. 3DMP), to quantitative coronary angiography for the detection of relevant coronary artery stenosis (>70%)—a meta-analysis of all published trials performed and analyzed in the US. Int J Med Sci. 2009;6(4):143-55. [pmid: 19381351].
7 Bluemke DA, Achenbach S, Budoff M, et al. Noninvasive coronary artery imaging: magnetic resonance angiography and multidetector computed tomography angiography: a scientific statement from the American Heart Association. Committee on Cardiovascular Imaging and Intervention of the Council on Cardiovascular Radiology and Intervention, and the Councils on Clinical Cardiology and Cardiovascular Disease in the Young. Circulation. 2008;118(5):586-606. [pmid: 18586979].
8 Einstein AJ. Radiation risk from coronary artery disease imaging: how do different diagnostic tests compare?. Heart. 2008;94(12):1519-21. [pmid: 19011135].
9 Agency for Healthcare Research and Quality. Methods Guide for Effectiveness and Comparative Effectiveness Reviews. Rockville, MD. Agency for Healthcare Research and Quality. http://www.effectivehealthcare.ahrq.gov/index.cfm/search-for-guides-reviews-and-reports/?pageaction=displayproduct&productid=318. Accessed August 22, 2011.
10 Grady D, Chaput L, Kristof M. Results of Systematic Review of Research on Diagnosis and Treatment of Coronary Heart Disease in Women. Evidence Report/Technology Assessment No. 80. (Prepared by the University of California, San Francisco-Stanford Evidence-based Practice Center under Contract No 290-97-0013.) AHRQ Publication No. 03-0035. Rockville, MD. Agency for Healthcare Research and Quality. May. 2003. http://archive.ahrq.gov/downloads/pub/evidence/pdf/chdwom/chdwom.pdf. Accessed July 14, 2011.
11 Grady D, Chaput L, Kristof M. Diagnosis and Treatment of Coronary Heart Disease in Women: Systematic Reviews of Evidence on Selected Topics. Evidence Report/Technology Assessment No. 81. (Prepared by the University of California, San Francisco-Stanford Evidence-based Practice Center under Contract No 290-97-0013.) AHRQ Publication No. 03-E037. Rockville, MD. Agency for Healthcare Research and Quality. May. 2003. http://www.ahrq.gov/downloads/pub/evidence/pdf/chdwomtop/chdwmtop.pdf. Accessed July 14, 2011.
12 Whiting P, Rutjes AW, Reitsma JB, et al. The development of QUADAS: a tool for the quality assessment of studies of diagnostic accuracy included in systematic reviews. BMC Med Res Methodol. 2003;3:25. [pmid: 14606960].
13 Atkins D, Chang SM, Gartlehner G, et al. Assessing applicability when comparing medical interventions: AHRQ and the Effective Health Care Program. J Clin Epidemiol. 2011;64(11):1198-207. [pmid: 21463926].
14 Leeflang MM, Deeks JJ, Gatsonis C, et al. Systematic reviews of diagnostic test accuracy. Ann Intern Med. 2008;149(12):889-97. [pmid: 19075208].
15 Blyth CR, Still HA. Binomial Confidence-Intervals. Journal of the American Statistical Association. 1983;78(381):108-116.
16 Harbord RM, Deeks JJ, Egger M, et al. A unification of models for meta-analysis of diagnostic accuracy studies. Biostatistics. 2007;8(2):239-51. [pmid: 16698768].
17 Arends LR, Hamza TH, van Houwelingen JC, et al. Bivariate random effects meta-analysis of ROC curves. Med Decis Making. 2008;28(5):621-38. [pmid: 18591542].
18 Rutter CM, Gatsonis CA. Regression methods for meta-analysis of diagnostic test data. Acad Radiol. 1995;2(Suppl 1):S48-56. discussion. S65. 7. S70. 1. pas. [pmid: 9419705].
19 Deeks JJ, Macaskill P, Irwig L. The performance of tests of publication bias and other sample size effects in systematic reviews of diagnostic test accuracy was assessed. J Clin Epidemiol. 2005;58(9):882-93. [pmid: 16085191].
20 Agency for Healthcare Research and Quality. Methods Guide for Medical Test Reviews. [posted November 2010]. Rockville, MD. http://effectivehealthcare.ahrq.gov/index.cfm/search-for-guides-reviews-and-reports/?pageaction=displayProduct&productID=558. Accessed August 22, 2011.
21 Owens DK, Lohr KN, Atkins D, et al. AHRQ series paper 5: Grading the strength of a body of evidence when comparing medical interventions—Agency for Healthcare Research and Quality and the Effective Health-Care Program. J Clin Epidemiol. 2010;63(5):513-23. [pmid: 19595577].
22 Dodi C, Cortigiani L, Masini M, et al. The incremental prognostic value of pharmacological stress echo over exercise electrocardiography in women with chest pain of unknown origin. Eur Heart J. 2001;22(2):145-52. [pmid: 11161916].
23 Sanfilippo AJ, Abdollah H, Knott TC, et al. Stress echocardiography in the evaluation of women presenting with chest pain syndrome: a randomized, prospective comparison with electrocardiographic stress testing. Can J Cardiol. 2005;21(5):405-12. [pmid: 15861257].
24 Shaw LJ, Mieres JH, Hendel RH, et al. Comparative Effectiveness of Exercise Electrocardiography With or Without Myocardial Perfusion Single Photon Emission Computed Tomography in Women With Suspected Coronary Artery Disease: Results From the What Is the Optimal Method for Ischemia Evaluation in Women (WOMEN) Trial. Circulation. 2011. [pmid: 21844080].
25 Siegler JC, Rehman S, Bhumireddy GP, et al. The Accuracy of the Electrocardiogram during Exercise Stress Test Based on Heart Size. PLoS One. 2011;6(8):e23044. [pmid: 21857990].
26 Doyle M, Fuisz A, Kortright E, et al. The impact of myocardial flow reserve on the detection of coronary artery disease by perfusion imaging methods: an NHLBI WISE study. J Cardiovasc Magn Reson. 2003;5(3):475-85. [pmid: 12882078].
27 Lehmkuhl HB, Siniawski H, Lehmkuhl E, et al. Value and limitations of dobutamine stress echocardiography in women with suspected coronary artery disease. Zeitschrift fur Herz-, Thorax-und Gefasschirurgie. 2007;21(6):250-258.
28 Lu C, Lu F, Fragasso G, et al. Comparison of exercise electrocardiography, technetium-99m sestamibi single photon emission computed tomography, and dobutamine and dipyridamole echocardiography for detection of coronary artery disease in hypertensive women. Am J Cardiol. 2010;105(9):1254-60. [pmid: 20403475].
29 Miller TD, Roger VL, Milavetz JJ, et al. Assessment of the exercise electrocardiogram in women versus men using tomographic myocardial perfusion imaging as the reference standard. Am J Cardiol. 2001;87(7):868-73. [pmid: 11274942].
30 Raman SV, Donnally MR, McCarthy B. Dobutamine stress cardiac magnetic resonance imaging to detect myocardial ischemia in women. Prev Cardiol. 2008;11(3):135-40. [pmid: 18607148].
31 Cin VG, Tartanoglu O, Duzenli A, et al. The use of basic clinical and exercise variables in postmenopausal women for the diagnosis of coronary artery disease. Int Angiol. 2000;9(3):135-137.
32 Hlatky MA, Pryor DB, Harrell FE Jr, et al. Factors affecting sensitivity and specificity of exercise electrocardiography. Multivariable analysis. Am J Med. 1984;77(1):64-71. [pmid: 6741986].
33 Hosokawa J, Shen JT, Imhoff M. Computerized 2-lead resting ECG analysis for the detection of relevant coronary artery stenosis in comparison with angiographic findings. Congest Heart Fail. 2008;14(5):251-60. [pmid: 18983288].
34 Svart K, Lehtinen R, Nieminen T, et al. Exercise electrocardiography detection of coronary artery disease by. Intl J Cardiol. 2010;140(2):182-188.
35 Elhendy A, Geleijnse ML, van Domburg RT, et al. Gender differences in the accuracy of dobutamine stress echocardiography for the diagnosis of coronary artery disease. Am J Cardiol. 1997;80(11):1414-8. [pmid: 9399713].
36 Yamauchi K, Simonson E, Dahl JC, et al. Sex differences in submaximal exercise tests correlation with coronary cineangiography in 133 patients. Nagoya J Med Sci. 1985;47(1–2):67-75. [pmid: 3990772].
37 Friedman TD, Greene AC, Iskandrian AS, et al. Exercise thallium-201 myocardial scintigraphy in women: correlation with coronary arteriography. Am J Cardiol. 1982;49(7):1632-7. [pmid: 7081050].
38 Lewis JF, McGorray S, Lin L, et al. Exercise treadmill testing using a modified exercise protocol in women with suspected myocardial ischemia: findings from the National Heart, Lung and Blood Institute-sponsored Women’s Ischemia Syndrome Evaluation (WISE). Am Heart J. 2005;149(3):527-33. [pmid: 15864243].
39 Laurienzo JM, Cannon RO 3rd, Quyyumi AA, et al. Improved specificity of transesophageal dobutamine stress echocardiography compared to standard tests for evaluation of coronary artery disease in women presenting with chest pain. Am J Cardiol. 1997;80(11):1402-7. [pmid: 9399711].
40 Chae SC, Heo J, Iskandrian AS, et al. Identification of extensive coronary artery disease in women by exercise single-photon emission computed tomographic (SPECT) thallium imaging. J Am Coll Cardiol. 1993;21(6):1305-11. [pmid: 8473634].
41 Lewandowski M, Szwed H, Kowalik I. Searching for the optimal strategy for the diagnosis of stable coronary artery disease. Cost-effectiveness of the new algorithm. Cardiol J. 2007;14(6):544-51. [pmid: 18651520].
42 Ozdemir K, Altunkeser BB, Aydin M, et al. New parameters in the interpretation of exercise testing in women: QTc dispersion and QT dispersion ratio difference. Clin Cardiol. 2002;25(4):187-92. [pmid: 12000077].
43 Gentile R, Vitarelli A, Schillaci O, et al. Diagnostic accuracy and prognostic implications of stress testing for coronary artery disease in the elderly. Ital Heart J. 2001;2(7):539-45. [pmid: 11501963].
44 Koide Y, Yotsukura M, Yoshino H, et al. A new coronary artery disease index of treadmill exercise electrocardiograms based on the step-up diagnostic method. Am J Cardiol. 2001;87(2):142-7. [pmid: 11152828].
45 Morise AP. Are the American College of Cardiology/American Heart Association guidelines for exercise testing for suspected coronary artery disease correct?. Chest. 2000;118(2):535-41. [pmid: 10936152].
46 Severi S, Picano E, Michelassi C, et al. Diagnostic and prognostic value of dipyridamole echocardiography in patients with suspected coronary artery disease. Comparison with exercise electrocardiography. Circulation. 1994;89(3):1160-73. [pmid: 8124803].
47 Richardson MT, Holly RG, Amsterdam EA, et al. The value of ten common exercise tolerance test measures in predicting coronary disease in symptomatic females. Cardiology. 1995;86(3):243-8. [pmid: 7614498].
48 Weiner DA, Ryan TJ, McCabe CH, et al. Exercise stress testing. Correlations among history of angina, ST-segment response and prevalence of coronary-artery disease in the Coronary Artery Surgery Study (CASS). N Engl J Med. 1979;301(5):230-5. [pmid: 449990].
49 Schupbach WM, Emese B, Loretan P, et al. Non-invasive diagnosis of coronary artery disease using cardiogoniometry performed at rest. Swiss Med Wkly. 2008;138(15–16):230-8. [pmid: 18431698].
50 Yeih DF, Huang PJ, Ho YL. Enhanced diagnosis of coronary artery disease in women by dobutamine thallium-201 ST-segment/heart rate slope and thallium-201 myocardial SPECT. J Formos Med Assoc. 2007;106(10):832-9. [pmid: 17964962].
51 Michaelides AP, Fourlas CA, Chatzistamatiou EI, et al. QRS score improves diagnostic ability of treadmill exercise testing in women. Coron Artery Dis. 2007;18(4):313-8. [pmid: 17496496].
52 Mieres JH, Makaryus AN, Cacciabaudo JM, et al. Value of electrocardiographically gated single-photon emission computed tomographic myocardial perfusion scintigraphy in a cohort of symptomatic postmenopausal women. Am J Cardiol. 2007;99(8):1096-9. [pmid: 17437734].
53 Hoilund-Carlsen PF, Johansen A, Christensen HW, et al. Usefulness of the exercise electrocardiogram in diagnosing ischemic or coronary heart disease in patients with chest pain. Am J Cardiol. 2005;95(1):96-9. [pmid: 15619400].
54 Rollan MJ, San Roman JA, Vilacosta I, et al. Dobutamine stress echocardiography in the diagnosis of coronary artery disease in women with chest pain: comparison with different noninvasive tests. Clin Cardiol. 2002;25(12):559-64. [pmid: 12492125].
55 Marwick TH, Anderson T, Williams MJ, et al. Exercise echocardiography is an accurate and cost-efficient technique for detection of coronary artery disease in women. J Am Coll Cardiol. 1995;26(2):335-41. [pmid: 7608432].
56 Agati L, Renzi M, Sciomer S, et al. Transesophageal dipyridamole echocardiography for diagnosis of coronary artery disease. J Am Coll Cardiol. 1992;19(4):765-70. [pmid: 1545071].
57 Barolsky SM, Gilbert CA, Faruqui A, et al. Differences in electrocardiographic response to exercise of women and men: a non-Bayesian factor. Circulation. 1979;60(5):1021-7. [pmid: 487535].
58 Morise AP, Diamond GA. Comparison of the sensitivity and specificity of exercise electrocardiography in biased and unbiased populations of men and women. Am Heart J. 1995;130(4):741-7. [pmid: 7572581].
59 Robert AR, Melin JA, Detry JM. Logistic discriminant analysis improves diagnostic accuracy of exercise testing for coronary artery disease in women. Circulation. 1991;83(4):1202-9. [pmid: 2013142].
60 Guiteras P, Chaitman BR, Waters DD, et al. Diagnostic accuracy of exercise ECG lead systems in clinical subsets of women. Circulation. 1982;65(7):1465-74. [pmid: 7074802].
61 Masini M, Picano E, Lattanzi F, et al. High dose dipyridamole-echocardiography test in women: correlation with exercise-electrocardiography test and coronary arteriography. J Am Coll Cardiol. 1988;12(3):682-5. [pmid: 3403825].
62 Bokhari S, Shahzad A, Bergmann SR. Superiority of exercise myocardial perfusion imaging compared with the exercise ECG in the diagnosis of coronary artery disease. Coron Artery Dis. 2008;19(6):399-404. [pmid: 18955833].
63 Sinha DP, Das M, Banerjee AK, et al. Comparative study to assess whether high sensitive C-reactive protein and carotid intima media thickness improve the predictive accuracy of exercise stress testing for coronary artery disease in perimenopausal women with typical angina. J Indian Med Assoc. 2008;106(2):86. 88. 90 passim. [pmid: 18705250].
64 Sketch MH, Mohiuddin SM, Lynch JD, et al. Significant sex differences in the correlation of electrocardiographic exercise testing and coronary arteriograms. Am J Cardiol. 1975;36(2):169-73. [pmid: 1155337].
65 Morise AP, Diamond GA, Detrano R, et al. Incremental value of exercise electrocardiography and thallium-201 testing in men and women for the presence and extent of coronary artery disease. Am Heart J. 1995;130(2):267-76. [pmid: 7631606].
66 Maffei E, Seitun S, Martini C, et al. CT coronary angiography and exercise ECG in a population with chest pain and low-to-intermediate pre-test likelihood of coronary artery disease. Heart. 2010;96(24):1973-9. [pmid: 21051457].
67 Ho YL, Wu CC, Huang PJ, et al. Assessment of coronary artery disease in women by dobutamine stress echocardiography: comparison with stress thallium-201 single-photon emission computed tomography and exercise electrocardiography. Am Heart J. 1998;135(4):655-62. [pmid: 9539482].
68 Santana-Boado C, Candell-Riera J, Castell-Conesa J, et al. Diagnostic accuracy of technetium-99m-MIBI myocardial SPECT in women and men. J Nucl Med. 1998;39(5):751-5. [pmid: 9591568].
69 Shin JH, Shiota T, Kim YJ, et al. False-positive exercise echocardiograms: impact of sex and blood pressure response. Am Heart J. 2003;146(5):914-9. [pmid: 14597944].
70 Bjornstad K, Aakhus S, Hatle L. Comparison of digital dipyridamole stress echocardiography and upright bicycle stress echocardiography for identification of coronary artery stenosis. Cardiology. 1995;86(6):514-20. [pmid: 7585764].
71 Elhendy A, van Domburg RT, Bax JJ, et al. Noninvasive diagnosis of coronary artery stenosis in women with limited exercise capacity: comparison of dobutamine stress echocardiography and 99mTc sestamibi single-photon emission CT. Chest. 1998;114(4):1097-104. [pmid: 9792583].
72 Lewis JF, Lin L, McGorray S, et al. Dobutamine stress echocardiography in women with chest pain Pilot phase data from the National Heart, Lung and Blood Institute. Women’s Ischemia Syndrome Evaluation (WISE). J Am Coll Cardiol. 1999;33(6):1462-8. [pmid: 10334409].
73 Sawada SG, Ryan T, Fineberg NS, et al. Exercise echocardiographic detection of coronary artery disease in women. J Am Coll Cardiol. 1989;14(6):1440-7. [pmid: 2809000].
74 Williams MJ, Marwick TH, O’Gorman D, et al. Comparison of exercise echocardiography with an exercise score to diagnose coronary artery disease in women. Am J Cardiol. 1994;74(5):435-8. [pmid: 8059721].
75 Dionisopoulos PN, Collins JD, Smart SC, et al. The value of dobutamine stress echocardiography for the detection of coronary artery disease in women. J Am Soc Echocardiogr. 1997;10(8):811-7. [pmid: 9356945].
76 Mazeika P, Nihoyannopoulos P, Joshi J, et al. Uses and limitations of high dose dipyridamole stress echocardiography for evaluation of coronary artery disease. Br Heart J. 1992;67(2):144-9. [pmid: 1540434].
77 Slavich GA, Guerra UP, Morocutti G, et al. Feasibility of simultaneous Tc99m sestamibi and 2D-echo cardiac imaging during dobutamine pharmacologic stress. Preliminary results in a female population. Int J Card Imaging. 1996;12(2):113-8. [pmid: 8864790].
78 Takeuchi M, Sonoda S, Miura Y, et al. Comparative diagnostic value of dobutamine stress echocardiography and stress thallium-201 single-photon-emission computed tomography for detecting coronary artery disease in women. Coron Artery Dis. 1996;7(11):831-5. [pmid: 8993941].
79 Roger VL, Pellikka PA, Bell MR, et al. Sex and test verification bias. Impact on the diagnostic value of exercise echocardiography. Circulation. 1997;95(2):405-10. [pmid: 9008457].
80 Slomka PJ, Nishina H, Abidov A, et al. Combined quantitative supine-prone myocardial perfusion SPECT improves detection of coronary artery disease and normalcy rates in women. J Nucl Cardiol. 2007;14(1):44-52. [pmid: 17276305].
81 Kaminek M, Myslivecek M, Husak V, et al. The accuracy of myocardial perfusion SPECT imaging in the evaluation of coronary artery disease in women and men. Nucl Med Rev Cent East Eur. 2001;4(2):69-72. [pmid: 14600887].
82 DePasquale EE, Nody AC, DePuey EG, et al. Quantitative rotational thallium-201 tomography for identifying and localizing coronary artery disease. Circulation. 1988;77(2):316-27. [pmid: 3257422].
83 Vashist A, Collins D, Prasad Y, et al. Does cardiac SPECT using attenuation and scatter correction accurately predict coronary artery disease in a minority women population?. Med Sci Monit. 2007;13(9):CR386-390. [pmid: 17767117].
84 Gulati M, Pratap P, Kansal P, et al. Gender differences in the value of ST-segment depression during adenosine stress testing. Am J Cardiol. 2004;94(8):997-1002. [pmid: 15476611].
85 Emmett L, Iwanochko RM, Freeman MR, et al. Reversible regional wall motion abnormalities on exercise technetium-99m-gated cardiac single photon emission computed tomography predict high-grade angiographic stenoses. J Am Coll Cardiol. 2002;39(6):991-8. [pmid: 11897441].
86 Kiat H, Van Train KF, Maddahi J, et al. Development and prospective application of quantitative 2-day stress-rest Tc-99m methoxy isobutyl isonitrile SPECT for the diagnosis of coronary artery disease. Am Heart J. 1990;120(6 Pt 1):1255-66. [pmid: 2248175].
87 Taillefer R, DePuey EG, Udelson JE, et al. Comparative diagnostic accuracy of Tl-201 and Tc-99m sestamibi SPECT imaging (perfusion and ECG-gated SPECT) in detecting coronary artery disease in women. J Am Coll Cardiol. 1997;29(1):69-77. [pmid: 8996297].
88 Mak KH, Ang ES, Goh AS, et al. Myocardial perfusion imaging with technetium-99m sestamibi SPECT in the evaluation of coronary artery disease. Australas Radiol. 1995;39(2):112-7. [pmid: 7605313].
89 Mohiuddin SM, Ravage CK, Esterbrooks DJ, et al. The comparative safety and diagnostic accuracy of adenosine myocardial perfusion imaging in women versus men. Pharmacotherapy. 1996;16(4):646-51. [pmid: 8840371].
90 Hung J, Chaitman BR, Lam J, et al. Noninvasive diagnostic test choices for the evaluation of coronary artery disease in women: a multivariate comparison of cardiac fluoroscopy, exercise electrocardiography and exercise thallium myocardial perfusion scintigraphy. J Am Coll Cardiol. 1984;4(1):8-16. [pmid: 6736458].
91 Wolak A, Slomka PJ, Fish MB, et al. Quantitative diagnostic performance of myocardial perfusion SPECT with attenuation correction in women. J Nucl Med. 2008;49(6):915-22. [pmid: 18483092].
92 Elhendy A, Schinkel AF, Bax JJ, et al. Accuracy of stress Tc-99m tetrofosmin myocardial perfusion tomography for the diagnosis and localization of coronary artery disease in women. J Nucl Cardiol. 2006;13(5):629-34. [pmid: 16945742].
93 Abramson BL, Ruddy TD, deKemp RA, et al. Stress perfusion/metabolism imaging: a pilot study for a potential new approach to the diagnosis of coronary disease in women. J Nucl Cardiol. 2000;7(3):205-12. [pmid: 10888390].
94 Van Train KF, Garcia EV, Maddahi J, et al. Multicenter trial validation for quantitative analysis of same-day rest-stress technetium-99m-sestamibi myocardial tomograms. J Nucl Med. 1994;35(4):609-18. [pmid: 8151383].
95 Gebker R, Jahnke C, Hucko T, et al. Dobutamine stress magnetic resonance imaging for the detection of coronary artery disease in women. Heart. 2010;96(8):616-20. [pmid: 19687013].
96 Merkle N, Wöhrle J, Nusser T, et al. Diagnostic performance of magnetic resonance first pass perfusion imaging is equally potent in female compared to male patients with coronary artery disease. Clin Res Cardiol. 2010;99(1):21-8. [pmid: 19756814].
97 Klem I, Greulich S, Heitner JF, et al. Value of cardiovascular magnetic resonance stress perfusion testing for the detection of coronary artery disease in women. JACC Cardiovasc Imaging. 2008;1(4):436-45. [pmid: 19356464].
98 Langer C, Peterschroder A, Franzke K, et al. Noninvasive coronary angiography focusing on calcification: multislice computed tomography compared with magnetic resonance imaging. J Comput Assist Tomogr. 2009;33(2):179-85. [pmid: 19346842].
99 Coelho-Filho OR, Seabra LF, Mongeon FP, et al. Stress Myocardial Perfusion Imaging by CMR Provides Strong Prognostic Value to Cardiac Events Regardless of Patient’s Sex. JACC Cardiovasc Imaging. 2011;4(8):850-61. [pmid: 21835377].
100 Dewey M, Vavere AL, Arbab-Zadeh A, et al. Patient characteristics as predictors of image quality and diagnostic accuracy of MDCT compared with conventional coronary angiography for detecting coronary artery stenoses: CORE-64 Multicenter International Trial. AJR Am J Roentgenol. 2010;194(1):93-102. [pmid: 20028910].
101 Pundziute G, Schuijf JD, Jukema JW, et al. Gender influence on the diagnostic accuracy of 64-slice multislice computed tomography coronary angiography for detection of obstructive coronary artery disease. Heart. 2008;94(1):48-52. [pmid: 17540687].
102 Jenkins SM, Johnston N, Hawkins NM, et al. Limited clinical utility of CT coronary angiography in a district hospital setting. QJM. 2010. [pmid: 20847015].
103 Dewey M, Rutsch W, Hamm B. Is there a gender difference in noninvasive coronary imaging? Multislice computed tomography for noninvasive detection of coronary stenoses. BMC Cardiovasc Disord. 2008;8:2. [pmid: 18230167].
104 Shivalkar B, Goovaerts I, Salgado RA, et al. Multislice cardiac computed tomography in symptomatic middle-aged women. Ann Med. 2007;39(4):290-7. [pmid: 17558600].
105 Dharampal AS, Rossi A, Papadopoulou SL, et al. Is there a difference in the diagnostic accuracy of computed tomography coronary angiography between women and men?. Coron Artery Dis. 2011;22(6):421-427. [pmid: 21606842].
106 Burger AJ, Al-Sergani H, Wrobleski D. False positive ST segment elevation during dobutamine stress echocardiography due to left ventricular hypertrophy. Echocardiography. 2002;19(2):103-8. [pmid: 11926971].
107 Gebker R, Mirelis JG, Jahnke C, et al. Influence of left ventricular hypertrophy and geometry on diagnostic accuracy of wall motion and perfusion magnetic resonance during dobutamine stress. Circ Cardiovasc Imaging. 2010;3(5):507-14. [pmid: 20576810].
108 Doyle M, Weinberg N, Pohost GM, et al. Prognostic Value of Global MR Myocardial Perfusion Imaging in Women With Suspected Myocardial Ischemia and No Obstructive Coronary Disease Results From the NHLBI-Sponsored WISE (Women’s Ischemia Syndrome Evaluation) Study. JACC Cardiovasc Imaging. 2010;3(10):1030-6. [pmid: 20947048].
109 Johnson BD, Shaw LJ, Buchthal SD, et al. Prognosis in women with myocardial ischemia in the absence of obstructive coronary disease: results from the National Institutes of Health-National Heart, Lung, and Blood Institute-Sponsored Women’s Ischemia Syndrome Evaluation (WISE). Circulation. 2004;109(24):2993-9. [pmid: 15197152].
110 Morise AP, Lauer MS, Froelicher VF. Development and validation of a simple exercise test score for use in women with symptoms of suspected coronary artery disease. Am Heart J. 2002;144(5):818-25. [pmid: 12422150].
111 Morise AP, Olson MB, Merz CN, et al. Validation of the accuracy of pretest and exercise test scores in women with a low prevalence of coronary disease: the NHLBI-sponsored Women’s Ischemia Syndrome Evaluation (WISE) study. Am Heart J. 2004;147(6):1085-92. [pmid: 15199360].
112 Wong Y, Rodwell A, Dawkins S, et al. Sex differences in investigation results and treatment in subjects referred for investigation of chest pain. Heart. 2001;85(2):149-52. [pmid: 11156662].
113 Weustink AC, Meijboom WB, Mollet NR, et al. Reliable high-speed coronary computed tomography in symptomatic patients. J Am Coll Cardiol. 2007;50(8):786-94. [pmid: 17707184].
114 Weustink AC, Mollet NR, Neefjes LA, et al. Preserved diagnostic performance of dual-source CT coronary angiography with reduced radiation exposure and cancer risk. Radiology. 2009;252(1):53-60. [pmid: 19451542].
115 Committee to Assess Health Risks from Exposure to Low Levels of Ionizing Radiation, National Research Council. Health Risks from Exposure to Low Levels of Ionizing Radiation: BEIR VII Phase 2. The National Academies Press. 2006. PMID:.
116 Hendel RC, Patel MR, Kramer CM, et al. ACCF/ACR/SCCT/SCMR/ASNC/NASCI/SCAI/SIR 2006 appropriateness criteria for cardiac computed tomography and cardiac magnetic resonance imaging: a report of the American College of Cardiology Foundation Quality Strategic Directions Committee Appropriateness Criteria Working Group, American College of Radiology. Society of Cardiovascular Computed Tomography, Society for Cardiovascular Magnetic Resonance, American Society of Nuclear Cardiology, North American Society for Cardiac Imaging, Society for Cardiovascular Angiography and Interventions, and Society of Interventional Radiology. J Am Coll Cardiol. 2006;48(7):1475-97. [pmid: 17010819].
117 Taylor AJ, Cerqueira M, Hodgson JM, et al. ACCF/SCCT/ACR/AHA/ASE/ASNC/NASCI/SCAI/SCMR 2010 Appropriate Use Criteria for Cardiac Computed Tomography A Report of the American College of Cardiology Foundation Appropriate Use Criteria Task Force, the Society of Cardiovascular Computed Tomography, the American College of Radiology the American Heart Association, the American Society of Echocardiography, the American Society of Nuclear Cardiology, the North American Society for Cardiovascular Imaging, the Society for Cardiovascular Angiography and Interventions, and the Society for Cardiovascular Magnetic Resonance. J Cardiovasc Comput Tomogr. 2010;4(6):407 e1-33. [pmid: 21232696].
118 Douglas PS, Garcia MJ, Haines DE, et al. ACCF/ASE/AHA/ASNC/HFSA/HRS/SCAI/SCCM/SCCT/SCMR 2011 Appropriate Use Criteria for Echocardiography A Report of the American College of Cardiology Foundation Appropriate Use Criteria Task Force, American Society of Echocardiography, American Heart Association American Society of Nuclear Cardiology, Heart Failure Society of America, Heart Rhythm Society, Society for Cardiovascular Angiography and Interventions, Society of Critical Care Medicine, Society of Cardiovascular Computed Tomography, and Society for Cardiovascular Magnetic Resonance Endorsed by the American College of Chest Physicians. J Am Coll Cardiol. 2011;57(9):1126-66. [pmid: 21349406].
119 Bonow RO, Douglas PS, Buxton AE, et al. ACCF/AHA methodology for the development of quality measures for cardiovascular technology: a report of the American College of Cardiology Foundation/American Heart Association. Task Force on Performance Measures. Circulation. 2011;124(13):1483-502. [pmid: 21875906].
120 Gibbons RJ, Chatterjee K, Daley J, et al. ACC/AHA/ACP-ASIM guidelines for the management of patients with chronic stable angina: a report of the American College of Cardiology/American Heart Association. Task Force on Practice Guidelines (Committee on Management of Patients With Chronic Stable Angina). J Am Coll Cardiol. 1999;33(7):2092-197. [pmid: 10362225].
121 Patel MR, Peterson ED, Dai D, et al. Low diagnostic yield of elective coronary angiography. [Erratum in: N Engl J Med. 2010 Jul 29;363(5):498.]. N Engl J Med. 2010;362(10):886-95. [pmid: 20220183].
122 Patel MR, Chen AY, Peterson ED, et al. Prevalence, predictors, and outcomes of patients with non-ST-segment elevation myocardial infarction and insignificant coronary artery disease: results from the Can Rapid risk stratification of Unstable angina patients Suppress ADverse outcomes with Early implementation of the ACC/AHA. Guidelines (CRUSADE) initiative. Am Heart J. 2006;152(4):641-7. [pmid: 16996828].