# Peer Reviewers

Elizabeth Barrett-Connor, M.D.

Professor and Division Chief of Epidemiology

University of California, San Diego

San Diego, CA

Kavitha M. Chinnaiyan, M.D.

Medical Director of Noninvasive Cardiology Education

Beaumont Heart Center

Royal Oak, MI

Nakela L. Cook, M.D., M.P.H.

Division of Cardiology

Washington Hospital Center

Washington, DC

Jean McSweeney, Ph.D., R.N.

Associate Dean for Research

University of Arkansas for Medical Sciences

Little Rock, AR

Lori Mosca, M.D., Ph.D., M.P.H.

Professor of Medicine

Director of Preventive Cardiology

Columbia University Medical Center

New York, NY

Frank John Rybicki III, M.D., Ph.D.

Associate Professor of Radiology

Brigham and Women’s Hospital

Boston, MA