# Methods

## Topic Development and Refinement

The Evidence-based Practice Center (EPC) followed AHRQ’s recommended methodology, described in Methods Guide for Effectiveness and Comparative Effectiveness Reviews,9 for literature search strategies, inclusion/exclusion of studies, abstract screening, data abstraction and management, assessment of methodological quality of individual studies, data synthesis, and grading of evidence for each Key Question (KQ).

During the topic refinement stage, we solicited input from Key Informants representing clinicians (cardiology, primary care, cardiac imaging), patients, scientific experts, and Federal agencies, to help define the KQs. The KQs were then posted for public comment for 30 days, and the comments received were considered in the development of the research protocol. We next convened a Technical Expert Panel (TEP), comprising clinical, content, and methodological experts, to provide input in defining populations, interventions, comparisons, or outcomes as well as identifying particular studies or databases to search. The Key Informants and members of the TEP were required to disclose any financial conflicts of interest greater than $10,000 and any other relevant business or professional conflicts of interest. Any potential conflicts of interest were balanced or mitigated. Neither Key Informants nor members of the TEP did analysis of any kind and did not contribute to the writing of the report.

## Analytic Framework

Figure 1 shows the analytic framework for the systematic review of NITs for the diagnosis of CAD in women.

Figure 1 Analytic framework

Abbreviations: CAD = coronary artery disease, KQ = Key Question, NSF = nephrogenic systemic fibrosis

Figure 1 depicts the key questions (KQs) within the context of the PICO (population, interventions, comparators, and outcomes) described elsewhere in this document. In general, the figure shows that the CER will consider the accuracy of one noninvasive diagnostic test (NIT) vs. another or vs. coronary angiography for diagnosing obstructive and nonobstructive coronary artery disease (CAD) in women with symptoms suspicious for CAD (KQ 1); various possible predictors of diagnostic accuracy (including age, race/ethnicity, body size, heart size, menopausal status, functional status, and stress modality) of the different NITs in this context (KQ 2); whether the use of NITs improves prognostic information, risk stratification, treatment offered, and clinical outcomes (including myocardial infarction, unstable angina, hospitalization, death, revascularization, angina relief, and quality of life in the population of interest) (KQ 3); and whether there are significant safety concerns or risks (including radiation exposure, access site complications, contrast agent-induced nephropathy, nephrogenic systemic fibrosis, anaphylaxis, and arrhythmias) associated with the use of NITs in this context (KQ 4).

## Literature Search Strategy

### Sources Searched

We included studies published in English from January 1, 2000, through September 12, 2011. Search strategies were specific to each database in order to retrieve the articles most relevant to the KQs. Our search strategy used the National Library of Medicine’s medical subject headings (MeSH) keyword nomenclature developed for MEDLINE^®^ and adapted for use in other databases. In consultation with our research librarians, we used PubMed^®^, Embase^®^, the Cochrane Database of Systematic Reviews, and the Cochrane Central Registry of Controlled Trials for our literature search. We also searched the grey literature of study registries and conference abstracts for relevant articles from completed trials. Grey literature databases included Clinicaltrials.gov; metaRegister of Controlled Trials; ClinicalStudyResults.org; WHO: International Clinical Trials Registry Platform Search Portal; CSA Conference Papers Index; and Scopus. The exact search strings used in our strategy are given in Appendix A. Reference lists of articles applicable to the relevant KQs of previous AHRQ reports on this topic10,11 and from identified systematic reviews and meta-analyses were manually hand-searched and cross-referenced against our library, and additional manuscripts were retrieved. All citations were imported into an electronic bibliographic database (EndNote^®^ Version X4; Thomson Reuters, Philadelphia, PA).

## Process for Study Selection

### Screening for Inclusion and Exclusion

We developed a list of article inclusion and exclusion criteria for the KQs (Table 1). Using the prespecified inclusion and exclusion criteria, titles and abstracts were examined independently by two reviewers for potential relevance to the KQs. Articles included by any reviewer underwent full-text screening. At the full-text screening stage, two independent reviewers read each article to determine if it met eligibility criteria. At the full-text review stage, paired researchers independently reviewed the articles and indicated a decision to “include” or “exclude” the article for data abstraction. When the paired reviewers arrived at different decisions about whether to include or exclude an article, we reconciled the difference through a third-party arbitrator. Articles meeting our eligibility criteria were included for data abstraction. Relevant systematic review articles, meta-analyses, and methods articles were flagged for hand-searching and cross-referencing against the library of citations identified through electronic database searching.

Table 1 Summary of inclusion and exclusion criteria

Study Characteristic | Inclusion Criteria | Exclusion Criteria
Study design | An article was included if the following two criteria were met:; - Original data or related methodology paper of an included article; - Randomized controlled trial, prospective or retrospective observational study, or registry | - Editorial; - Letter to editor; - Case series; - Review article, meta-analysis, or methods paper of an excluded article; - Not peer reviewed
Population | Study included adult women (age ≥ 18 years of age) who present symptoms of symptoms suspicious for CAD (e.g., exertional dyspnea, shortness of breath, and/or angina) with or without a known diagnosis of CAD; data for women must be presented separately from data for men | - All subjects were < 18 years of age, or some subjects were under < 18 but results were not broken down by age; - No patients had symptomatic chest pain (i.e., an asymptomatic population), or some of the patients had symptomatic chest pain but results were not reported separately for this subgroup; - All patients were known to have CAD and were not being tested for chest pain symptoms (e.g., postrevascularization testing to assess for persistent ischemia)
Interventions | NITs for the diagnosis of obstructive and nonobstructive CAD included:; - Exercise electrocardiogram stress test; - Resting electrocardiogram technology; - Exercise/stress echocardiography with or without a contrast agent; - Exercise/stress radionuclide myocardial perfusion imaging, including single proton emission computed tomography and positron emission tomography; - Stress myocardial perfusion and wall motion magnetic resonance imaging; - Coronary computed tomography angiography | Coronary artery calcium scoring by electron beam computed tomography since this modality is often used to screen asymptomatic patients for CAD
Comparators | Another NIT or coronary angiography | Study did not compare one NIT with another, or with coronary angiography
Outcomes | Primary outcome—accurate diagnosis of obstructive and nonobstructive CAD | Outcomes not related to diagnostic accuracy for detecting CAD
Outcomes | KQ 1 patient-level outcomes:; - Sensitivity; - Specificity; - True positive, false negative, true negative, false positive; - Indeterminate or technically inadequate results; - Prevalence | - Vessel-based outcomes; - Outcomes of women not reported separately from total population
Outcomes | KQ 2 outcomes: Predictors of diagnostic accuracy—age, race/ethnicity, body size, heart size, menopausal status, functional status, stress modality | Outcomes of women not reported separately from total population
Outcomes | KQ 3 outcomes:; - Risk stratification/prognostic information; - Treatment —none, medical therapy, percutaneous coronary intervention, or coronary artery bypass surgery; - Clinical outcomes—death, myocardial infarction, unstable angina, hospitalization, revascularization, angina relief, quality of life | Outcomes of women not reported separately from total population
Outcomes | KQ 4 outcomes: Safety and adverse events—radiation exposure, access site complications, contrast agent-induced nephropathy, nephrogenic systemic fibrosis, anaphylaxis, arrhythmias—and how these events varied by demographic factors | Outcomes of women not reported separately from total population
Setting | Inpatient or outpatient settings, primarily primary care and cardiology clinics | None
Publication languages | English only | Given the high volume of English-language publications (including the majority of known important studies), non-English articles were excluded

Abbreviations: CAD = coronary artery disease; KQ = Key Question; NIT = noninvasive technology

## Data Extraction and Data Management

The investigative team created forms for abstracting the data elements for the KQs. The data abstraction forms were piloted by two members of the study team, and refinements to clarify the questions and collection of data were added after the first week of data abstraction. The investigators who piloted the forms were also the main data abstractors. Based on their clinical and methodological expertise, two researchers were assigned to abstract data from the eligible articles pertaining to the research questions. One researcher abstracted the data, and the second overread the article and the accompanying abstraction form to check for accuracy and completeness. Disagreements were resolved by consensus or by obtaining a third reviewer’s opinion if consensus was not reached by the first two researchers. Any data changes during overreading were noted in a comment field. The overall interrater reliability was 0.76.

To aid in both reproducibility and standardization of data collection, researchers received data abstraction instructions directly on each form created specifically for this project with the DistillerSR data synthesis software program (Evidence Partners Inc., Manotick, ON, Canada). We designed these forms to collect the data required to evaluate the specified eligibility criteria for inclusion in this review as well as to collect demographics and data needed to determine outcomes (intermediate outcomes, health outcomes, and safety outcomes). The safety outcomes were framed to help identify radiation exposure, contrast agent-induced nephropathy, nephrogenic systemic fibrosis, anaphylaxis, and arrhythmias, which are the more common adverse events resulting from use of the different NITs. The abstraction form templates were pilot tested with a sample of included articles to ensure that all relevant data elements were captured and that there was consistency and reproducibility between abstractors. Appendix B lists the elements used in the data abstraction forms.

Appendix C contains a bibliography of all studies included in this review, organized alphabetically by author. When appropriate, methods articles providing additional detail were considered when abstracting data for an included study. If a methods article was used as a source for information in the abstraction of a study, it was included in the review and is listed in the bibliography in Appendix C.

## Individual Study Quality Assessment

The studies included in this comparative effectiveness review were assessed on the basis of the quality of their reporting of relevant data. We evaluated the quality of individual studies using the approach described in AHRQ’s Methods Guide for Effectiveness and Comparative Effectiveness Reviews (hereafter referred to as the Methods Guide).9 To assess study quality, we (1) classified the study design, (2) applied predefined criteria for quality and critical appraisal, and (3) made a summary judgment of the study’s quality. To evaluate methodological quality, we applied criteria for each study type that were derived from the core elements described in the Methods Guide9 and from QUADAS,12 a tool for the quality assessment of studies of diagnostic accuracy included in systematic reviews. To indicate the summary judgment of the quality of the individual studies, we used the summary ratings of Good, Fair, and Poor based on the study’s adherence to well-accepted standard methodologies (such as QUADAS) and adequate reporting standards.

Grading was outcome specific; thus, a given study may have been graded of different quality for two individual outcomes reported within that study. Study design was considered when grading quality. Randomized controlled trials were graded as Good, Fair, or Poor. Observational studies were graded separately also as Good, Fair, or Poor.

We used data abstracted on the population studied, the intervention and comparator, the outcomes measured, settings, and timing of assessments to identify specific issues that may have limited the applicability of individual studies or a body of evidence as recommended in the Methods Guide.9,13 We used these data to evaluate the applicability to clinical practice, paying special attention to study eligibility criteria, demographic features of the enrolled population in comparison with the target population, the intervention used in comparison with technologies currently in use, and clinical relevance and timing of the outcome measures. We summarized issues of applicability qualitatively. The quality grading and applicability were conducted in similar fashion to the rest of the data abstraction phase, with one investigator entering ratings, a second investigator overreading the entries, and disagreements resolved through consensus or a third party. Appendix D summarizes our assessment of the quality and applicability for each included study as well as the assessed QUADAS quality scores for diagnostic accuracy.

## Data Synthesis

We summarized the primary literature by abstracting relevant continuous data (e.g., age, sensitivity, specificity, event rates) and categorical data (e.g., race/ethnicity, presence of CAD). Data for patients with no known diagnosis of CAD were collected and analyzed separately from data for mixed CAD populations that included patients with and without known CAD. We then determined the feasibility of completing a quantitative synthesis (i.e., summary receiver operating characteristic [SROC] curves for diagnostic accuracy or meta-analysis for other outcomes). The feasibility of a meta-analysis or SROC curve depended on the volume of relevant literature, the homogeneity of the studies in terms of the populations studied, the interventions included, or the outcomes assessed, and the completeness of the results reporting. For each SROC calculation, we ran separate analyses of the accuracy of each NIT modality compared with coronary angiography on the no-known CAD and mixed CAD populations using random-effects models to quantitatively synthesize the available evidence. In our primary analyses, we evaluated these performance characteristics in the population of women who had no previously known CAD. In secondary analyses, we explored a broader patient population by including those studies that had women from a mixed population of known and no known CAD. We also assessed the impact on our findings if, in each population, we restricted our analyses to those studies that were assessed to be good quality. We then compared the performance characteristics of the NIT modalities with each other using a generalized linear mixed model to assess for differences in summary sensitivity and specificity between the NIT modalities (ECG, ECHO, SPECT, CTA, CMR), as well as differences in disease state (no known and mixed CAD). In a final exploratory analysis, we evaluated the test performance of the modalities in women compared with men in a separate generalized linear mixed model with sex (women, men) as a covariate. We presented summary estimates and confidence intervals (CIs).

For synthesizing the accuracy data for studies included in our assessment of KQ 1, we used the following approach as advocated by Leeflang,, et al.14 This approach allows the paired nature of sensitivity and specificity and randomness between studies to be taken into account. The analyses are based on true positive (TP), false negative (FN), false positive (FP), and true negative (TN) frequencies abstracted from relevant publications. Estimated study specific sensitivity (TP/[TP+FN]) and specificity (TN/[TN+FP]) values are displayed in paired forest plots together with exact 95 % CIs.15 The summary estimates of sensitivity and specificity resulted from random-effects modeling with two random effects, with each study being considered a random realization of the underlying true distribution. In the absence of covariates, both the bivariate random-effects model and the hierarchical model with random effects are mathematically equivalent.16 We used the GLIMMIX procedure in the SAS statistical package (SAS Institute; Cary, NC) with maximum likelihood estimation. A binomial error model was used with the logit link. The unstructured covariance matrix of the two random effects was considered during the fitting process, and its Cholesky parameterization was used.

The fixed-effects estimates and their variance–covariance matrix provided (after reverse logit transformation) summary sensitivity and specificity values and a joint confidence region (dotted oval shape on figures) as well as separate CIs for summary sensitivity and specificity as presented on figures and forest plots in the report. There were several possible choices for the SROC curve resulting from the random-effects modeling.17 We used the Rutter and Gatsonis18 SROC curve as described by Arends,, et al.,17 and it is presented in figures as a solid line over the range of the available data.

In addition to our SROC curve estimation, we evaluated other available outcomes. Most outcomes that we analyzed in this comparative effectiveness report were binary or categorical, and so we summarized these outcomes by proportions. We summarized inherently continuous variables, such as age, by mean, median, and standard deviation.

We also evaluated the potential of verification bias and other limitations of our synthesized analyses based on the underlying clinical domain and diagnostic testing practices. For example, angiography is often administered only to a subset of patients who are undergoing diagnostic tests within a studied population. This subset of patients is not a completely random sample because angiography-based verification of disease is often driven by previous test results and/or other considerations. We explored the potential for publication bias across the different modalities in our four populations of interest (studies of women with no known CAD, good-quality studies of women with no known CAD, studies of women from mixed populations, and good-quality studies of women from mixed populations). Using methods advocated by Deeks,, et al.,19 we computed for each study the diagnostic odds ratio (DOR) and the effective sample size (ESS). Subsequently we performed regression of natural logarithm of DOR against 1/ESS^1/2^ weighing by ESS, and reported the p value for testing whether slope is equal to zero. A nonsignificant p value indicated no evidence for publication bias.

To explore additional sources of potential bias, we also recorded whether the diagnostic tests were interpreted in a blinded fashion; that is, without knowledge of results of other diagnostic tests or clinical history and risk factors, if such information was available in the reviewed studies.

## Grading the Body of Evidence

The strength of evidence for each KQ was assessed using the approach described in AHRQ’s Methods Guide on Medical Test Reviews for grading the evidence related to the diagnostic accuracy of the NITs (KQ 1),20 and the Methods Guide for grading the evidence related to the other KQs (KQs 2–4).9,21 The outcomes used for grading the body of evidence for each KQ are outlined in Table 1. The evidence was evaluated using the four required domains: risk of bias (low, medium, or high), consistency (consistent, inconsistent, or unknown/not applicable), directness (direct or indirect), and precision (precise or imprecise). Additionally, when appropriate, the studies were evaluated for the presence of confounders that would diminish an observed effect, the strength of association (magnitude of effect), and publication bias. The strength of evidence was assigned an overall grade of High, Moderate, Low, or Insufficient according to the following four-level scale:

- High—High confidence that the evidence reflects the true effect. Further research is very unlikely to change our confidence in the estimate of effect.
- Moderate—Moderate confidence that the evidence reflects the true effect. Further research may change our confidence in the estimate of effect and may change the estimate.
- Low—Low confidence that the evidence reflects the true effect. Further research is likely to change the confidence in the estimate of effect and is likely to change the estimate.
- Insufficient—Evidence either is unavailable or does not permit estimation of effect.

## Peer Review and Public Commentary

The peer review process was our principal external quality-monitoring device. Nominations for peer reviewers were solicited from several sources, including the TEP and interested Federal agencies. The list of nominees was forwarded to AHRQ for vetting and approval. A list of reviewers submitting comments on this draft is included in the Preface of this report.