# Key Informants

Bonnie Arkus, R.N.

Executive Director

Women’s Heart Foundation

West Trenton, NJ

Javed Butler, M.D., M.P.H.

Associate Professor of Medicine

Emory University

Atlanta, GA

Brenda J. Clark

Go Red for Women

American Heart Association

Stacie Daugherty, M.D., M.S.P.H.

Assistant Professor of Cardiology

University of Colorado

Aurora, CO

John F. Heitner, M.D.

Director of Noninvasive Imaging

New York Methodist Hospital

Brooklyn, NY

Mark Hlatky, M.D.

Director, Stanford-Kaiser Cardiovascular Outcomes Research Center

Stanford University

Stanford, CA

Neil Jensen, M.B.A., M.H.A.

Director, Cardiology Networks

United HealthCare

Edina, MN

Marcel Salive, M.D., M.P.H.

Director, Division of Medical and Surgical Services

Centers for Medicare and Medicaid

Bethesda, MD