# Introduction

## Background

Cardiovascular disease is the leading cause of mortality for women in the United States.1 Coronary heart disease—which includes coronary artery (or atherosclerotic) disease (CAD), myocardial infarction (MI), acute coronary syndromes, and angina—is the largest subset of this mortality.1 According to the American Heart Association (AHA), approximately one in three female adults has some form of cardiovascular disease. Since 1984, the number of deaths attributed to cardiovascular disease in women has exceeded that in men, reaching 454,613 in 2005—more than deaths from all forms of cancer combined.2 It is estimated that 8.1 million women alive today have a history of heart attack, angina pectoris (chest pain or discomfort caused by reduced blood supply to the heart muscle), or both, and experts predict that in 2010 alone an estimated 370,000 women will have a new or recurrent MI. Overall, women who have had an acute MI—particularly those older than 55 years of age—have a worse prognosis than men, with a greater recurrence of MI and higher mortality.1 More women (5.5 million) than men (4.3 million) have angina in total numbers. Among women older than 20 years of age, non-Hispanic black women have the highest incidence of angina (6.7 percent) when compared with non-Hispanic whites (4.3 percent) and Mexican Americans (4.5 percent).2 However, the prevalence of CAD in women with chest pain is about 50 percent, as compared with 80 percent in men, which complicates diagnosis in women.3

The AHA suggests there is evidence showing that women at risk for CAD are less often referred for the appropriate diagnostic test than are men.1 Coronary anatomy and pathology have traditionally been defined and identified by invasive, catheter-based x-ray angiography, also referred to as coronary angiography.4 In this invasive procedure, a catheter is inserted into the femoral, brachial, or radial artery and passed up through the aorta to directly engage the right and left coronary arteries; an iodinated contrast agent is then injected into each artery while digital x-ray images are recorded.4 The major benefits of invasive coronary angiography over noninvasive techniques are that the use of a catheter makes it possible to see the coronary arteries with greater anatomic precision and resolution and to combine diagnosis and treatment in a single procedure. The limitations of the procedure include the invasive nature of the test and the limited data on the functional impact of a luminal obstruction. These limitations are generally considered to be minor when compared with the benefits of the procedure, and coronary angiography is now the reference (gold) standard for clinical care of patients who have chest pain suggestive of CAD.

Coronary angiography, however, is not risk-free.4 Arterial bleeding can occur at the access site, and manipulation of the catheter within the aorta and coronary arteries may cause an atherosclerotic embolus that, in turn, could result in stroke or heart attack. Separation of material from the inner lining of the artery may also cause a blockage downstream of the catheter tip. The contrast agent used during the procedure to visualize the coronary arteries may cause anaphylaxis or renal impairment or injury, and there is radiation exposure during the digital x-ray imaging. Although it is a rare occurrence, the catheter can puncture an artery and cause internal bleeding.

Coronary angiography is generally indicated in patients who have chest pain and are at high risk for CAD. For intermediate-risk patients, clinicians have a wide range of noninvasive diagnostic modalities to choose from, with wide variability in reported sensitivities and specificities. Noninvasive technologies (NITs) are especially important options for patients who have contraindications to invasive catheterization, or for those who would be put at higher risk for complications with invasive screening. Included in this group would be patients who have a higher risk of an embolic stroke because of extensive vascular disease in the aorta; those with endocarditis involving the aortic valve; and those who are at high risk for developing a pseudoaneurysm at the site of catheter insertion because of underlying vascular disease.4

### Types of Noninvasive Technologies

NITs can assess functional status (i.e., ischemia or no ischemia) or visualize anatomic abnormalities (i.e., no CAD, nonobstructive CAD, or obstructive CAD). Types of NITs include:

- Functional modalities:
  ○ Exercise/stress electrocardiography (ECG) exercise/stress or resting
  ○ Exercise/stress echocardiography (ECHO) with or without a contrast agent
  ○ Exercise/stress radionuclide myocardial perfusion imaging, including single proton emission computed tomography (SPECT) and positron emission tomography (PET)
- Anatomic modalities:
  ○ Stress myocardial perfusion and wall motion magnetic resonance imaging (CMR)
  ○ Coronary computed tomography angiography (coronary CTA)

The AHA and the American College of Cardiology (ACC) recommend that women with suspected CAD should be classified as either symptomatic or asymptomatic and further classified as being at low, intermediate, or high risk for the disease to guide the decision about which diagnostic test to use first.1 In 2005, the AHA developed a consensus statement on the role of noninvasive testing in the clinical evaluation of women with suspected CAD. In this statement, the AHA recommended that women who are symptomatic and at intermediate to high risk of having CAD should undergo noninvasive diagnostic studies (i.e., exercise electrocardiography and cardiac imaging studies) and that those who are asymptomatic and at low risk of CAD should not undergo cardiac imaging studies.1 The AHA consensus statement was a thorough synopsis of the extant literature regarding the diagnosis of CAD in women with expert-guided recommendations for the workup of symptomatic women but did not include a comparative effectiveness review of the accuracy of the various NIT modalities in women.

#### Functional Modalities

##### Electrocardiographic Modalities

Treadmill testing with exercise ECG is the oldest and most commonly used form of stress testing. It is widely available and has low initial costs. According to the joint AHA/ACC guidelines, women should undergo exercise testing if they have an intermediate risk of CAD on the basis of symptoms and risk factors.5 Factors that are unique to women (such as hormonal factors) have been reported to induce ECG changes during exercise that diminish the accuracy of the test. For exercise ECG, a positive test is defined, at peak exercise, by a significant ST segment horizontal or downsloping depression (significant level may vary by study as ≥1 mm, 1–2 mm, or ≥2 mm ST). ECG changes alone may not provide adequate prognostication. Exercise ECG has been recognized in the literature as being less sensitive and specific for diagnosing obstructive CAD in women than in men. Additional factors may improve the accuracy of the exercise test, such as chronotropic and hemodynamic responses to exercise. Despite sex-specific limitations, existing ACC/AHA guidelines propose that evidence of sex-specific limitations is insufficient to remove the stress exercise ECG test as the initial test for symptomatic women at intermediate risk for CAD who have normal resting ECG results and are capable of exercise.1,5 The AHA asserts that integrating other parameters into exercise scores (e.g., the Duke Treadmill Score, the ST/heart rate index) may improve the predictive value in women and that a positive ECG result in women indicates more diagnostic tests are necessary.1

Another ECG-based test is the newly developed Multifunction Cardiogram^®^ (Cardiac Analytics, Powell, OH). With this resting ECG technology, patients are tested while lying in a supine position. From the multifunction cardiogram machine, five ECG wires with electrodes are attached to the patient at the four standard limb-lead and precordial-lead V5 positions. An automatic simultaneous 2-lead (leads V5 and II) ECG sampling is recorded for 82 seconds with amplification and digitization, and the ECG data are then transmitted to a data center via an encrypted Internet connection. Results are then compiled into a report that can be reviewed on the multifunction cardiogram unit itself or on any computer that has a Web browser. At present, this device is not widely available.6

##### Echocardiographic Modalities

Exercise/stress ECHO is another noninvasive method for diagnosing CAD that provides information on the presence of left ventricular systolic or diastolic dysfunction, valvular heart disease, and the extent of infarction and stress-induced ischemia (defined as new or worsening wall motion abnormalities). Exercise ECHO can be performed using a treadmill or upright bicycle. In patients who cannot exercise, dobutamine is the most commonly used pharmacological stress agent. Vasodilator stress ECHO uses dipyridamole or adenosine. Contrast agents available for stress ECHO include SonoVue^®^, Optison™, and Luminity™. For stress ECHO, a positive test is defined by the evidence of new wall motion abnormalities in a different segment of the heart that can occur at stress only or at rest and stress. The AHA asserts that exercise/stress ECHO provides significantly higher specificity and accuracy for diagnosing obstructive CAD in women than standard exercise ECG testing does. Exercise/stress ECHO is recommended for women who are symptomatic and are at intermediate to high risk of CAD (women with suspected CAD must also have abnormal results from resting ECG), and dobutamine stress ECHO is recommended for women with normal or abnormal ECG results who are incapable of exercise.1 The significant advantages of stress ECHO over ECG are superior diagnostic performance, ability to localize areas of ischemia, and the option of performing stress testing on patients who are unable to exercise.3 According to a recent review, the overall sensitivities for exercise/stress ECHO are reported to be slightly lower in women than in men, although the specificities appear to be comparable for both.3

##### Myocardial Perfusion Imaging Modalities

Exercise/stress myocardial perfusion imaging, which includes SPECT, PET, and scintigraphy, is a nuclear-based technique that uses a combination of test elements to diagnose CAD. Of the imaging modalities, exercise SPECT, PET, and scintigraphy can be performed by using a treadmill or an upright bicycle. In patients who cannot exercise, the pharmacologic stress agents are dobutamine, adenosine, and dipyridamole. The radionuclides commonly used are technetium Tc 99m sestamibi (MIBI), thallous chloride TL-201 (thallium) and fluorodeoxyglucose.

SPECT is the most commonly performed stress imaging test in the United States, especially for men and women who are unable to exercise.1 Recently, the use of stress PET has increased. Parameters included in this modality are perfusion defects, global and regional left ventricular function, and left ventricular volumes. For myocardial perfusion imaging studies, a positive test is one that demonstrates reversible ischemia, and different scores can be used. The most frequently used is the summed stress score, which is a semiquantitative index obtained by adding the individual score derived from the 17 or 20 segments analyzed and scored during the stress study. Each segment is scored on a 5-point scale (0 = normal, 1 = slight reduction of tracer uptake, 2 = moderate reduction of tracer uptake, 3 = severe reduction of uptake, 4 = absence of uptake). A summed stress score <4 is considered normal; 4 to 8, mildly abnormal; 9 to 13, moderately abnormal; and >13, severely abnormal. Another score is based on the analysis of extent and severity of stress perfusion defect in the different segments of the left ventricle. This modality has been found to have technical limitations in women, including false-positive results, because of breast attenuation and a small left ventricular chamber size; however, recent advances in nuclear imaging have improved its accuracy (i.e., reduced the breast artifact).1

SPECT imaging is recommended for symptomatic women with an intermediate to high risk of CAD in the AHA 2005 consensus statement for the role of NIT in women.1 A higher prevalence of single-vessel CAD among women adversely affects the diagnostic accuracy of this modality (as well as the ECHO modality).3

#### Anatomic Modalities

ECG, ECHO, and myocardial perfusion imaging techniques do not provide direct visualization of coronary artery anatomy. They evaluate cardiac electrical activity, wall motion, or perfusion at rest and under stress, and any abnormal findings are used to make inferences about the presence and severity of obstructive CAD and the need for invasive coronary artery imaging. Other anatomic modalities provide direct visualization of coronary anatomy similar to that of coronary angiography but without invasive catheterization. These include cardiac magnetic resonance imaging (CMR) and coronary computed tomography angiography (coronary CTA). For CMR, a positive test is defined by the evidence of perfusion defects (extent and severity) and of wall motion abnormalities (at rest and/or at stress) in different left ventricular segments. For coronary CTA, a significant stenosis is defined quantitatively as at least a 50-percent narrowing (stenosis) of the coronary artery lumen.

Recently, the AHA published a scientific statement on CMR and coronary CTA in which recommendations were made for the general population and were not specific to women.7 The AHA states that both tests are suboptimal for patients with atrial fibrillation and other arrhythmias, and image quality may be further reduced by a high body mass index. Overall, the AHA concludes that the potential benefit of noninvasive coronary angiography is likely to be greatest for symptomatic patients who are at intermediate risk for CAD after initial risk stratification, including patients with equivocal stress test results. The AHA does not recommend that CMR or coronary CTA be used to screen for CAD in patients without symptoms; in particular, concerns about the radiation dose limit the use of coronary CTA in patients who have a very low pretest likelihood of coronary stenoses. At the same time, patients with a high pretest likelihood of coronary stenoses are likely to require intervention and invasive catheter angiography for definitive evaluation. The AHA asserts that the main advantages of coronary CTA, compared with CMR, are wider availability, higher spatial resolution, and more consistent, shorter examinations with better patient adherence. Advantages associated with CMR include the lack of need for ionizing radiation and an iodinated contrast agent. However, it is not clear whether the diagnostic accuracy or the relative balance of benefits and harms associated with either of these techniques differs between men and women.3,8

### Uncertainties Surrounding Noninvasive Diagnosis of CAD in Women

Noninvasive diagnosis of CAD in women is particularly challenging for many reasons. Women with chest pain demonstrate a lower prevalence of CAD, and their symptoms are less predictive and more often atypical when compared with those of men. Additionally, women are often older at the time of initial diagnosis; therefore, age-related comorbidities limit their tolerance for exercise testing.3 Thus, many factors affect the accuracy of diagnostic testing for CAD in women, including:

- Lower prevalence of CAD
- Higher prevalence of nonobstructive CAD (microvascular abnormalities, mitral valve prolapse)
- Less predictive symptomatology
- Limited exercise tolerance because of older age, obesity, and diabetes at initial diagnosis
- Different response to exercise than men
- Lower peak exercise values
- Lesser increase in the left ventricular ejection fraction
- Increase in cardiac output by enhancing end-diastolic volume
- Inappropriate catecholamine release
- Hormonal influences of estrogens mimicking a digitalis-like false-positive ECG response
- Anatomic differences affecting stress test results
- Female breast attenuation artifacts
- Smaller coronary artery size
- Smaller left ventricular chamber size
- Higher prevalence of single-vessel disease
- Poor left ventricular opacification on echocardiography

In addition to all the factors that may affect the accuracy of noninvasive testing in women, there is currently considerable variation in which tests are used and in which order. In the acute-care setting, patients are often referred for early invasive coronary angiography as the initial risk stratification test although lower risk patients may be evaluated first with noninvasive testing.4 After undergoing coronary angiography, some patients may be referred for noninvasive stress testing to define the functional significance of a coronary stenosis (constriction or narrowing) that is borderline in severity or is located such that the risk of treatment is increased.4 Some cardiovascular experts advocate for a diagnostic strategy that includes both anatomic information (from direct coronary imaging, traditionally performed by using catheter angiography) and functional information collected during exercise or pharmacological stress testing.4 Currently, there is no NIT modality that achieves both of these objectives.4

### Relevance

The goals of the diagnostic workup for women who have symptoms suspicious for CAD are to identify CAD with optimal accuracy and establish the basis for instituting preventive and therapeutic interventions.1 More effective diagnostic strategies are critical for women at risk of CAD because up to 40 percent of initial cardiac events are fatal.2 The literature suggests that, when compared with men, women are initially diagnosed with more advanced CAD because of the lack of early recognition and management.3 Therefore, a better understanding of how the accuracy of the many different noninvasive tests for CAD varies by sex could dramatically improve outcomes for many women.

Noninvasive testing of women for CAD also raises uncertainty for decisionmakers because invasive coronary angiography has non-negligible patient risk. In addition, it is costly, requiring expensive equipment and the time and skill of highly trained physicians and support staff.7 Although the use of noninvasive modalities to minimize the need for invasive procedures offers the possibility of better patient outcomes at lower cost, the wide range of diagnostic modalities—each with advantages and disadvantages for their use—makes it difficult for clinicians, patients, and payers to determine which test is best or should be used or covered in a given clinical situation.

## Scope and Key Questions

The following Key Questions (KQs) were considered in this comparative effectiveness review:

- KQ 1. What is the accuracy of one NIT in diagnosing obstructive and nonobstructive CAD when compared with another NIT or with coronary angiography in women with symptoms suspicious for CAD?
  ○ Exercise ECG stress test, including resting ECG technology (e.g., multifunctional cardiogram)
  ○ Exercise/stress ECHO with or without a contrast agent
  ○ Exercise/stress radionuclide myocardial perfusion imaging, including SPECT and PET
  ○ CMR imaging
  ○ Coronary CTA
- KQ 2. What are the predictors of diagnostic accuracy (e.g., age, race/ethnicity, body size, heart size, menopausal status, functional status, stress modality) of different NITs in women?
- KQ 3. Is there evidence that the use of NITs (when compared with other NITs or with coronary angiography) in women improves:
  ○ KQ 3a. Risk stratification/prognostic information?
  ○ KQ 3b. Decisionmaking regarding treatment options (e.g., revascularization, optimal medical therapy)?
  ○ KQ 3c. Clinical outcomes (e.g., death, myocardial infarction, unstable angina, hospitalization, revascularization, angina relief, quality of life)?
- KQ 4. Are there significant safety concerns/risks (i.e., radiation exposure, access site complications, contrast agent-induced nephropathy, nephrogenic systemic fibrosis, anaphylaxis, arrhythmias) associated with the use of different NITs to diagnose CAD in women with symptoms suspicious for CAD?