# Future Research

This comprehensive review of the comparative effectiveness of NIT modalities for diagnosing women with suspected CAD identified numerous gaps in evidence that would be suitable for future research and for improving the reporting of findings of NIT studies in the published literature.

Randomized trials comparing functional versus anatomic modalities. Almost all the studies reviewed were prospective observational studies where patients already scheduled for coronary angiography also underwent one or two NIT modalities to assess the diagnostic accuracy of the NITs. In routine clinical practice, clinicians order one type of NIT modality based on a patient’s ability to exercise, test availability, and clinician preference. Exercise ECG, stress ECHO, and nuclear imaging all measure functional parameters to assess for ischemia and obstructive CAD. Newer technologies such as coronary CTA and CMR offer clinicians the ability to evaluate anatomic parameters to assess both nonobstructive and obstructive CAD. A comparison of a functional testing strategy to an anatomic testing strategy for patients with symptomatic chest pain is currently being done in two large clinical trials (PROMISE [NCT001174550] and RESCUE [NCT01262625]). The information from these clinical trials could inform how the choice of an NIT modality affects the prognosis, treatment decisions, and clinical outcomes.

Studies assessing outcomes beyond diagnostic accuracy. Our review found very few comparative NIT studies that looked at the risk stratification, prognostic information, treatment decisions, and clinical outcomes. Future studies, whether observational or controlled clinical trials, should have long-term followup of patient cohorts to assess these factors. This is important because a positive NIT result could lead to further testing to establish the diagnosis of CAD as well as lead to more attention to secondary prevention for CAD. As stated previously, multiple testing or layered-testing strategies, plus the influence on risk-factor modification (e.g., medication prescriptions and adherence), are areas where significant research is needed.

Studies of sufficient sample size and representation of women. Many studies assessing the comparative diagnostic accuracy of an NIT modality with another NIT modality or with coronary angiography did not present a sample size calculation for the numbers needed per group. In addition, after excluding the women-only studies, the trials with both sexes had low representation of women. In order to assess sex differences in NIT diagnostic accuracy or the impact on clinical outcomes, a sufficient sample size is required to have adequate statistical power for subgroup analyses.

Reporting sex and CAD population subgroups separately. From 1662 citations, we excluded 1376 (83 percent) for not reporting data on women and 615 (37 percent) for looking only at a population with known CAD. Since publication of the AHRQ report on the use of NITs in women,10,11 there has been an increase in the number of studies reporting sex-based differences. We encourage more reporting of women results as well as separating the results from no known CAD and known CAD populations. One challenge we encountered in this review was that the primary data representing the numbers of TP, TN, FP, and FN were not presented in most studies and often needed to be back-calculated based on reported sensitivities and specificities and underlying disease prevalence for our quantitative synthesis. It would aid future comparisons of modalities if study authors were to report the primary data for women and men separately either within the article itself or within an online supplementary appendix.

Assessing clinical and demographic factors that influence diagnostic accuracy. Clinicians are taught that clinical factors such as weight, heart size, functional status, race/ethnicity, sex, age, and menopausal status can influence the diagnostic accuracy of various NIT modalities. However, we found very few comparative studies that looked at the impact of these clinical and demographic factors on the sensitivity and specificity of NIT results. More evidence about predictors affecting diagnostic cardiac testing is needed to support or dispel these long-held notions. Additional studies of the NIT modalities to assess differing symptomatology and timing at presentation, racial differences, various risk profiles, and different settings (outpatient, inpatient, emergency room) would be help to build the evidence base needed for clinical decisionmaking.

Reporting of risk, harms, and/or safety outcomes. Diagnostic procedures to screen for heart disease can result in harmful clinical events (nephropathy, radiation exposure, access site complications). Systematic reporting of adverse events in publications—in total and by sex—should continue to clarify which NIT modalities are safe after they are approved for use in clinical practice.