# List of Excluded Studies

All studies listed below were reviewed in their full-text version and excluded. Following each reference, in italics, is the reason for exclusion. Reasons for exclusion signify only the usefulness of the articles for this study and are not intended as criticisms of the articles.

Ababneh AA, Sciacca RR, Kim B, et al. Normal limits for left ventricular ejection fraction and volumes estimated with gated myocardial perfusion imaging in patients with normal exercise test results: influence of tracer, gender, and acquisition camera. J Nucl Cardiol. 2000;7(6):661-8. Full-text exclusion reason(s): Study does not compare one NIT to another or to diagnostic cardiac catheterization; No outcomes of interest. [pmid: 11144482].
Abaci A, Oguzhan A, Topsakal R, et al. Intracoronary electrocardiogram and angina pectoris during percutaneous coronary interventions as an assessment of myocardial viability: comparison with low-dose dobutamine echocardiography. Catheter Cardiovasc Interv. 2003;60(4):469-76. Full-text exclusion reason(s): No data for NITs of interest (ECG, ECHO, SPECT, PET, CMR, CTA). [pmid: 14624423].
Abbara S, Chow BJ, Pena AJ, et al. Assessment of left ventricular function with 16- and 64-slice multi-detector computed tomography. Eur J Radiol. 2008;67(3):481-6. Full-text exclusion reason(s): Data for women not reported as a subgroup; No outcomes of interest. [pmid: 17826936].
Abbott BG, Abdel-Aziz I, Nagula S, et al. Selective use of single-photon emission computed tomography myocardial perfusion imaging in a chest pain center. Am J Cardiol. 2001;87(12):1351-5. Full-text exclusion reason(s): Study does not compare one NIT to another or to diagnostic cardiac catheterization; Data for women not reported as a subgroup. [pmid: 11397352].
Abbott BG, Afshar M, Berger AK, et al. Prognostic significance of ischemic electrocardiographic changes during adenosine infusion in patients with normal myocardial perfusion imaging. J Nucl Cardiol. 2003;10(1):9-16. Full-text exclusion reason(s): Study does not compare one NIT to another or to diagnostic cardiac catheterization; Data for women not reported as a subgroup. [pmid: 12569326].
Abdelmoneim SS, Bernier M, Dhoble A, et al. Assessment of myocardial perfusion during adenosine stress using real time three-dimensional and two-dimensional myocardial contrast echocardiography: comparison with single-photon emission computed tomography. Echocardiography. 2010;27(4):421-9. Full-text exclusion reason(s): No women with symptomatic chest pain, or results are not reported separately for symptomatic subgroup; All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 20331695].
Abdelmoneim SS, Bernier M, Dhoble A, et al. Diagnostic accuracy of contrast echocardiography during adenosine stress for detection of abnormal myocardial perfusion: a prospective comparison with technetium-99 m sestamibi single-photon emission computed tomography. Heart Vessels. 2010;25(2):121-30. Full-text exclusion reason(s): No women with symptomatic chest pain, or results are not reported separately for symptomatic subgroup; All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 20339973].
Abdelmoneim SS, Bernier M, Scott CG, et al. Safety of contrast agent use during stress echocardiography: a 4-year experience from a single-center cohort study of 26,774 patients. JACC Cardiovasc Imaging. 2009;2(9):1048-56. Full-text exclusion reason(s): No data for NITs of interest (ECG, ECHO, SPECT, PET, CMR, CTA). [pmid: 19761981].
Abdelmoneim SS, Dhoble A, Bernier M, et al. Quantitative myocardial contrast echocardiography during pharmacological stress for diagnosis of coronary artery disease: a systematic review and meta-analysis of diagnostic accuracy studies. Eur J Echocardiogr. 2009;10(7):813-25. Full-text exclusion reason(s): Not a clinical study report. [pmid: 19549700].
Abdelmoneim SS, Dhoble A, Bernier M, et al. Absolute myocardial blood flow determination using real-time myocardial contrast echocardiography during adenosine stress: comparison with single-photon emission computed tomography. Heart. 2009;95(20):1662-8. Full-text exclusion reason(s): No women with symptomatic chest pain, or results are not reported separately for symptomatic subgroup; All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 19584062].
Abdullah SM, Khera A, Das SR, et al. Relation of coronary atherosclerosis determined by electron beam computed tomography and plasma levels of n-terminal pro-brain natriuretic peptide in a multiethnic population-based sample (the Dallas Heart Study). Am J Cardiol. 2005;96(9):1284-9. Full-text exclusion reason(s): Study does not compare one NIT to another or to diagnostic cardiac catheterization; Data for women not reported as a subgroup; No outcomes of interest. [pmid: 16253599].
Abidov A, Bax JJ, Hayes SW, et al. Transient ischemic dilation ratio of the left ventricle is a significant predictor of future cardiac events in patients with otherwise normal myocardial perfusion SPECT. J Am Coll Cardiol. 2003;42(10):1818-25. Full-text exclusion reason(s): Study does not compare one NIT to another or to diagnostic cardiac catheterization; Data for women not reported as a subgroup. [pmid: 14642694].
Abidov A, Gallagher MJ, Chinnaiyan KM, et al. Clinical effectiveness of coronary computed tomographic angiography in the triage of patients to cardiac catheterization and revascularization after inconclusive stress testing: results of a 2-year prospective trial. J Nucl Cardiol. 2009;16(5):701-13. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 19626385].
Abitbol E, Monin JL, Garot J, et al. Relationship between the ischemic threshold at the onset of wall-motion abnormality on semisupine exercise echocardiography and the extent of coronary artery disease. J Am Soc Echocardiogr. 2004;17(2):121-5. Full-text exclusion reason(s): All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 14752485].
Aboul-Enein FA, Hayes SW, Matsumoto N, et al. Rest perfusion defects in patients with no history of myocardial infarction predict the presence of a critical coronary artery stenosis. J Nucl Cardiol. 2003;10(6):656-62. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 14668778].
Abraham A, Kass M, Ruddy TD, et al. Right and left ventricular uptake with Rb-82 PET myocardial perfusion imaging: markers of left main or 3 vessel disease. J Nucl Cardiol. 2010;17(1):52-60. Full-text exclusion reason(s): No women with symptomatic chest pain, or results are not reported separately for symptomatic subgroup; Data for women not reported as a subgroup. [pmid: 19826892].
Acampa W, Petretta M, Florimonte L, et al. Prognostic value of exercise cardiac tomography performed late after percutaneous coronary intervention in symptomatic and symptom-free patients. Am J Cardiol. 2003;91(3):259-63. Full-text exclusion reason(s): All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 12565079].
Acarturk E, Bozkurt A, Cayli M, et al. Mitral annular calcification and aortic valve calcification may help in predicting significant coronary artery disease. Angiology. 2003;54(5):561-7. Full-text exclusion reason(s): Study does not compare one NIT to another or to diagnostic cardiac catheterization; Data for women not reported as a subgroup. [pmid: 14565631].
Achenbach S, Giesler T, Ropers D, et al. Detection of coronary artery stenoses by contrast-enhanced, retrospectively electrocardiographically-gated, multislice spiral computed tomography. Circulation. 2001;103(21):2535-8. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 11382719].
Achenbach S, Goroll T, Seltmann M, et al. Detection of coronary artery stenoses by low-dose, prospectively ECG-triggered, high-pitch spiral coronary CT angiography. JACC Cardiovasc Imaging. 2011;4(4):328-37. Full-text exclusion reason(s): Data for women not reported as a subgroup; No outcomes of interest. [pmid: 21492807].
Achenbach S, Ropers D, Pohle FK, et al. Detection of coronary artery stenoses using multi-detector CT with 16 x 0.75 collimation and 375 ms rotation. Eur Heart J. 2005;26(19):1978-86. Full-text exclusion reason(s): Data for women not reported as a subgroup; No outcomes of interest. [pmid: 15923203].
Achenbach S, Ropers U, Kuettner A, et al. Randomized comparison of 64-slice single- and dual-source computed tomography coronary angiography for the detection of coronary artery disease. JACC Cardiovasc Imaging. 2008;1(2):177-86. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 19356426].
Adams GL, Trimble MA, Brosnan RB, et al. Evaluation of combined cardiac positron emission tomography and coronary computed tomography angiography for the detection of coronary artery disease. Nucl Med Commun. 2008;29(7):593-8. Full-text exclusion reason(s): No women with symptomatic chest pain, or results are not reported separately for symptomatic subgroup; Data for women not reported as a subgroup. [pmid: 18528180].
Adamu U, Knollmann D, Almutairi B, et al. Stress/rest myocardial perfusion scintigraphy in patients without significant coronary artery disease. J Nucl Cardiol. 2010;17(1):38-44. Full-text exclusion reason(s): No women with symptomatic chest pain, or results are not reported separately for symptomatic subgroup; Data for women not reported as a subgroup. [pmid: 19705212].
Adler Y, Vaturi M, Herz I, et al. Nonobstructive aortic valve calcification: a window to significant coronary artery disease. Atherosclerosis. 2002;161(1):193-7. Full-text exclusion reason(s): No data for NITs of interest (ECG, ECHO, SPECT, PET, CMR, CTA). [pmid: 11882332].
Aepfelbacher FC, Johnson RB, Schwartz JG, et al. Validation of a model of left ventricular segmentation for interpretation of SPET myocardial perfusion images. Eur J Nucl Med. 2001;28(11):1624-9. Full-text exclusion reason(s): All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 11702103].
Aessopos A, Tsironi M, Vassiliadis I, et al. Exercise-induced myocardial perfusion abnormalities in sickle beta-thalassemia: Tc-99m tetrofosmin gated SPECT imaging study. Am J Med. 2001;111(5):355-60. Full-text exclusion reason(s): No women with symptomatic chest pain, or results are not reported separately for symptomatic subgroup; No outcomes of interest. [pmid: 11583637].
Afonso L, Mahajan N. Single-photon emission computed tomography myocardial perfusion imaging in the diagnosis of left main disease. Clin Cardiol. 2009;32(12):E11-5. Full-text exclusion reason(s): No women with symptomatic chest pain, or results are not reported separately for symptomatic subgroup; All women in the study are known to have CAD. [pmid: 20014205].
Agarwal PP, Patel S, Corbett J, et al. Left ventricular functional analysis with 16- and 64-row multidetector computed tomography: comparison with gated single-photon emission computed tomography. J Comput Assist Tomogr. 2009;33(1):8-14. Full-text exclusion reason(s): All women in the study are known to have CAD; Data for women not reported as a subgroup; No outcomes of interest. [pmid: 19188778].
Aggeli C, Christoforatou E, Giannopoulos G, et al. The diagnostic value of adenosine stress-contrast echocardiography for diagnosis of coronary artery disease in hypertensive patients: comparison to Tl-201 single-photon emission computed tomography. Am J Hypertens. 2007;20(5):533-8. Full-text exclusion reason(s): No women with symptomatic chest pain, or results are not reported separately for symptomatic subgroup. [pmid: 17485016].
Aggeli C, Giannopoulos G, Misovoulos P, et al. Real-time three-dimensional dobutamine stress echocardiography for coronary artery disease diagnosis: validation with coronary angiography. Heart. 2007;93(6):672-5. Full-text exclusion reason(s): Data for women not reported as a subgroup; No outcomes of interest. [pmid: 17085530].
Ahlberg AW, Baghdasarian SB, Athar H, et al. Symptom-limited exercise combined with dipyridamole stress: prognostic value in assessment of known or suspected coronary artery disease by use of gated SPECT imaging. J Nucl Cardiol. 2008;15(1):42-56. Full-text exclusion reason(s): No women with symptomatic chest pain, or results are not reported separately for symptomatic subgroup; All women in the study are known to have CAD; No outcomes of interest. [pmid: 18242479].
Ahmad M, Xie T, McCulloch M, et al. Real-time three-dimensional dobutamine stress echocardiography in assessment stress echocardiography in assessment of ischemia: comparison with two-dimensional dobutamine stress echocardiography. J Am Coll Cardiol. 2001;37(5):1303-9. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 11300439].
Ahmadi N, Nabavi V, Hajsadeghi F, et al. Impaired aortic distensibility measured by computed tomography is associated with the severity of coronary artery disease. Int J Cardiovasc Imaging. 2010. Full-text exclusion reason(s): No women with symptomatic chest pain, or results are not reported separately for symptomatic subgroup; Study does not compare one NIT to another or to diagnostic cardiac catheterization; No outcomes of interest.
Ahmadi N, Nabavi V, Hajsadeghi F, et al. Mortality incidence of patients with non-obstructive coronary artery disease diagnosed by computed tomography angiography. Am J Cardiol. 2011;107(1):10-6. Full-text exclusion reason(s): No women with symptomatic chest pain, or results are not reported separately for symptomatic subgroup; Study does not compare one NIT to another or to diagnostic cardiac catheterization; Data for women not reported as a subgroup. [pmid: 21146679].
Ahmadi N, Shavelle D, Nabavi V, et al. Coronary distensibility index measured by computed tomography is associated with the severity of coronary artery disease. J Cardiovasc Comput Tomogr. 2010;4(2):119-26. Full-text exclusion reason(s): Study does not compare one NIT to another or to diagnostic cardiac catheterization; Data for women not reported as a subgroup; No outcomes of interest. [pmid: 20430343].
Ahmed B, Merz CNB, Sopko G. Are we ‘WISE’r? Findings from the NHLBI-sponsored Women’s Ischemia Syndrome Evaluation study. Women’s Health. 2006;2(1):57-64. Full-text exclusion reason(s): Not a clinical study report.
Ahn JM, Kang SJ, Mintz GS, et al. Validation of minimal luminal area measured by intravascular ultrasound for assessment of functionally significant coronary stenosis: Comparison with myocardial perfusion imaging. JACC: Cardiovascular Interventions. 2011;4(6):665-671. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 21700253].
Akinboboye OO, Idris O, Onwuanyi A, et al. Incidence of major cardiovascular events in black patients with normal myocardial stress perfusion study results. J Nucl Cardiol. 2001;8(5):541-7. Full-text exclusion reason(s): No women with symptomatic chest pain, or results are not reported separately for symptomatic subgroup; All women in the study are known to have CAD; Study does not compare one NIT to another or to diagnostic cardiac catheterization; Data for women not reported as a subgroup; No outcomes of interest. [pmid: 11593217].
Akram K, Voros S. Absolute coronary artery calcium scores are superior to MESA percentile rank in predicting obstructive coronary artery disease. Int J Cardiovasc Imaging. 2008;24(7):743-9. Full-text exclusion reason(s): No women with symptomatic chest pain, or results are not reported separately for symptomatic subgroup; Study does not compare one NIT to another or to diagnostic cardiac catheterization. [pmid: 18351440].
Al Moudi M, Sun Z, Lenzo N. Diagnostic value of SPECT, PET and PET/CT in the diagnosis of coronary artery disease: A systematic review. Biomedical Imaging and Intervention Journal. 2011;7(2). Full-text exclusion reason(s): Conference abstract or trial registry posting.
Al-Attar AT, Mahussain SA, Sadanandan S. Cardiac tests in asymptomatic type 2 diabetics. Med Princ Pract. 2002;11(4):171-5. Full-text exclusion reason(s): No women with symptomatic chest pain, or results are not reported separately for symptomatic subgroup; Data for women not reported as a subgroup. [pmid: 12424409].
Albro PC, Gould KL, Westcott RJ, et al. Noninvasive assessment of coronary stenoses by myocardial imaging during pharmacologic coronary vasodilatation. III. Clinical trial. Am J Cardiol. 1978;42(5):751-60. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 707288].
Aldrovandi A, Cademartiri F, Menozzi A, et al. Evaluation of coronary atherosclerosis by multislice computed tomography in patients with acute myocardial infarction and without significant coronary artery stenosis: a comparative study with quantitative coronary angiography. Circ Cardiovasc Imaging. 2008;1(3):205-11. Full-text exclusion reason(s): All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 19808544].
Aldrovandi A, Maffei E, Palumbo A, et al. Prognostic value of computed tomography coronary angiography in patients with suspected coronary artery disease: a 24-month follow-up study. Eur Radiol. 2009;19(7):1653-60. Full-text exclusion reason(s): No women with symptomatic chest pain, or results are not reported separately for symptomatic subgroup; Study does not compare one NIT to another or to diagnostic cardiac catheterization; Data for women not reported as a subgroup. [pmid: 19224218].
Alessandri N, Di Matteo A, Rondoni G, et al. Heart imaging: the accuracy of the 64-MSCT in the detection of coronary artery disease. Eur Rev Med Pharmacol Sci. 2009;13(3):163-71. Full-text exclusion reason(s): All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 19673166].
Alexander W, Mehta SR, Giugliano RP. American Heart Association. 2008 Scientific Sessions: The TMACS trial. P and T. 2009;34(1):30. Full-text exclusion reason(s): Conference abstract or trial registry posting. [pmid: 19562003].
Alexanderson E, Mannting F, Gomez-Martin D, et al. Technetium-99m-Sestamibi SPECT myocardial perfusion imaging in patients with complete left bundle branch block. Arch Med Res. 2004;35(2):150-6. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 15010196].
Alexopoulos D, Stathopoulos C, Kotrsaridis A, et al. Coronary artery calcium by digital cinefluoroscopy in patients with pain suggestive of an acute coronary syndrome. Clin Cardiol. 2005;28(2):81-4. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 15757079].
Ali M, Mallick NH, Abid AR, et al. Significance of perfusion defects on dipyridamole thallium cardiac SPECT in patients with left bundle branch block. J Ayub Med Coll Abbottabad. 2007;19(4):21-5. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 18693590].
Alkadhi H, Scheffel H, Desbiolles L, et al. Dual-source computed tomography coronary angiography: influence of obesity, calcium load, and heart rate on diagnostic accuracy. Eur Heart J. 2008;29(6):766-76. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 18292596].
Alkadhi H, Stolzmann P, Desbiolles L, et al. Low-dose, 128-slice, dual-source CT coronary angiography: accuracy and radiation dose of the high-pitch and the step-and-shoot mode. Heart. 2010;96(12):933-8. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 20538669].
Alkadhi H, Stolzmann P, Desbiolles L, et al. Low-dose, 128-slice, dual-source CT coronary angiography: accuracy and radiation dose of the high-pitch and the step-and-shoot mode. Heart. 2010:933-8. [pmid: 20538669].
Al-Khalili F, Janszky I, Andersson A, et al. Physical activity and exercise performance predict long-term prognosis in middle-aged women surviving acute coronary syndrome. J Intern Med. 2007;261(2):178-87. Full-text exclusion reason(s): All women in the study are known to have CAD; Study does not compare one NIT to another or to diagnostic cardiac catheterization; No outcomes of interest. [pmid: 17241183].
Allison JS, Heo J, Iskandrian AE. Artificial neural network modeling of stress single-photon emission computed tomographic imaging for detecting extensive coronary artery disease. Am J Cardiol. 2005;95(2):178-81. Full-text exclusion reason(s): All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 15642548].
Allman KC, Berry J, Sucharski LA, et al. Determination of extent and location of coronary artery disease in patients without prior myocardial infarction by thallium-201 tomography with pharmacologic stress. J Nucl Med. 1992;33(12):2067-73. Full-text exclusion reason(s): No women with symptomatic chest pain, or results are not reported separately for symptomatic subgroup; Data for women not reported as a subgroup. [pmid: 1460494].
Al-Mallah M, Alqaisi F, Arafeh A, et al. Long term favorable prognostic value of negative treadmill echocardiogram in the setting of abnormal treadmill electrocardiogram: a 95 month median duration follow-up study. J Am Soc Echocardiogr. 2008;21(9):1018-22. Full-text exclusion reason(s): All women in the study are known to have CAD; Study does not compare one NIT to another or to diagnostic cardiac catheterization; Data for women not reported as a subgroup. [pmid: 18650063].
Al-Mallah MH, Hachamovitch R, Dorbala S, et al. Incremental prognostic value of myocardial perfusion imaging in patients referred to stress single-photon emission computed tomography with renal dysfunction. Circ Cardiovasc Imaging. 2009;2(6):429-36. Full-text exclusion reason(s): No women with symptomatic chest pain, or results are not reported separately for symptomatic subgroup; All women in the study are known to have CAD; Study does not compare one NIT to another or to diagnostic cardiac catheterization; Data for women not reported as a subgroup. [pmid: 19920040].
Al-Mallah MH, Sitek A, Moore SC, et al. Assessment of myocardial perfusion and function with PET and PET/CT. J Nucl Cardiol. 2010;17(3):498-513. Full-text exclusion reason(s): Not original peer-reviewed data or a secondary analysis of RCT, prospective or retrospective observational study, or registry. [pmid: 20379862].
Almeda FQ, Shah R, Senter S, et al. Clinical and angiographic profile of patients with markedly elevated coronary calcium scores (>or=1000) detected by electron beam computed tomography. Cardiovasc Radiat Med. 2004;5(3):109-12. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 15721844].
Almeida AG, Gabriel HM, Coutinho CA, et al. Myocardial perfusion and angioplasty. Comparison of myocardial contrast echocardiography and scintigraphy. Rev Port Cardiol. 2002;21(7–8):859-68. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 12369175].
Almeida MC, Markman Filho B. Prognostic value of dipyridamole stress echocardiography in women. Arq Bras Cardiol. 2011;96(1):31-7. Full-text exclusion reason(s): All women in the study are known to have CAD; Study does not compare one NIT to another or to diagnostic cardiac catheterization. [pmid: 21109908].
Alqaisi F, Albadarin F, Jaffery Z, et al. Prognostic predictors and outcomes in patients with abnormal myocardial perfusion imaging and angiographically insignificant coronary artery disease. J Nucl Cardiol. 2008;15(6):754-61. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 18984450].
Al-Saadi N, Nagel E, Gross M, et al. Noninvasive detection of myocardial ischemia from perfusion reserve based on cardiovascular magnetic resonance. Circulation. 2000;101(12):1379-83. Full-text exclusion reason(s): No women with symptomatic chest pain, or results are not reported separately for symptomatic subgroup; Data for women not reported as a subgroup. [pmid: 10736280].
Amanullah AM. Diagnostic and prognostic value of myocardial perfusion imaging in patients with known or suspected stable coronary artery disease. Echocardiography. 2000;17(6 Pt 1):587-95. Full-text exclusion reason(s): Not original peer-reviewed data or a secondary analysis of RCT, prospective or retrospective observational study, or registry. [pmid: 11000598].
Amanullah AM, Berman DS, Kiat H, et al. Usefulness of hemodynamic changes during adenosine infusion in predicting the diagnostic accuracy of adenosine technetium-99m sestamibi single-photon emission computed tomography (SPECT). Am J Cardiol. 1997;79(10):1319-22. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 9165150].
Amanullah AM, Bevegard S, Lindvall K, et al. Assessment of left ventricular wall motion in angina pectoris by two-dimensional echocardiography and myocardial perfusion by technetium-99m sestamibi tomography during adenosine-induced coronary vasodilation and comparison with coronary angiography. Am J Cardiol. 1993;72(14):983-9. Full-text exclusion reason(s): No women with symptomatic chest pain, or results are not reported separately for symptomatic subgroup; All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 8213598].
Ambrosi P, Bruneau P, Faugere G, et al. Prognostic value of thallium-201 myocardial scintigraphy in patients with hypertension, suspected of coronary disease. Ann Cardiol Angeiol (Paris). 1993;42(9):479-83. Full-text exclusion reason(s): Non-English. [pmid: 8122863].
Amemiya S, Takao H. Computed tomographic coronary angiography for diagnosing stable coronary artery disease: a cost-utility and cost-effectiveness analysis. Circ J. 2009;73(7):1263-70. Full-text exclusion reason(s): Not original peer-reviewed data or a secondary analysis of RCT, prospective or retrospective observational study, or registry. [pmid: 19436120].
Amici E, Cortigiani L, Coletta C, et al. Usefulness of pharmacologic stress echocardiography for the long-term prognostic assessment of patients with typical versus atypical chest pain. Am J Cardiol. 2003;91(4):440-2. Full-text exclusion reason(s): Study does not compare one NIT to another or to diagnostic cardiac catheterization; Data for women not reported as a subgroup. [pmid: 12586260].
Ammann P, Naegeli B, Rickli H, et al. Characteristics of patients with abnormal stress technetium Tc 99m sestamibi SPECT studies without significant coronary artery diameter stenoses. Clin Cardiol. 2003;26(11):521-4. Full-text exclusion reason(s): No women with symptomatic chest pain, or results are not reported separately for symptomatic subgroup; All women in the study are known to have CAD; Data for women not reported as a subgroup; No outcomes of interest. [pmid: 14640468].
Anagnostopoulos C, Almonacid A, El Fakhri G, et al. Quantitative relationship between coronary vasodilator reserve assessed by 82Rb PET imaging and coronary artery stenosis severity. Eur J Nucl Med Mol Imaging. 2008;35(9):1593-601. Full-text exclusion reason(s): No women with symptomatic chest pain, or results are not reported separately for symptomatic subgroup; All women in the study are known to have CAD; Study does not compare one NIT to another or to diagnostic cardiac catheterization; Data for women not reported as a subgroup; No outcomes of interest. [pmid: 18425513].
Anand DV, Lim E, Raval U, et al. Prevalence of silent myocardial ischemia in asymptomatic individuals with subclinical atherosclerosis detected by electron beam tomography. J Nucl Cardiol. 2004;11(4):450-7. Full-text exclusion reason(s): No women with symptomatic chest pain, or results are not reported separately for symptomatic subgroup; Study does not compare one NIT to another or to diagnostic cardiac catheterization; Data for women not reported as a subgroup. [pmid: 15295414].
Andersen K, Hennersdorf M, Cohnen M, et al. Myocardial delayed contrast enhancement in patients with arterial hypertension: initial results of cardiac MRI. Eur J Radiol. 2009;71(1):75-81. Full-text exclusion reason(s): Data for women not reported as a subgroup; No outcomes of interest. [pmid: 18434065].
Andrade JM, Gowdak LH, Giorgi MC, et al. Cardiac MRI for detection of unrecognized myocardial infarction in patients with end-stage renal disease: comparison with ECG and scintigraphy. AJR Am J Roentgenol. 2009;193(1):W25-32. Full-text exclusion reason(s): All women in the study are known to have CAD; Data for women not reported as a subgroup; No outcomes of interest. [pmid: 19542379].
Andrade MJ, Picano E, Pingitore A, et al. Dipyridamole stress echocardiography in patients with severe left main coronary artery narrowing. Echo Persantine International Cooperative (EPIC) Study Group—Subproject “Left Main Detection”. Am J Cardiol. 1994;73(7):450-5. Full-text exclusion reason(s): All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 8141085].
Andreini D, Pontone G, Ballerini G, et al. Feasibility and diagnostic accuracy of 16-slice multidetector computed tomography coronary angiography in 500 consecutive patients: critical role of heart rate. Int J Cardiovasc Imaging. 2007;23(6):789-801. Full-text exclusion reason(s): No women with symptomatic chest pain, or results are not reported separately for symptomatic subgroup; All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 17357824].
Andreini D, Pontone G, Bartorelli AL, et al. Comparison of the diagnostic performance of 64-slice computed tomography coronary angiography in diabetic and non-diabetic patients with suspected coronary artery disease. Cardiovasc Diabetol. 2010;9:80. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 21114858].
Anjaneyulu A, Raghu K, Chandramukhi S, et al. Evaluation of left main coronary artery stenosis by transthoracic echocardiography. J Am Soc Echocardiogr. 2008;21(7):855-60. Full-text exclusion reason(s): No data for NITs of interest (ECG, ECHO, SPECT, PET, CMR, CTA). [pmid: 18325732].
Anthopoulos LP, Bonou MS, Kardaras FG, et al. Stress echocardiography in elderly patients with coronary artery disease: applicability, safety and prognostic value of dobutamine and adenosine echocardiography in elderly patients. J Am Coll Cardiol. 1996;28(1):52-9. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 8752794].
Anthopoulos LP, Bonou MS, Sioras EP, et al. Echocardiographic detection of the extent of coronary artery disease in the elderly using dobutamine and adenosine infusion. Coron Artery Dis. 1997;8(10):633-43. Full-text exclusion reason(s): No women with symptomatic chest pain, or results are not reported separately for symptomatic subgroup; All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 9457445].
Arantes RL, Gowdak LH, Paula FJ, et al. Myocardial scintigraphy and clinical stratification as predictors of events in renal transplant candidates. J Nephrol. 2010;23(3):314-20. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 20349410].
Ariff B, Thom SA, Foale RA, et al. Stress echocardiography for the diagnosis of ischaemia in hypertensives. Journal of human hypertension. 2000;(6):399-401. Full-text exclusion reason(s): No women with symptomatic chest pain, or results are not reported separately for symptomatic subgroup; All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 10878704].
Ariyarajah V, Kranis M, Apiyasawat S, et al. Association of myocardial ischemia and coronary angiographic lesions with increased left atrial dimension during exercise tolerance tests among patients without known coronary heart disease. Am J Cardiol. 2007;99(9):1187-92. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 17478138].
Arnold J, Selvanayagam J. Non-invasive Detection of Coronary Artery Disease Using Blood Oxygen Leveldependent Magnetic Resonance Imaging at 3 Tesla. 2009 American Heart Association Scientific Sessions, Orange County Convention Center. Orlando, Florida. 14–18 Nov 2009. 2009. Full-text exclusion reason(s): Conference abstract or trial registry posting.
Arnold JR, Karamitsos TD, Bhamra-Ariza P, et al. Blood oxygen level-dependent magnetic resonance imaging at 3 Tesla in coronary artery disease: Validation using quantitative coronary angiography and cardiovascular magnetic resonance perfusion imaging. Journal of Cardiovascular Magnetic Resonance. 2010;12:35. Full-text exclusion reason(s): Conference abstract or trial registry posting. [pmid: 20525337].
Arnoldi E, Gebregziabher M, Schoepf UJ, et al. Automated computer-aided stenosis detection at coronary CT angiography: initial experience. Eur Radiol. 2010;20(5):1160-7. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 19890640].
Arruda AL, Barretto RB, Shub C, et al. Prognostic significance of ST-segment elevation during dobutamine stress echocardiography. Am Heart J. 2006;151(3):744 e1-744 e6. Full-text exclusion reason(s): No women with symptomatic chest pain, or results are not reported separately for symptomatic subgroup; All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 16504644].
Arruda AM, Das MK, Roger VL, et al. Prognostic value of exercise echocardiography in 2,632 patients > or = 65 years of age. J Am Coll Cardiol. 2001;37(4):1036-41. Full-text exclusion reason(s): All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 11263605].
Arruda-Olson AM, Juracan EM, Mahoney DW, et al. Prognostic value of exercise echocardiography in 5,798 patients: is there a gender difference?. J Am Coll Cardiol. 2002;39(4):625-31. Full-text exclusion reason(s): No women with symptomatic chest pain, or results are not reported separately for symptomatic subgroup; All women in the study are known to have CAD; Study does not compare one NIT to another or to diagnostic cardiac catheterization. [pmid: 11849861].
Ashley EA, Myers J, Froelicher V. Exercise testing in clinical medicine. Lancet. 2000;356(9241):1592-1597. Full-text exclusion reason(s): Not original peer-reviewed data or a secondary analysis of RCT, prospective or retrospective observational study, or registry. [pmid: 11075788].
Askew JW, Miller TD, Araoz PA, et al. Abnormal electron beam computed tomography results: the value of repeating myocardial perfusion single-photon emission computed tomography in the ongoing assessment of coronary artery disease. Mayo Clin Proc. 2008;83(1):17-22. Full-text exclusion reason(s): No women with symptomatic chest pain, or results are not reported separately for symptomatic subgroup; Data for women not reported as a subgroup. [pmid: 18174005].
Aslam M, Ziaul S, Anwar MA, et al. Accuracy of thallium scintigraphy versus coronary angiography for coronary artery disease in diabetics. J Coll Physicians Surg Pak. 2010;20(1):6-9. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 20141685].
Assomull RG, Lyne JC, Keenan N, et al. The role of cardiovascular magnetic resonance in patients presenting with chest pain, raised troponin, and unobstructed coronary arteries. Eur Heart J. 2007;28(10):1242-9. Full-text exclusion reason(s): Data for women not reported as a subgroup; No outcomes of interest. [pmid: 17478458].
Astarita C, Palinkas A, Nicolai E, et al. Dipyridamole-atropine stress echocardiography versus exercise SPECT scintigraphy for detection of coronary artery disease in hypertensives with positive exercise test. J Hypertens. 2001;19(3):495-502. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 11288820].
Astorri E, Pattoneri P, Calbiani B, et al. Thallium-201 myocardial perfusion imaging in patients with systemic lupus erythematosus. Minerva Cardioangiol. 2004;52(1):49-54. Full-text exclusion reason(s): Not a clinical study report. [pmid: 14765038].
Atak R, Turhan H, Sezgin AT, et al. Effects of slow coronary artery flow on QT interval duration and dispersion. Ann Noninvasive Electrocardiol. 2003;8(2):107-11. Full-text exclusion reason(s): No data for NITs of interest (ECG, ECHO, SPECT, PET, CMR, CTA). [pmid: 12848790].
Atar S, Cercek B, Nagai T, et al. Transthoracic stress echocardiography with transesophageal atrial pacing for bedside evaluation of inducible myocardial ischemia in patients with new-onset chest pain. Am J Cardiol. 2000;86(1):12-6. Full-text exclusion reason(s): All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 10867085].
Atar S, Feldman A, Darawshe A, et al. Utility and diagnostic accuracy of hand-carried ultrasound for emergency room evaluation of chest pain. Am J Cardiol. 2004;94(3):408-9. Full-text exclusion reason(s): All women in the study are known to have CAD; Data for women not reported as a subgroup; No outcomes of interest. [pmid: 15276122].
Atar S, Nagai T, Cercek B, et al. Pacing stress echocardiography: an alternative to pharmacologic stress testing. J Am Coll Cardiol. 2000;36(6):1935-41. Full-text exclusion reason(s): All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 11092667].
Atchley AE, Iskandrian AE, Bensimhon D, et al. Relationship of technetium-99m tetrofosmin-gated rest single-photon emission computed tomography myocardial perfusion imaging to death and hospitalization in heart failure patients: Results from the nuclear ancillary study of the HF-ACTION trial. Am Heart J. 2011;161(6):1038-1045. Full-text exclusion reason(s): No women with symptomatic chest pain, or results are not reported separately for symptomatic subgroup; All women in the study are known to have CAD; Study does not compare one NIT to another or to diagnostic cardiac catheterization; Data for women not reported as a subgroup. [pmid: 21641348].
Atsma DE, Bavelaar-Croon CD, Germano G, et al. Good correlation between gated single photon emission computed myocardial tomography and contrast ventriculography in the assessment of global and regional left ventricular function. Int J Card Imaging. 2000;16(6):447-53. Full-text exclusion reason(s): All women in the study are known to have CAD; Data for women not reported as a subgroup; No outcomes of interest. [pmid: 11482710].
Attar MN, Wong K, Groves DG, et al. Clinical implications of QRS duration and QT peak prolongation in patients with suspected coronary disease referred for elective cardiac catheterization. Ann Noninvasive Electrocardiol. 2008;13(2):106-12. Full-text exclusion reason(s): No women with symptomatic chest pain, or results are not reported separately for symptomatic subgroup; All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 18426435].
Auseon AJ, Advani SS, Bush CA, et al. Impact of 64-slice multidetector computed tomography on other diagnostic studies for coronary artery disease. Am J Med. 2009;122(4):387-91. Full-text exclusion reason(s): All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 19332234].
Auseon AJ, Tran T, Garcia AM, et al. Aortic pathophysiology by cardiovascular magnetic resonance in patients with clinical suspicion of coronary artery disease. J Cardiovasc Magn Reson. 2007;9(1):43-8. Full-text exclusion reason(s): No women with symptomatic chest pain, or results are not reported separately for symptomatic subgroup; All women in the study are known to have CAD; Data for women not reported as a subgroup; No outcomes of interest. [pmid: 17178679].
Aviram G, Finkelstein A, Herz I, et al. Clinical value of 16-slice multi-detector CT compared to invasive coronary angiography. Int J Cardiovasc Intervent. 2005;7(1):21-8. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 16019611].
Aydinalp A, Bal U, Atar I, et al. Value of stress myocardial perfusion scanning in diagnosis of severe coronary artery disease in liver transplantation candidates. Transplant Proc. 2009;41(9):3757-60. Full-text exclusion reason(s): No women with symptomatic chest pain, or results are not reported separately for symptomatic subgroup; Data for women not reported as a subgroup. [pmid: 19917381].
Bacci S, Villella M, Villella A, et al. Screening for silent myocardial ischaemia in type 2 diabetic patients with additional atherogenic risk factors: applicability and accuracy of the exercise stress test. Eur J Endocrinol. 2002;147(5):649-54. Full-text exclusion reason(s): No women with symptomatic chest pain, or results are not reported separately for symptomatic subgroup. [pmid: 12444897].
Bachar GN, Atar E, Fuchs S, et al. Prevalence and clinical predictors of atherosclerotic coronary artery disease in asymptomatic patients undergoing coronary multidetector computed tomography. Coron Artery Dis. 2007;18(5):353-60. Full-text exclusion reason(s): No women with symptomatic chest pain, or results are not reported separately for symptomatic subgroup; All women in the study are known to have CAD; Study does not compare one NIT to another or to diagnostic cardiac catheterization; Data for women not reported as a subgroup. [pmid: 17627184].
Badano LP, Muraru D, Rigo F, et al. High volume-rate three-dimensional stress echocardiography to assess inducible myocardial ischemia: a feasibility study. J Am Soc Echocardiogr. 2010;23(6):628-35. Full-text exclusion reason(s): No women with symptomatic chest pain, or results are not reported separately for symptomatic subgroup; All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 20434877].
Badruddin SM, Ahmad A, Mickelson J, et al. Supine bicycle versus post-treadmill exercise echocardiography in the detection of myocardial ischemia: a randomized single-blind crossover trial. J Am Coll Cardiol. 1999;33(6):1485-90. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 10334412].
Baghdasarian SB, Heller GV. The role of myocardial perfusion imaging in the diagnosis of patients with coronary artery disease: developments over the past year. Curr Opin Cardiol. 2005;20(5):369-74. Full-text exclusion reason(s): Not original peer-reviewed data or a secondary analysis of RCT, prospective or retrospective observational study, or registry. [pmid: 16093754].
Baik HK, Budoff MJ, Lane KL, et al. Accurate measures of left ventricular ejection fraction using electron beam tomography: a comparison with radionuclide angiography, and cine angiography. Int J Card Imaging. 2000;16(5):391-8. Full-text exclusion reason(s): Data for women not reported as a subgroup; No outcomes of interest. [pmid: 11215924].
Bailon R, Mateo J, Olmos S, et al. Coronary artery disease diagnosis based on exercise electrocardiogram indexes from repolarisation, depolarisation and heart rate variability. Med Biol Eng Comput. 2003;41(5):561-71. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 14572007].
Balaravi B, Miller TD, Hodge DO, et al. The value of stress single photon emission computed tomography in patients without known coronary artery disease presenting with dyspnea. Am Heart J. 2006;152(3):551-7. Full-text exclusion reason(s): Data for women not reported as a subgroup; No outcomes of interest. [pmid: 16923430].
Balnave K, Scott ME, Morton P, et al. Reliable prediction of coronary disease using treadmill exercise testing. Br Med J. 1978;1(6118):958-9. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 638548].
Bamberg F, Becker A, Schwarz F, et al. Detection of hemodynamically significant coronary artery stenosis: incremental diagnostic value of dynamic CT-based myocardial perfusion imaging. Radiology. 2011;260(3):689-98. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 21846761].
Bamberg F, Sommer WH, Hoffmann V, et al. Meta-analysis and systematic review of the long-term predictive value of assessment of coronary atherosclerosis by contrast-enhanced coronary computed tomography angiography. J Am Coll Cardiol. 2011;57(24):2426-36. Full-text exclusion reason(s): Not original peer-reviewed data or a secondary analysis of RCT, prospective or retrospective observational study, or registry. [pmid: 21658564].
Bamberg F, Truong QA, Blankstein R, et al. Usefulness of age and gender in the early triage of patients with acute chest pain having cardiac computed tomographic angiography. Am J Cardiol. 2009;104(9):1165-70. Full-text exclusion reason(s): Study does not compare one NIT to another or to diagnostic cardiac catheterization. [pmid: 19840556].
Bampi AB, Rochitte CE, Favarato D, et al. Comparison of non-invasive methods for the detection of coronary atherosclerosis. Clinics (Sao Paulo). 2009;64(7):675-82. Full-text exclusion reason(s): No data for NITs of interest (ECG, ECHO, SPECT, PET, CMR, CTA). [pmid: 19606245].
Banerjee SK, Haque KM, Sharma AK, et al. Role of exercise tolerance test (ETT) and gated single photon emission computed tomography-myocardial perfusion imaging (SPECT-MPI) in predicting severity of ischemia in patients with chest pain. Bangladesh Med Res Counc Bull. 2005;31(1):27-35. Full-text exclusion reason(s): All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 16689138].
Bangalore S, Gopinath D, Yao SS, et al. Risk stratification using stress echocardiography: incremental prognostic value over historic, clinical, and stress electrocardiographic variables across a wide spectrum of bayesian pretest probabilities for coronary artery disease. J Am Soc Echocardiogr. 2007;20(3):244-52. Full-text exclusion reason(s): Study does not compare one NIT to another or to diagnostic cardiac catheterization. [pmid: 17336749].
Banzo I, Pena FJ, Allende RH, et al. Prospective clinical comparison of non-corrected and attenuation- and scatter-corrected myocardial perfusion SPECT in patients with suspicion of coronary artery disease. Nucl Med Commun. 2003;24(9):995-1002. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 12960599].
Barbirato GB, Azevedo JC, Felix RC, et al. Use of resting myocardial scintigraphy during chest pain to exclude diagnosis of acute myocardial infarction. Arq Bras Cardiol. 2009;92(4):269-74. Full-text exclusion reason(s): All women in the study are known to have CAD; Study does not compare one NIT to another or to diagnostic cardiac catheterization; Data for women not reported as a subgroup. [pmid: 19565134].
Barmeyer AA, Stork A, Muellerleile K, et al. Contrast-enhanced cardiac MR imaging in the detection of reduced coronary flow velocity reserve. Radiology. 2007;243(2):377-85. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 17456867].
Bart BA, Cen YY, Hendel RC, et al. Comparison of dobutamine stress echocardiography, dobutamine SPECT, and adenosine SPECT myocardial perfusion imaging in patients with end-stage renal disease. J Nucl Cardiol. 2009;16(4):507-15. Full-text exclusion reason(s): No women with symptomatic chest pain, or results are not reported separately for symptomatic subgroup; Data for women not reported as a subgroup. [pmid: 19308650].
Bart BA, Erlien DA, Herzog CA, et al. Marked differences between patients referred for stress echocardiography and myocardial perfusion imaging studies. Am Heart J. 2005;149(5):888-93. Full-text exclusion reason(s): No women with symptomatic chest pain, or results are not reported separately for symptomatic subgroup; Data for women not reported as a subgroup; No outcomes of interest. [pmid: 15894973].
Bartel T, Yang Y, Muller S, et al. Noninvasive assessment of microvascular function in arterial hypertension by transthoracic Doppler harmonic echocardiography. J Am Coll Cardiol. 2002;39(12):2012-8. Full-text exclusion reason(s): All women in the study are known to have CAD; Study does not compare one NIT to another or to diagnostic cardiac catheterization; Data for women not reported as a subgroup. [pmid: 12084602].
Basic D, Siu SC, Skyba DM, et al. Prognostic value of myocardial perfusion contrast echocardiography in patients with suggested or known ischemic heart disease. J Am Soc Echocardiogr. 2006;19(10):1203-10. Full-text exclusion reason(s): All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 17000358].
Baskot B, Obradovic S, Rafajlovski S, et al. Adenosine stress protocols for nuclear cardiology imaging. Prilozi. 2008;29(1):281-9. Full-text exclusion reason(s): No women with symptomatic chest pain, or results are not reported separately for symptomatic subgroup; All women in the study are known to have CAD; Study does not compare one NIT to another or to diagnostic cardiac catheterization; Data for women not reported as a subgroup; No outcomes of interest. [pmid: 18709016].
Bastarrika G, Ramos-Duran L, Rosenblum MA, et al. Adenosine-stress dynamic myocardial CT perfusion imaging: initial clinical experience. Invest Radiol. 2010;45(6):306-13. Full-text exclusion reason(s): No women with symptomatic chest pain, or results are not reported separately for symptomatic subgroup; All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 20421800].
Bateman TM, Heller GV, McGhie AI, et al. Multicenter investigation comparing a highly efficient half-time stress-only attenuation correction approach against standard rest-stress Tc-99m SPECT imaging. J Nucl Cardiol. 2009;16(5):726-735. Full-text exclusion reason(s): No women with symptomatic chest pain, or results are not reported separately for symptomatic subgroup; All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 19548048].
Bateman TM, Heller GV, McGhie AI, et al. Diagnostic accuracy of rest/stress ECG-gated Rb-82 myocardial perfusion PET: comparison with ECG-gated Tc-99m sestamibi SPECT. J Nucl Cardiol. 2006;13(1):24-33. Full-text exclusion reason(s): No women with symptomatic chest pain, or results are not reported separately for symptomatic subgroup; Data for women not reported as a subgroup. [pmid: 16464714].
Batlle E, Vilacosta I, San Roman JA, et al. Elective noninvasive test in the diagnosis of coronary disease in the aged. Rev Esp Cardiol. 1998;51(1):35-42. Full-text exclusion reason(s): Non-English. [pmid: 9580166].
Bauer RW, Thilo C, Chiaramida SA, et al. Noncalcified atherosclerotic plaque burden at coronary CT angiography: a better predictor of ischemia at stress myocardial perfusion imaging than calcium score and stenosis severity. AJR Am J Roentgenol. 2009;193(2):410-8. Full-text exclusion reason(s): All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 19620437].
Bauernfeind T, Preda I, Szakolczai K, et al. Diagnostic value of the left atrial electrical potentials detected by body surface potential mapping in the prediction of coronary artery disease. Int J Cardiol. 2011;150(3):315-318. Full-text exclusion reason(s): No data for NITs of interest (ECG, ECHO, SPECT, PET, CMR, CTA). [pmid: 20537737].
Baumgart D, Schmermund A, Goerge G, et al. Comparison of electron beam computed tomography with intracoronary ultrasound and coronary angiography for detection of coronary atherosclerosis. J Am Coll Cardiol. 1997;30(1):57-64. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 9207621].
Baumuller S, Leschka S, Desbiolles L, et al. Dual-source versus 64-section CT coronary angiography at lower heart rates: comparison of accuracy and radiation dose. Radiology. 2009;253(1):56-64. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 19587311].
Bayrak F, Guneysu T, Gemici G, et al. Diagnostic performance of 64-slice computed tomography coronary angiography to detect significant coronary artery stenosis. Acta Cardiol. 2008;63(1):11-7. Full-text exclusion reason(s): All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 18372575].
Beanlands RS, Nichol G, Huszti E, et al. F-18-fluorodeoxyglucose positron emission tomography imaging-assisted management of patients with severe left ventricular dysfunction and suspected coronary disease: a randomized, controlled trial (PARR-2). J Am Coll Cardiol. 2007;50(20):2002-12. Full-text exclusion reason(s): All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 17996568].
Beck T, Burgstahler C, Kuettner A, et al. Clinical use of multislice spiral computed tomography in 210 highly preselected patients: experience with 4 and 16 slice technology. Heart. 2005;91(11):1423-7. Full-text exclusion reason(s): No women with symptomatic chest pain, or results are not reported separately for symptomatic subgroup; All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 15761053].
Beck T, Kuettner A, Burgstahler C, et al. Noninvasive detection of coronary stenosis using 16-slice detector computed tomography in carefully selected patients. Med Klin (Munich). 2004;99(11):645-50. Full-text exclusion reason(s): Non-English. [pmid: 15583874].
Becker A, Leber A, Becker C, et al. Predictive value of coronary calcifications for future cardiac events in asymptomatic individuals. Am Heart J. 2008;155(1):154-60. Full-text exclusion reason(s): No women with symptomatic chest pain, or results are not reported separately for symptomatic subgroup; Study does not compare one NIT to another or to diagnostic cardiac catheterization. [pmid: 18082507].
Becker A, Leber A, White CW, et al. Multislice computed tomography for determination of coronary artery disease in a symptomatic patient population. Int J Cardiovasc Imaging. 2007;23(3):361-7. Full-text exclusion reason(s): No outcomes of interest. [pmid: 17160425].
Becker A, Leber AW, Becker C, et al. Predictive value of coronary calcifications for future cardiac events in asymptomatic patients with diabetes mellitus: a prospective study in 716 patients over 8 years. BMC Cardiovasc Disord. 2008;8:27. Full-text exclusion reason(s): No women with symptomatic chest pain, or results are not reported separately for symptomatic subgroup; Study does not compare one NIT to another or to diagnostic cardiac catheterization. [pmid: 18847481].
Becker CR, Knez A, Leber A, et al. Detection of coronary artery stenoses with multislice helical CT angiography. J Comput Assist Tomogr. 2002;26(5):750-5. Full-text exclusion reason(s): No women with symptomatic chest pain, or results are not reported separately for symptomatic subgroup; Data for women not reported as a subgroup; No outcomes of interest. [pmid: 12439310].
Bedetti G, Gargani L, Sicari R, et al. Comparison of prognostic value of echographic [corrected] risk score with the Thrombolysis in Myocardial Infarction (TIMI) and Global Registry in Acute Coronary Events (GRACE) risk scores in acute coronary syndrome. Am J Cardiol. 2010;106(12):1709-16. Full-text exclusion reason(s): No data for NITs of interest (ECG, ECHO, SPECT, PET, CMR, CTA). [pmid: 21126614].
Bedetti G, Pasanisi EM, Pizzi C, et al. Economic analysis including long-term risks and costs of alternative diagnostic strategies to evaluate patients with chest pain. Cardiovasc Ultrasound. 2008;6:21. Full-text exclusion reason(s): Not original peer-reviewed data or a secondary analysis of RCT, prospective or retrospective observational study, or registry; Data for women not reported as a subgroup; No outcomes of interest. [pmid: 18510723].
Bedetti G, Pasanisi EM, Tintori G, et al. Stress echo in chest pain unit: the SPEED trial. Int J Cardiol. 2005;102(3):461-7. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 16004892].
Beer SG, Heo J, Kong B, et al. Use of oral dipyridamole SPECT thallium-201 imaging in detection of coronary artery disease. Am Heart J. 1989;118(5 Pt 1):1022-7. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 2816686].
Beigel R, Oieru D, Goitein O, et al. Usefulness of routine use of multidetector coronary computed tomography in the “fast track” evaluation of patients with acute chest pain. Am J Cardiol. 2009;103(11):1481-6. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 19463503].
Beinart R, Matetzky S, Shechter M, et al. Stress-induced ST-segment elevation in patients without prior Q-wave myocardial infarction. J Electrocardiol. 2008;41(4):312-7. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 18490025].
Beleslin BD, Ostojic M, Djordjevic-Dikic A, et al. Integrated evaluation of relation between coronary lesion features and stress echocardiography results: the importance of coronary lesion morphology. J Am Coll Cardiol. 1999;33(3):717-26. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 10080473].
Beleslin BD, Ostojic M, Stepanovic J, et al. Stress echocardiography in the detection of myocardial ischemia. Head-to-head comparison of exercise, dobutamine, and dipyridamole tests. Circulation. 1994;90(3):1168-76. Full-text exclusion reason(s): No women with symptomatic chest pain, or results are not reported separately for symptomatic subgroup; All women in the study are known to have CAD; Study does not compare one NIT to another or to diagnostic cardiac catheterization; Data for women not reported as a subgroup. [pmid: 7916274].
Belge B, Coche E, Pasquet A, et al. Accurate estimation of global and regional cardiac function by retrospectively gated multidetector row computed tomography: comparison with cine magnetic resonance imaging. Eur Radiol. 2006;16(7):1424-33. Full-text exclusion reason(s): All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 16518654].
Bell GW, Edwardes M, Dunning AM, et al. Periprocedural safety of 64-detector row coronary computed tomographic angiography: results from the prospective multicenter ACCURACY trial. J Cardiovasc Comput Tomogr. 2010;4(6):375-80. Full-text exclusion reason(s): Study does not compare one NIT to another or to diagnostic cardiac catheterization; Data for women not reported as a subgroup. [pmid: 21030334].
Bellasi A, Ferramosca E, Muntner P, et al. Correlation of simple imaging tests and coronary artery calcium measured by computed tomography in hemodialysis patients. Kidney Int. 2006;70(9):1623-8. Full-text exclusion reason(s): No women with symptomatic chest pain, or results are not reported separately for symptomatic subgroup; All women in the study are known to have CAD; Study does not compare one NIT to another or to diagnostic cardiac catheterization; Data for women not reported as a subgroup; No outcomes of interest. [pmid: 16955104].
Beller GA. Perfusion imaging. J Am Coll Cardiol. 2000;35(5 SUPPL B):29B-31B. Full-text exclusion reason(s): Not a clinical study report. [pmid: 10636255].
Ben-Gal T, Zafrir N. The utility and potential cost-effectiveness of stress myocardial perfusion thallium SPECT imaging in hospitalized patients with chest pain and normal or non-diagnostic electrocardiogram. Isr Med Assoc J. 2001;3(10):725-30. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 11692545].
Ben-Gal T, Zafrir N. Utility of stress myocardial perfusion imaging in hospitalized patients with chest pain and normal or nondiagnostic electrocardiograms. Cardiovascular Reviews and Reports. 2001;22(10):600-606. Full-text exclusion reason(s): Data for women not reported as a subgroup.
Berger BC, Watson DD, Taylor GJ, et al. Quantitative thallium-201 exercise scintigraphy for detection of coronary artery disease. J Nucl Med. 1981;22(7):585-93. Full-text exclusion reason(s): All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 7252562].
Bergeron S, Ommen SR, Bailey KR, et al. Exercise echocardiographic findings and outcome of patients referred for evaluation of dyspnea. J Am Coll Cardiol. 2004;43(12):2242-6. Full-text exclusion reason(s): All women in the study are known to have CAD; Study does not compare one NIT to another or to diagnostic cardiac catheterization; Data for women not reported as a subgroup. [pmid: 15193687].
Berman D, Hachamovitch R, Lewin H, et al. Risk stratification in coronary artery disease: Implications for stabilization and prevention. Am J Cardiol. 1997;79(12 B):10-16. Full-text exclusion reason(s): Not original peer-reviewed data or a secondary analysis of RCT, prospective or retrospective observational study, or registry. [pmid: 9223352].
Berman DS, Hachamovitch R, Shaw LJ, et al. Roles of nuclear cardiology, cardiac computed tomography, and cardiac magnetic resonance: Noninvasive risk stratification and a conceptual framework for the selection of noninvasive imaging tests in patients with known or suspected coronary artery disease. J Nucl Med. 2006;47(7):1107-18. Full-text exclusion reason(s): Not original peer-reviewed data or a secondary analysis of RCT, prospective or retrospective observational study, or registry. [pmid: 16818945].
Berman DS, Kang X, Gransar H, et al. Quantitative assessment of myocardial perfusion abnormality on SPECT myocardial perfusion imaging is more reproducible than expert visual analysis. J Nucl Cardiol. 2009;16(1):45-53. Full-text exclusion reason(s): All women in the study are known to have CAD; Study does not compare one NIT to another or to diagnostic cardiac catheterization; Data for women not reported as a subgroup. [pmid: 19152128].
Berman DS, Kang X, Hayes SW, et al. Adenosine myocardial perfusion single-photon emission computed tomography in women compared with men. Impact of diabetes mellitus on incremental prognostic value and effect on patient management. J Am Coll Cardiol. 2003;41(7):1125-33. Full-text exclusion reason(s): No women with symptomatic chest pain, or results are not reported separately for symptomatic subgroup; All women in the study are known to have CAD; Study does not compare one NIT to another or to diagnostic cardiac catheterization. [pmid: 12679212].
Berman DS, Kang X, Schisterman EF, et al. Serial changes on quantitative myocardial perfusion SPECT in patients undergoing revascularization or conservative therapy. J Nucl Cardiol. 2001;8(4):428-37. Full-text exclusion reason(s): No women with symptomatic chest pain, or results are not reported separately for symptomatic subgroup; All women in the study are known to have CAD; Data for women not reported as a subgroup; No outcomes of interest. [pmid: 11481564].
Berman DS, Kiat H, Friedman JD, et al. Separate acquisition rest thallium-201/stress technetium-99m sestamibi dual-isotope myocardial perfusion single-photon emission computed tomography: a clinical validation study. J Am Coll Cardiol. 1993;22(5):1455-64. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 8227805].
Berman DS, Wong ND, Gransar H, et al. Relationship between stress-induced myocardial ischemia and atherosclerosis measured by coronary calcium tomography. J Am Coll Cardiol. 2004;44(4):923-30. Full-text exclusion reason(s): No women with symptomatic chest pain, or results are not reported separately for symptomatic subgroup; Data for women not reported as a subgroup. [pmid: 15312881].
Bernhardt P, Engels T, Levenson B, et al. Prediction of necessity for coronary artery revascularization by adenosine contrast-enhanced magnetic resonance imaging. Int J Cardiol. 2006;112(2):184-90. Full-text exclusion reason(s): No women with symptomatic chest pain, or results are not reported separately for symptomatic subgroup; All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 16271778].
Bernhardt P, Levenson B, Albrecht A, et al. Detection of cardiac small vessel disease by adenosine-stress magnetic resonance. Int J Cardiol. 2007;121(3):261-6. Full-text exclusion reason(s): No women with symptomatic chest pain, or results are not reported separately for symptomatic subgroup; Data for women not reported as a subgroup. [pmid: 17196688].
Bernhardt P, Manzke R, Bornstedt A, et al. Blood oxygen level-dependent magnetic resonance imaging using T2-prepared steady-state free-precession imaging in comparison to contrast-enhanced myocardial perfusion imaging. Int J Cardiol. 2011;147(3):416-419. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 19880203].
Bernheim AM, Kittipovanonth M, Scott CG, et al. Relation of dyspnea in patients unable to perform exercise stress testing to outcome and myocardial ischemia. Am J Cardiol. 2009;104(2):265-9. Full-text exclusion reason(s): All women in the study are known to have CAD; Study does not compare one NIT to another or to diagnostic cardiac catheterization; Data for women not reported as a subgroup. [pmid: 19576358].
Bernheim AM, Kittipovanonth M, Takahashi PY, et al. Does the prognostic value of dobutamine stress echocardiography differ among different age groups?. Am Heart J. 2011;161(4):740-5. Full-text exclusion reason(s): All women in the study are known to have CAD; Study does not compare one NIT to another or to diagnostic cardiac catheterization; Data for women not reported as a subgroup. [pmid: 21473974].
Beslic N, Kucukalic-Selimovic E. Comparison of the diagnostic capabilities of noninvasive methods for early detection of coronary artery disease. Med Arh. 2011;65(2):96-8. Full-text exclusion reason(s): No women with symptomatic chest pain, or results are not reported separately for symptomatic subgroup; Data for women not reported as a subgroup. [pmid: 21585183].
Bestetti A, Di Leo C, Alessi A, et al. Post-stress end-systolic left ventricular dilation: a marker of endocardial post-ischemic stunning. Nucl Med Commun. 2001;22(6):685-93. Full-text exclusion reason(s): All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 11403181].
Bettencourt N, Rocha J, Carvalho M, et al. Multislice computed tomography in the exclusion of coronary artery disease in patients with presurgical valve disease. Circ Cardiovasc Imaging. 2009;2(4):306-13. Full-text exclusion reason(s): No women with symptomatic chest pain, or results are not reported separately for symptomatic subgroup; Data for women not reported as a subgroup. [pmid: 19808611].
Bhat A, Desai A, Amsterdam EA. Usefulness of high functional capacity in patients with exercise-induced ST-depression to predict a negative result on exercise echocardiography and low prognostic risk. Am J Cardiol. 2008;101(11):1541-3. Full-text exclusion reason(s): Study does not compare one NIT to another or to diagnostic cardiac catheterization; Data for women not reported as a subgroup. [pmid: 18489930].
Bholasingh R, Cornel JH, Kamp O, et al. Prognostic value of predischarge dobutamine stress echocardiography in chest pain patients with a negative cardiac troponin T. J Am Coll Cardiol. 2003;41(4):596-602. Full-text exclusion reason(s): All women in the study are known to have CAD; Study does not compare one NIT to another or to diagnostic cardiac catheterization; Data for women not reported as a subgroup. [pmid: 12598071].
Biagini E, Elhendy A, Bax JJ, et al. Seven-year follow-up after dobutamine stress echocardiography: impact of gender on prognosis. J Am Coll Cardiol. 2005;45(1):93-7. Full-text exclusion reason(s): No women with symptomatic chest pain, or results are not reported separately for symptomatic subgroup; All women in the study are known to have CAD; Study does not compare one NIT to another or to diagnostic cardiac catheterization. [pmid: 15629381].
Bielak LF, Rumberger JA, Sheedy PF 2nd, et al. Probabilistic model for prediction of angiographically defined obstructive coronary artery disease using electron beam computed tomography calcium score strata. Circulation. 2000;102(4):380-5. Full-text exclusion reason(s): No data for NITs of interest (ECG, ECHO, SPECT, PET, CMR, CTA). [pmid: 10908208].
Bigi R, Bax JJ, van Domburg RT, et al. Simultaneous echocardiography and myocardial perfusion single photon emission computed tomography associated with dobutamine stress to predict long-term cardiac mortality in normotensive and hypertensive patients. J Hypertens. 2005;23(7):1409-15. Full-text exclusion reason(s): All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 15942465].
Bigi R, Desideri A, Cortigiani L, et al. Stress echocardiography for risk stratification of diabetic patients with known or suspected coronary artery disease. Diabetes Care. 2001;24(9):1596-601. Full-text exclusion reason(s): Study does not compare one NIT to another or to diagnostic cardiac catheterization; Data for women not reported as a subgroup. [pmid: 11522705].
Bigi R, Occhi G, Fiorentini C, et al. Dobutamine stress echocardiography for the identification of multivessel coronary artery disease after uncomplicated myocardial infarction: the importance of test end-point. Int J Cardiol. 1995;50(1):51-60. Full-text exclusion reason(s): All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 7558464].
Bingham SE, Hachamovitch R. Incremental prognostic significance of combined cardiac magnetic resonance imaging, adenosine stress perfusion, delayed enhancement, and left ventricular function over preimaging information for the prediction of adverse events. Circulation. 2011;123(14):1509-18. Full-text exclusion reason(s): All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 21444886].
Bischoff B, Hein F, Meyer T, et al. Comparison of sequential and helical scanning for radiation dose and image quality: results of the Prospective Multicenter Study on Radiation Dose Estimates of Cardiac CT Angiography (PROTECTION) I Study. AJR Am J Roentgenol. 2010:1495-9. Full-text exclusion reason(s): Study does not compare one NIT to another or to diagnostic cardiac catheterization; Data for women not reported as a subgroup. [pmid: 20489088].
Bjornstad K, Aakhus S, Hatle L. Digital high frame rate stress echocardiography for detection of coronary artery stenosis by high dose dipyridamole stress testing. Int J Card Imaging. 1995;11(3):163-70. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 7499905].
Bjornstad K, Aakhus S, Torp HG. How does computer-assisted digital wall motion analysis influence observer agreement and diagnostic accuracy during stress echocardiography?. Int J Card Imaging. 1997;13(2):105-14. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 9110190].
Blankstein R, Devore AD. Selecting a noninvasive imaging study after an inconclusive exercise test. Circulation. 2010;122(15):1514-1518. Full-text exclusion reason(s): Not a clinical study report. [pmid: 20937987].
Blankstein R, Di Carli MF. Integration of coronary anatomy and myocardial perfusion imaging. Nature Reviews Cardiology. 2010;7(4):226-236. Full-text exclusion reason(s): Not a clinical study report.
Blankstein R, Okada DR, Rocha-Filho JA, et al. Cardiac myocardial perfusion imaging using dual source computed tomography. Int J Cardiovasc Imaging. 2009;25(SUPPL 2):209-216. Full-text exclusion reason(s): Not a clinical study report. [pmid: 19051056].
Blankstein R, Shturman LD, Rogers IS, et al. Adenosine-induced stress myocardial perfusion imaging using dual-source cardiac computed tomography. J Am Coll Cardiol. 2009;54(12):1072-84. Full-text exclusion reason(s): All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 19744616].
Blinder G, Benhorin J, Koukoui D, et al. The value of electrocardiography-gated multi-slice computed tomography in the evaluation of patients with chest pain. Isr Med Assoc J. 2005;7(7):419-23. Full-text exclusion reason(s): All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 16011054].
Blomkalns AL, Chen AY, Hochman JS, et al. Gender disparities in the diagnosis and treatment of non-ST-segment elevation acute coronary syndromes: large-scale observations from the CRUSADE (Can Rapid Risk Stratification of Unstable Angina Patients Suppress Adverse Outcomes With Early Implementation of the American College of Cardiology/American Heart Association Guidelines) National Quality Improvement Initiative. J Am Coll Cardiol. 2005;45(6):832-7. Full-text exclusion reason(s): No data for NITs of interest (ECG, ECHO, SPECT, PET, CMR, CTA). [pmid: 15766815].
Blumenthal RS, Becker DM, Yanek LR, et al. Detecting occult coronary disease in a high-risk asymptomatic population. Circulation. 2003;107(5):702-7. Full-text exclusion reason(s): No women with symptomatic chest pain, or results are not reported separately for symptomatic subgroup; Data for women not reported as a subgroup. [pmid: 12578872].
Blumenthal RS, Becker DM, Yanek LR, et al. Comparison of coronary calcium and stress myocardial perfusion imaging in apparently healthy siblings of individuals with premature coronary artery disease. Am J Cardiol. 2006;97(3):328-33. Full-text exclusion reason(s): No women with symptomatic chest pain, or results are not reported separately for symptomatic subgroup; Study does not compare one NIT to another or to diagnostic cardiac catheterization; Data for women not reported as a subgroup. [pmid: 16442390].
Bodenheimer MM, Banka VS, Fooshee CM, et al. Comparative sensitivity of the exercise electrocardiogram, thallium imaging and stress radionuclide angiography to detect the presence and severity of coronary heart disease. Circulation. 1979;60(6):1270-8. Full-text exclusion reason(s): All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 498452].
Bodi V, Sanchis J, Lopez-Lereu MP, et al. Prognostic value of dipyridamole stress cardiovascular magnetic resonance imaging in patients with known or suspected coronary artery disease. J Am Coll Cardiol. 2007;50(12):1174-9. Full-text exclusion reason(s): All women in the study are known to have CAD; Study does not compare one NIT to another or to diagnostic cardiac catheterization; Data for women not reported as a subgroup. [pmid: 17868810].
Bodi V, Sanchis J, Lopez-Lereu MP, et al. Prognostic and therapeutic implications of dipyridamole stress cardiovascular magnetic resonance on the basis of the ischaemic cascade. Heart. 2009;95(1):49-55. Full-text exclusion reason(s): All women in the study are known to have CAD; Study does not compare one NIT to another or to diagnostic cardiac catheterization; Data for women not reported as a subgroup. [pmid: 18381373].
Bogaert J, Kuzo R, Dymarkowski S, et al. Coronary artery imaging with real-time navigator three-dimensional turbo-field-echo MR coronary angiography: initial experience. Radiology. 2003;226(3):707-16. Full-text exclusion reason(s): All women in the study are known to have CAD; No outcomes of interest. [pmid: 12601209].
Bokhari S, Blood DK, Bergmann SR. Failure of right precordial electrocardiography during stress testing to identify coronary artery disease. J Nucl Cardiol. 2001;8(3):325-31. Full-text exclusion reason(s): No women with symptomatic chest pain, or results are not reported separately for symptomatic subgroup; All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 11391302].
Bonmassari R, Muraglia S, Centonze M, et al. Noninvasive detection of coronary artery stenosis with 16-slice spiral computed tomography in a population at low to moderate risk for coronary artery disease. J Cardiovasc Med (Hagerstown). 2006;7(11):817-25. Full-text exclusion reason(s): No women with symptomatic chest pain, or results are not reported separately for symptomatic subgroup; Data for women not reported as a subgroup. [pmid: 17060808].
Boogers MJ, Schuijf JD, Kitslaar PH, et al. Automated quantification of stenosis severity on 64-slice CT: A comparison with quantitative coronary angiography. JACC: Cardiovascular Imaging. 2010;3(7):699-709. Full-text exclusion reason(s): No women with symptomatic chest pain, or results are not reported separately for symptomatic subgroup; All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 20633847].
Bordeleau E, Lamonde A, Prenovault J, et al. Accuracy and rate of coronary artery segment visualization with CT angiography for the non-invasive detection of coronary artery stenoses. Int J Cardiovasc Imaging. 2007;23(6):771-80. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 17216125].
Borer JS, Brensike JF, Redwood DR, et al. Limitations of the electrocardiographic response to exercise in predicting coronary-artery disease. N Engl J Med. 1975;293(8):367-71. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 168493].
Borges-Neto S, Shaw LK, Tuttle RH, et al. Incremental prognostic power of single-photon emission computed tomographic myocardial perfusion imaging in patients with known or suspected coronary artery disease. Am J Cardiol. 2005;95(2):182-8. Full-text exclusion reason(s): No women with symptomatic chest pain, or results are not reported separately for symptomatic subgroup; All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 15642549].
Borges-Neto S, Tuttle RH, Shaw LK, et al. Outcome prediction in patients at high risk for coronary artery disease: comparison between 99mTc tetrofosmin and 99mTc sestamibi. Radiology. 2004;232(1):58-65. Full-text exclusion reason(s): No women with symptomatic chest pain, or results are not reported separately for symptomatic subgroup; All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 15220493].
Boshchenko AA, Vrublevsky AV, Karpov RS. Transthoracic echocardiography in the detection of chronic total coronary artery occlusion. Eur J Echocardiogr. 2009;10(1):62-8. Full-text exclusion reason(s): No women with symptomatic chest pain, or results are not reported separately for symptomatic subgroup; All women in the study are known to have CAD; Data for women not reported as a subgroup; No outcomes of interest. [pmid: 18490275].
Boudik F, Anger Z, Aschermann M, et al. Dipyridamole body surface potential mapping: noninvasive differentiation of syndrome X from coronary artery disease. J Electrocardiol. 2002;35(3):181-91. Full-text exclusion reason(s): No women with symptomatic chest pain, or results are not reported separately for symptomatic subgroup; All women in the study are known to have CAD; Data for women not reported as a subgroup; No outcomes of interest. [pmid: 12122608].
Boudoulas H, Weissler AM, Sohn YH, et al. Detection of the High Mortality Risk by Combined Noninvasive Measures of Mechanical and Electrical Dysfunction in Coronary Artery Disease. Joint Meeting of the American Federation for Clinical Research, the Association of American Physicians and the American Society for Clinical Investigation. Washington, DC. 7–10 May 82. (World Meeting Number 822 0218). Full-text exclusion reason(s): Full-text unobtainable.
Bourque JM, Charlton GT, Holland BH, et al. Prognosis in patients achieving >/=10 METS on exercise stress testing: was SPECT imaging useful?. J Nucl Cardiol. 2011;18(2):230-7. Full-text exclusion reason(s): All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 21132417].
Bourque JM, Holland BH, Watson DD, et al. Achieving an exercise workload of > or = 10 metabolic equivalents predicts a very low risk of inducible ischemia: does myocardial perfusion imaging have a role?. J Am Coll Cardiol. 2009;54(6):538-45. Full-text exclusion reason(s): No women with symptomatic chest pain, or results are not reported separately for symptomatic subgroup; All women in the study are known to have CAD; Study does not compare one NIT to another or to diagnostic cardiac catheterization; Data for women not reported as a subgroup; No outcomes of interest. [pmid: 19643316].
Boussel L, Gamondes D, Staat P, et al. Acute chest pain with normal coronary angiogram: role of contrast-enhanced multidetector computed tomography in the differential diagnosis between myocarditis and myocardial infarction. J Comput Assist Tomogr. 2008;32(2):228-32. Full-text exclusion reason(s): All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 18379307].
Bouvier E, Logeart D, Sablayrolles JL, et al. Diagnosis of aortic valvular stenosis by multislice cardiac computed tomography. Euro Heart J. 2006;(24):3033-8. Full-text exclusion reason(s): No women with symptomatic chest pain, or results are not reported separately for symptomatic subgroup; All women in the study are known to have CAD; Study does not compare one NIT to another or to diagnostic cardiac catheterization; Data for women not reported as a subgroup; No outcomes of interest.
Bouzas-Mosquera A, Peteiro J, Alvarez-Garcia N, et al. Prediction of mortality and major cardiac events by exercise echocardiography in patients with normal exercise electrocardiographic testing. J Am Coll Cardiol. 2009;53(21):1981-90. Full-text exclusion reason(s): No women with symptomatic chest pain, or results are not reported separately for symptomatic subgroup; All women in the study are known to have CAD; Study does not compare one NIT to another or to diagnostic cardiac catheterization; Data for women not reported as a subgroup. [pmid: 19460612].
Boyne TS, Koplan BA, Parsons WJ, et al. Predicting adverse outcome with exercise SPECT technetium-99m sestamibi imaging in patients with suspected or known coronary artery disease. Am J Cardiol. 1997;79(3):270-4. Full-text exclusion reason(s): Study does not compare one NIT to another or to diagnostic cardiac catheterization; Data for women not reported as a subgroup. [pmid: 9036743].
Brodoefel H, Burgstahler C, Tsiflikas I, et al. Dual-source CT: effect of heart rate, heart rate variability, and calcification on image quality and diagnostic accuracy. Radiology. 2008;247(2):346-55. Full-text exclusion reason(s): No women with symptomatic chest pain, or results are not reported separately for symptomatic subgroup; All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 18372455].
Brook RD, Bard RL, Patel S, et al. A negative carotid plaque area test is superior to other noninvasive atherosclerosis studies for reducing the likelihood of having underlying significant coronary artery disease. Arterioscler Thromb Vasc Biol. 2006;26(3):656-62. Full-text exclusion reason(s): No women with symptomatic chest pain, or results are not reported separately for symptomatic subgroup; All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 16357319].
Brown KA. Prognostic value of thallium-201 myocardial perfusion imaging. A diagnostic tool comes of age. Circulation. 1991;83(2):363-81. Full-text exclusion reason(s): Not original peer-reviewed data or a secondary analysis of RCT, prospective or retrospective observational study, or registry. [pmid: 1991361].
Brown KA, Boucher CA, Okada RD, et al. Prognostic value of exercise thallium-201 imaging in patients presenting for evaluation of chest pain. J Am Coll Cardiol. 1983;1(4):994-1001. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 6833659].
Brown RA, Schlegel TT. Diagnostic utility of the spatial versus individual planar QRS-T angles in cardiac disease detection. J Electrocardiol. 2011;44(4):404-409. Full-text exclusion reason(s): No data for NITs of interest (ECG, ECHO, SPECT, PET, CMR, CTA). [pmid: 21353236].
Brown TL, Voicu C, Merrill J, et al. Pathophysiologic correlates of 82Rb biodistribution in cardiac PET/CT. Eur J Nucl Med Mol Imaging. 2011;38(3):479-84. Full-text exclusion reason(s): Study does not compare one NIT to another or to diagnostic cardiac catheterization; Data for women not reported as a subgroup; No outcomes of interest. [pmid: 20936408].
Bruder O, Schneider S, Nothnagel D, et al. EuroCMR (European Cardiovascular Magnetic Resonance) registry: results of the German pilot phase. J Am Coll Cardiol. 2009;54(15):1457-66. Full-text exclusion reason(s): All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 19682818].
Bucci M, Joutsiniemi E, Saraste A, et al. Intrapericardial, but not extrapericardial, fat is an independent predictor of impaired hyperemic coronary perfusion in coronary artery disease. Arterioscler Thromb Vasc Biol. 2011;31(1):211-8. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 21030717].
Bucerius J, Joe AY, Herder E, et al. Hemodynamic variables during stress testing can predict referral to early catheterization but failed to show a prognostic impact on emerging cardiac events in patients aged 70 years and older undergoing exercise (99m)Tc-sestamibi myocardial perfusion scintigraphy. Int J Cardiovasc Imaging. 2009;25(6):569-79. Full-text exclusion reason(s): No women with symptomatic chest pain, or results are not reported separately for symptomatic subgroup; All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 19381866].
Bucerius J, Joe AY, Herder E, et al. Pathological 99mTc-sestamibi myocardial perfusion scintigraphy is independently associated with emerging cardiac events in elderly patients with known or suspected coronary artery disease. Acta Radiol. 2011;52(1):52-8. Full-text exclusion reason(s): No women with symptomatic chest pain, or results are not reported separately for symptomatic subgroup; All women in the study are known to have CAD; Study does not compare one NIT to another or to diagnostic cardiac catheterization; Data for women not reported as a subgroup. [pmid: 21498326].
Bucerius J, Joe AY, Herder E, et al. Significant association of female gender with lower degree of pathological 99mTc-sestamibi scintigraphy results as well as higher cardiac-related deaths free survival in elderly patients. Med Klin (Munich). 2010;105(12):901-9. Full-text exclusion reason(s): All women in the study are known to have CAD; Study does not compare one NIT to another or to diagnostic cardiac catheterization. [pmid: 21240589].
Buchthal SD, den Hollander JA, Merz CN, et al. Abnormal myocardial phosphorus-31 nuclear magnetic resonance spectroscopy in women with chest pain but normal coronary angiograms. N Engl J Med. 2000;342(12):829-35. Full-text exclusion reason(s): All women in the study are known to have CAD; No outcomes of interest. [pmid: 10727587].
Budoff MJ. Coronary CT Angiography after invasive angiography: is it worth it?. J Invasive Cardiol. 2008;20(1):7-8. Full-text exclusion reason(s): Not a clinical study report. [pmid: 18174611].
Budoff MJ, Ahmadi N, Sarraf G, et al. Determination of left ventricular mass on cardiac computed tomographic angiography. Acad Radiol. 2009;16(6):726-32. Full-text exclusion reason(s): No outcomes of interest. [pmid: 19427981].
Budoff MJ, Diamond GA, Raggi P, et al. Continuous probabilistic prediction of angiographically significant coronary artery disease using electron beam tomography. Circulation. 2002;105(15):1791-6. Full-text exclusion reason(s): No data for NITs of interest (ECG, ECHO, SPECT, PET, CMR, CTA). [pmid: 11956121].
Budoff MJ, Dowe D, Jollis JG, et al. Diagnostic performance of 64-multidetector row coronary computed tomographic angiography for evaluation of coronary artery stenosis in individuals without known coronary artery disease: results from the prospective multicenter ACCURACY (Assessment by Coronary Computed Tomographic Angiography of Individuals Undergoing Invasive Coronary Angiography) trial. J Am Coll Cardiol. 2008;52(21):1724-32. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 19007693].
Budoff MJ, Georgiou D, Brody A, et al. Ultrafast computed tomography as a diagnostic modality in the detection of coronary artery disease: a multicenter study. Circulation. 1996;93(5):898-904. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 8598080].
Budoff MJ, Gopal A, Gopalakrishnan D. Cardiac computed tomography: Diagnostic utility and integration in clinical practice. Clin Cardiol. 2006;29(9 SUPPL 1):I4-I14. Full-text exclusion reason(s): Not original peer-reviewed data or a secondary analysis of RCT, prospective or retrospective observational study, or registry. [pmid: 17009573].
Budoff MJ, Gopal A, Gul KM, et al. Prevalence of obstructive coronary artery disease in an outpatient cardiac CT angiography environment. Int J Cardiol. 2008;129(1):32-6. Full-text exclusion reason(s): Study does not compare one NIT to another or to diagnostic cardiac catheterization; Data for women not reported as a subgroup. [pmid: 17651836].
Budoff MJ, Lu B, Shinbane JS, et al. Methodology for improved detection of coronary stenoses with computed tomographic angiography. Am Heart J. 2004;148(6):1085-90. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 15632897].
Budoff MJ, Rasouli ML, Shavelle DM, et al. Cardiac CT angiography (CTA) and nuclear myocardial perfusion imaging (MPI)-a comparison in detecting significant coronary artery disease. Acad Radiol. 2007;14(3):252-7. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 17307657].
Budoff MJ, Shavelle DM, Lamont DH, et al. Usefulness of electron beam computed tomography scanning for distinguishing ischemic from nonischemic cardiomyopathy. J Am Coll Cardiol. 1998;32(5):1173-8. Full-text exclusion reason(s): No women with symptomatic chest pain, or results are not reported separately for symptomatic subgroup; All women in the study are known to have CAD. [pmid: 9809922].
Budoff MJ, Shokooh S, Shavelle RM, et al. Electron beam tomography and angiography: sex differences. Am Heart J. 2002;143(5):877-82. Full-text exclusion reason(s): No data for NITs of interest (ECG, ECHO, SPECT, PET, CMR, CTA). [pmid: 12040352].
Budzynski J. Does esophageal dysfunction affect the course of treadmill stress test in patients with recurrent angina-like chest pain?. Pol Arch Med Wewn. 2010;120(12):484-90. Full-text exclusion reason(s): Study does not compare one NIT to another or to diagnostic cardiac catheterization; Data for women not reported as a subgroup; No outcomes of interest. [pmid: 21178904].
Buechel RR, Pazhenkottil AP, Herzog BA, et al. Prognostic performance of low-dose coronary CT angiography with prospective ECG triggering. Heart. 2011;97(17):1385-1390. Full-text exclusion reason(s): Study does not compare one NIT to another or to diagnostic cardiac catheterization. [pmid: 21487129].
Bunce NH, Jhooti P, Keegan J, et al. Evaluation of free-breathing three-dimensional magnetic resonance coronary angiography with hybrid ordered phase encoding (HOPE) for the detection of proximal coronary artery stenosis. J Magn Reson Imaging. 2001;14(6):677-84. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 11747023].
Bunce NH, Reyes E, Keegan J, et al. Combined coronary and perfusion cardiovascular magnetic resonance for the assessment of coronary artery stenosis. J Cardiovasc Magn Reson. 2004;6(2):527-39. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 15137337].
Bungo MW, Leland OS Jr. Discordance of exercise thallium testing with coronary arteriography in patients with atypical presentations. Chest. 1983;83(1):112-6. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 6848315].
Burgstahler C, Beck T, Kuettner A, et al. Image quality and diagnostic accuracy of 16-slice multidetector computed tomography for the detection of coronary artery disease in obese patients. Int J Obes (Lond). 2006;30(3):569-73. Full-text exclusion reason(s): All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 16276363].
Burgstahler C, Beck T, Kuettner A, et al. Image quality and diagnostic accuracy of 16-slice multidetector spiral computed tomography for the detection of coronary artery disease in elderly patients. J Comput Assist Tomogr. 2005;29(6):734-8. Full-text exclusion reason(s): All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 16272841].
Burgstahler C, Beck T, Reimann A, et al. Diagnostic accuracy of multislice computed tomography for the detection of coronary artery disease in diabetic patients. J Diabetes Complications. 2007;21(2):69-74. Full-text exclusion reason(s): All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 17331854].
Burgstahler C, Kunze M, Gawaz MP, et al. Adenosine stress first pass perfusion for the detection of coronary artery disease in patients with aortic stenosis: a feasibility study. Int J Cardiovasc Imaging. 2008;24(2):195-200. Full-text exclusion reason(s): No women with symptomatic chest pain, or results are not reported separately for symptomatic subgroup; Data for women not reported as a subgroup. [pmid: 17541724].
Burgstahler C, Reimann A, Drosch T, et al. Cardiac dual-source computed tomography in patients with severe coronary calcifications and a high prevalence of coronary artery disease. J Cardiovasc Comput Tomogr. 2007;1(3):143-51. Full-text exclusion reason(s): No women with symptomatic chest pain, or results are not reported separately for symptomatic subgroup; All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 19083898].
Burns RJ, Galligan L, Wright LM, et al. Improved specificity of myocardial thallium-201 single-photon emission computed tomography in patients with left bundle branch block by dipyridamole. Am J Cardiol. 1991;68(5):504-8. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 1872279].
Butler J, Shapiro M, Reiber J, et al. Extent and distribution of coronary artery disease: a comparative study of invasive versus noninvasive angiography with computed angiography. Am Heart J. 2007;153(3):378-84. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 17307416].
Bybee KA, Lee J, Markiewicz R, et al. Diagnostic and clinical benefit of combined coronary calcium and perfusion assessment in patients undergoing PET/CT myocardial perfusion stress imaging. J Nucl Cardiol. 2010;17(2):188-196. Full-text exclusion reason(s): All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 20012515].
Cademartiri F, Carli MF. MSCT is better than stress perfusion imaging for detecting CAD. European Journal of Nuclear Medicine and Molecular Imaging. 2006;33(3):353-359. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 16435114].
Cademartiri F, La Grutta L, Malago R, et al. Assessment of left main coronary artery atherosclerotic burden using 64-slice CT coronary angiography: correlation between dimensions and presence of plaques. Radiol Med. 2009;114(3):358-69. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 19381764].
Cademartiri F, La Grutta L, Palumbo A, et al. Computed tomography coronary angiography vs. stress ECG in patients with stable angina. Radiol Med. 2009;114(4):513-23. Full-text exclusion reason(s): Not original peer-reviewed data or a secondary analysis of RCT, prospective or retrospective observational study, or registry. [pmid: 19367464].
Cademartiri F, Maffei E, Notarangelo F, et al. 64-slice computed tomography coronary angiography: diagnostic accuracy in the real world. Radiol Med. 2008;113(2):163-80. Full-text exclusion reason(s): All women in the study are known to have CAD; No outcomes of interest. [pmid: 18386119].
Cademartiri F, Maffei E, Palumbo A, et al. Diagnostic accuracy of 64-slice computed tomography coronary angiography in patients with low-to-intermediate risk. Radiol Med. 2007;112(7):969-81. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 17952682].
Cademartiri F, Maffei E, Palumbo A, et al. Diagnostic accuracy of computed tomography coronary angiography in patients with a zero calcium score. Eur Radiol. 2010;20(1):81-7. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 19657651].
Cademartiri F, Maffei E, Palumbo A, et al. Coronary calcium score and computed tomography coronary angiography in high-risk asymptomatic subjects: assessment of diagnostic accuracy and prevalence of non-obstructive coronary artery disease. Eur Radiol. 2010;20(4):846-54. Full-text exclusion reason(s): No women with symptomatic chest pain, or results are not reported separately for symptomatic subgroup; Data for women not reported as a subgroup. [pmid: 19760230].
Cademartiri F, Maffei E, Palumbo AA, et al. Influence of intra-coronary enhancement on diagnostic accuracy with 64-slice CT coronary angiography. Eur Radiol. 2008;18(3):576-83. Full-text exclusion reason(s): All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 17934740].
Cademartiri F, Malago R, Belgrano M, et al. Spectrum of collateral findings in multislice CT coronary angiography. Radiol Med. 2007;112(7):937-48. Full-text exclusion reason(s): Study does not compare one NIT to another or to diagnostic cardiac catheterization; Data for women not reported as a subgroup; No outcomes of interest. [pmid: 17952684].
Cademartiri F, Mollet NR, Lemos PA, et al. Impact of coronary calcium score on diagnostic accuracy for the detection of significant coronary stenosis with multislice computed tomography angiography. Am J Cardiol. 2005;95(10):1225-7. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 15877996].
Cademartiri F, Mollet NR, Runza G, et al. Diagnostic accuracy of multislice computed tomography coronary angiography is improved at low heart rates. Int J Cardiovasc Imaging. 2006;22(1):101-5. discussion 107–9. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 16077999].
Cademartiri F, Romano M, Seitun S, et al. Prevalence and characteristics of coronary artery disease in a population with suspected ischemic heart disease using CT coronary angiography: correlations with cardiovascular risk factors and clinical presentation. Radiol Med. 2008;113(3):363-72. Full-text exclusion reason(s): Study does not compare one NIT to another or to diagnostic cardiac catheterization; Data for women not reported as a subgroup. [pmid: 18493773].
Cademartiri F, Runza G, Marano R, et al. Diagnostic accuracy of 16-row multislice CT angiography in the evaluation of coronary segments. Radiol Med. 2005;109(1–2):91-7. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 15729189].
Cademartiri F, Seitun S, Romano M, et al. Prognostic value of 64-slice coronary angiography in diabetes mellitus patients with known or suspected coronary artery disease compared with a nondiabetic population. Radiol Med. 2008;113(5):627-43. Full-text exclusion reason(s): No women with symptomatic chest pain, or results are not reported separately for symptomatic subgroup; All women in the study are known to have CAD; Study does not compare one NIT to another or to diagnostic cardiac catheterization; Data for women not reported as a subgroup. [pmid: 18478189].
Campisi R. Noninvasive assessment of coronary microvascular function in women at risk for ischaemic heart disease. Int J Clin Pract. 2008;62(2):300-7. Full-text exclusion reason(s): Not a clinical study report. [pmid: 17956559].
Campos AM, da Cunha AB. Dobutamine stress echocardiography as a predictor of coronary lesion severity on coronary angiography. Rev Port Cardiol. 2007;26(5):505-18. Full-text exclusion reason(s): No women with symptomatic chest pain, or results are not reported separately for symptomatic subgroup; All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 17691277].
Candell-Riera J, Oller-Martinez G, de Leon G, et al. Yield of early rest and stress myocardial perfusion single-photon emission computed tomography and electrocardiographic exercise test in patients with atypical chest pain, nondiagnostic electrocardiogram, and negative biochemical markers in the emergency department. Am J Cardiol. 2007;99(12):1662-6. Full-text exclusion reason(s): All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 17560871].
Candell-Riera J, Oller-Martínez G, Pereztol-Valdés O, et al. Early myocardial perfusion gated-SPECT in patients with chest pain and non-diagnostic ECG in the emergency department. Revista espanola de cardiología. 2004;(3):225-33. Full-text exclusion reason(s): Data for women not reported as a subgroup.
Candell-Riera J, Santana-Boado C, Bermejo B, et al. Interhospital observer agreement in interpretation of exercise myocardial Tc-99m tetrofosmin SPECT studies. J Nucl Cardiol. 2001;8(1):49-57. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 11182709].
Carmo MM, Ferreira T, Quininha J, et al. Non-invasive coronary artery evaluation with multidetector computed tomography. Rev Port Cardiol. 2005;24(5):667-79. Full-text exclusion reason(s): All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 16041964].
Carrascosa P, Capunay C, Bettinotti M, et al. Feasibility of gadolinium-diethylene triamine pentaacetic acid enhanced multidetector computed tomography for the evaluation of coronary artery disease. J Cardiovasc Comput Tomogr. 2007;1(2):86-94. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 19083885].
Carrascosa P, Capunay C, Deviggiano A, et al. Feasibility of 64-slice gadolinium-enhanced cardiac CT for the evaluation of obstructive coronary artery disease. Heart. 2010;96(19):1543-1549. Full-text exclusion reason(s): No women with symptomatic chest pain, or results are not reported separately for symptomatic subgroup; All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 20406770].
Carrascosa P, Capunay C, Deviggiano A, et al. Accuracy of low-dose prospectively gated axial coronary CT angiography for the assessment of coronary artery stenosis in patients with stable heart rate. J Cardiovasc Comput Tomogr. 2010;4(3):197-205. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 20444666].
Carrascosa PM, Capunay CM, Parodi JC, et al. General utilities of multislice tomography in the cardiac field. Herz. 2003;28(1):44-51. Full-text exclusion reason(s): All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 12616320].
Carrigan TP, Nair D, Schoenhagen P, et al. Prognostic utility of 64-slice computed tomography in patients with suspected but no documented coronary artery disease. Eur Heart J. 2009;30(3):362-71. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 19153177].
Carrillof Lopez L, Frade Garcia J, Gomez Lepe A, et al. Correlation between findings of exertion ECG with 12 derivations and coronoriography. Arch Inst Cardiol Mex. 1978;48(4):823-39. Full-text exclusion reason(s): Non-English. [pmid: 697470].
Carrinho M, Moraes A, Morcerf F, et al. Myocardial contrast echocardiography in patients with suspected or known coronary artery disease: comparison with myocardial nuclear scintigraphy. Arq Bras Cardiol. 2004;83(5):419-23. 414. 8. Full-text exclusion reason(s): All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 15543361].
Caruana L, Petrie MC, Davie AP, et al. Do patients with suspected heart failure and preserved left ventricular systolic function suffer from “diastolic heart failure” or from misdiagnosis? A prospective descriptive study. BMJ. 2000;321(7255):215-8. Full-text exclusion reason(s): No data for NITs of interest (ECG, ECHO, SPECT, PET, CMR, CTA). [pmid: 10903655].
Casolo G, Del Meglio J, Rega L, et al. Detection and assessment of coronary artery anomalies by three-dimensional magnetic resonance coronary angiography. Int J Cardiol. 2005;103(3):317-22. Full-text exclusion reason(s): All women in the study are known to have CAD; Data for women not reported as a subgroup; No outcomes of interest. [pmid: 16098396].
Castini D, Gentile F, Ornaghi M, et al. Dobutamine echocardiography: usefulness of digital image processing. Eur Heart J. 1995;16(10):1420-4. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 8746911].
Catalan P, Leta R, Hidalgo A, et al. Ruling out coronary artery disease with noninvasive coronary multidetector CT angiography before noncoronary cardiovascular surgery. Radiology. 2011;258(2):426-34. Full-text exclusion reason(s): No women with symptomatic chest pain, or results are not reported separately for symptomatic subgroup; Data for women not reported as a subgroup. [pmid: 21079198].
Caussin C, Daoud B, Ghostine S, et al. Comparison of lumens of intermediate coronary stenosis using 16-slice computed tomography versus intravascular ultrasound. Am J Cardiol. 2005;96(4):524-8. Full-text exclusion reason(s): All women in the study are known to have CAD; Study does not compare one NIT to another or to diagnostic cardiac catheterization; Data for women not reported as a subgroup. [pmid: 16098305].
Caussin C, Ohanessian A, Ghostine S, et al. Characterization of vulnerable nonstenotic plaque with 16-slice computed tomography compared with intravascular ultrasound. Am J Cardiol. 2004;94(1):99-104. Full-text exclusion reason(s): All women in the study are known to have CAD; Study does not compare one NIT to another or to diagnostic cardiac catheterization. [pmid: 15219516].
Cecil MP, Kosinski AS, Jones MT, et al. The importance of work-up (verification) bias correction in assessing the accuracy of SPECT thallium-201 testing for the diagnosis of coronary artery disease. J Clin Epidemiol. 1996;49(7):735-42. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 8691222].
Cerci MSJ, Cerci JJ, Cerci RJ, et al. Myocardial perfusion imaging is a strong predictor of death in women. JACC: Cardiovascular Imaging. 2011;4(8):880-888. Full-text exclusion reason(s): Study does not compare one NIT to another or to diagnostic cardiac catheterization. [pmid: 21835380].
Chalela WA, Mansur AP, Aldrighi JM. Noninvasive diagnostic evaluation for chest pain in women. Arq Bras Cardiol. 2001;76(6):535-44. Full-text exclusion reason(s): Not a clinical study report. [pmid: 11449299].
Chammas E, Yatim A, Hage C, et al. Evaluation of Tc-99m tetrofosmin scan for coronary artery disease diagnosis. Asian Cardiovasc Thorac Ann. 2002;10(3):244-7. Full-text exclusion reason(s): No women with symptomatic chest pain, or results are not reported separately for symptomatic subgroup; All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 12213749].
Chan RK, Tonkin AM, Byrgiotis S, et al. Assessment of coronary artery disease by dobutamine stress echocardiography (DSE). Aust N Z J Med. 1995;25(6):707-15. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 8770336].
Chang AM, Shofer FS, Weiner MG, et al. Actual financial comparison of four strategies to evaluate patients with potential acute coronary syndromes. Acad Emerg Med. 2008;15(7):649-55. Full-text exclusion reason(s): No women with symptomatic chest pain, or results are not reported separately for symptomatic subgroup; All women in the study are known to have CAD; Data for women not reported as a subgroup; No outcomes of interest. [pmid: 18691213].
Chang SA, Choi SI, Choi EK, et al. Usefulness of 64-slice multidetector computed tomography as an initial diagnostic approach in patients with acute chest pain. Am Heart J. 2008;156(2):375-83. Full-text exclusion reason(s): Study does not compare one NIT to another or to diagnostic cardiac catheterization; Data for women not reported as a subgroup. [pmid: 18657674].
Chang SM, Hakeem A, Nagueh SF. Predicting clinically unrecognized coronary artery disease: use of two- dimensional echocardiography. Cardiovasc Ultrasound. 2009;7:10. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 19267918].
Chang SM, Nabi F, Xu J, et al. The coronary artery calcium score and stress myocardial perfusion imaging provide independent and complementary prediction of cardiac risk. J Am Coll Cardiol. 2009;54(20):1872-82. Full-text exclusion reason(s): No women with symptomatic chest pain, or results are not reported separately for symptomatic subgroup; Data for women not reported as a subgroup. [pmid: 19892239].
Chang SM, Nabi F, Xu J, et al. Normal stress-only versus standard stress/rest myocardial perfusion imaging: similar patient mortality with reduced radiation exposure. J Am Coll Cardiol. 2010;55(3):221-30. Full-text exclusion reason(s): No women with symptomatic chest pain, or results are not reported separately for symptomatic subgroup; All women in the study are known to have CAD; Study does not compare one NIT to another or to diagnostic cardiac catheterization; Data for women not reported as a subgroup; No outcomes of interest. [pmid: 19913381].
Chao SP, Law WY, Kuo CJ, et al. The diagnostic accuracy of 256-row computed tomographic angiography compared with invasive coronary angiography in patients with suspected coronary artery disease. Euro Heart J. 2010;31(15):1916-1923. Full-text exclusion reason(s): No women with symptomatic chest pain, or results are not reported separately for symptomatic subgroup; All women in the study are known to have CAD; Data for women not reported as a subgroup.
Charvat J, Michalova K, Taborska K, et al. Comparison of the exercise ECG and stress myocardial SPECT in detection of the significant coronary artery disease in the asymptomatic patients with diabetes mellitus type 2. Bratisl Lek Listy. 2004;105(2):56-61. Full-text exclusion reason(s): No women with symptomatic chest pain, or results are not reported separately for symptomatic subgroup; Data for women not reported as a subgroup. [pmid: 15253536].
Chattranukulchai P, Tumkosit M, Cholteesupachai J, et al. Diagnostic accuracy of combined dipyridamole stress perfusion and delayed enhancement cardiovascular magnetic resonance imaging for detection of coronary artery disease. Asian Biomedicine. 2010;4(1):19-25. Full-text exclusion reason(s): No women with symptomatic chest pain, or results are not reported separately for symptomatic subgroup; All women in the study are known to have CAD; Data for women not reported as a subgroup.
Chatziioannou SN, Moore WH, Dhekne RD, et al. Women with high exercise tolerance and the role of myocardial perfusion imaging. Clin Cardiol. 2001;24(6):475-80. Full-text exclusion reason(s): No women with symptomatic chest pain, or results are not reported separately for symptomatic subgroup. [pmid: 11403510].
Chatziioannou SN, Moore WH, Ford PV, et al. Prognostic value of myocardial perfusion imaging in patients with high exercise tolerance. Circulation. 1999;99(7):867-72. Full-text exclusion reason(s): Study does not compare one NIT to another or to diagnostic cardiac catheterization; Data for women not reported as a subgroup. [pmid: 10027807].
Chaudhry FA, Tauke JT, Alessandrini RS, et al. Enhanced detection of ischemic myocardium by transesophageal dobutamine stress echocardiography: comparison with simultaneous transthoracic echocardiography. Echocardiography. 2000;17(3):241-53. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 10978988].
Cheezum MK, Hulten EA, Taylor AJ, et al. Cardiac CT angiography compared with myocardial perfusion stress testing on downstream resource utilization. J Cardiovasc Comput Tomogr. 2011;5(2):101-9. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 21256102].
Chen G, Redberg RF. Noninvasive diagnostic testing of coronary artery disease in women. Cardiol Rev. 2000;8(6):354-60. Full-text exclusion reason(s): Not a clinical study report. [pmid: 11208256].
Chen HW, Fang XM, Hu XY, et al. Efficacy of dual-source CT coronary angiography in evaluating coronary stenosis: initial experience. Clin Imaging. 2010;34(3):165-71. Full-text exclusion reason(s): No women with symptomatic chest pain, or results are not reported separately for symptomatic subgroup; Data for women not reported as a subgroup; No outcomes of interest. [pmid: 20416479].
Chen JC, Wang MT, Wang YIC, et al. 40-Slice multi-detector computed tomography in detecting coronary artery stenosis: A preliminary result. Chinese Journal of Radiology. 2009;34(3):161-170. +171. Full-text exclusion reason(s): No women with symptomatic chest pain, or results are not reported separately for symptomatic subgroup; Data for women not reported as a subgroup.
Chen LC, Chen JW, Wu MH, et al. Differential coronary artery calcification detected by electron beam computed tomography as an indicator of coronary stenosis among patients with stable angina pectoris. Can J Cardiol. 2001;17(6):667-76. Full-text exclusion reason(s): No women with symptomatic chest pain, or results are not reported separately for symptomatic subgroup; Data for women not reported as a subgroup. [pmid: 11420578].
Chen LC, Ding PY, Chen JW, et al. Coronary artery calcium determined by electron beam computed tomography for predicting angiographic coronary artery disease in moderate- to high-risk Chinese patients. Cardiology. 2001;95(4):183-9. Full-text exclusion reason(s): No women with symptomatic chest pain, or results are not reported separately for symptomatic subgroup; All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 11585993].
Chen Y, Han P, Liang B, et al. Comparative study on 16-slice CT coronary angiography vs conventional coronary angiography—a report of 38 cases. J Huazhong Univ Sci Technolog Med Sci. 2008;28(1):110-3. Full-text exclusion reason(s): No women with symptomatic chest pain, or results are not reported separately for symptomatic subgroup; Data for women not reported as a subgroup. [pmid: 18278472].
Chen YC, Chin KC, Ko JT. Value of ECG-gated thallium-201 dipyridamole SPECT in borderline cases of myocardial perfusion scan. Acta Cardiologica Sinica. 2006;22(1):24-30. Full-text exclusion reason(s): Data for women not reported as a subgroup.
Chen Z, Duan Q, Xue X, et al. Noninvasive detection of coronary artery stenoses with contrast-enhanced whole-heart coronary magnetic resonance angiography at 3.0 T. Cardiology. 2010;117(4):284-290. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 21325851].
Cheneau E, Vahdat B, Bernard L, et al. Routine use of coronary computed tomography as initial diagnostic test for angina pectoris. Arch Cardiovasc Dis. 2011;104(1):29-34. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 21276575].
Cheng AS, Pegg TJ, Karamitsos TD, et al. Cardiovascular magnetic resonance perfusion imaging at 3-tesla for the detection of coronary artery disease: a comparison with 1.5-tesla. J Am Coll Cardiol. 2007;49(25):2440-9. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 17599608].
Cheng CW, Yang NI, Lin KJ, et al. Role of coronary spasm for a positive noninvasive stress test result in angina pectoris patients without hemodynamically significant coronary artery disease. Am J Med Sci. 2008;335(5):354-62. Full-text exclusion reason(s): Data for women not reported as a subgroup; No outcomes of interest. [pmid: 18480651].
Cheng V, Gutstein A, Wolak A, et al. Moving beyond binary grading of coronary arterial stenoses on coronary computed tomographic angiography: insights for the imager and referring clinician. JACC Cardiovasc Imaging. 2008;1(4):460-71. Full-text exclusion reason(s): No women with symptomatic chest pain, or results are not reported separately for symptomatic subgroup; All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 19356468].
Cheng W, Zeng M, Arellano C, et al. Detection of myocardial perfusion abnormalities: Standard dual-source coronary computed tomography angiography versus rest/stress technetium-99m single-photo emission CT. Br J Radiol. 2010;83(992):652-660. Full-text exclusion reason(s): All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 20413446].
Chikamori T, Doi YL, Yonezawa Y, et al. Noninvasive identification of significant narrowing of the left main coronary artery by dipyridamole thallium scintigraphy. Am J Cardiol. 1991;68(5):472-7. Full-text exclusion reason(s): All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 1872274].
Chikamori T, Hirakawa K, Seo H, et al. Diagnostic significance of exercise-induced ST-segment depression in the lateral limb leads in patients with suspected coronary artery disease. Am J Cardiol. 1995;76(7):513-6. Full-text exclusion reason(s): No women with symptomatic chest pain, or results are not reported separately for symptomatic subgroup; Data for women not reported as a subgroup. [pmid: 7653455].
Chiou KR, Huang WC, Lin SL, et al. Real-time dobutamine stress myocardial contrast echocardiography for detecting coronary artery disease: correlating abnormal wall motion and disturbed perfusion. Can J Cardiol. 2004;20(12):1237-43. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 15494776].
Cho JS, Youn HJ, Cho EJ, et al. Dyssynchrony contributes to false-positive myocardial perfusion SPECT results in patients with stable angina. Eur J Echocardiogr. 2011;12(6):461-6. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 21551451].
Choi EK, Chun EJ, Choi SI, et al. Assessment of subclinical coronary atherosclerosis in asymptomatic patients with type 2 diabetes mellitus with single photon emission computed tomography and coronary computed tomography angiography. Am J Cardiol. 2009;104(7):890-6. Full-text exclusion reason(s): No women with symptomatic chest pain, or results are not reported separately for symptomatic subgroup; Data for women not reported as a subgroup. [pmid: 19766752].
Choi JO, Cho SW, Song YB, et al. Longitudinal 2D strain at rest predicts the presence of left main and three vessel coronary artery disease in patients without regional wall motion abnormality. Eur J Echocardiogr. 2009;10(5):695-701. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 19401300].
Choi SW, Cho KI, Lee HG, et al. Diagnostic value of ultrasound-based strain imaging in patients with suspected coronary artery disease. Korean Circulation Journal. 2008;38(8):398-404. Full-text exclusion reason(s): No women with symptomatic chest pain, or results are not reported separately for symptomatic subgroup; Data for women not reported as a subgroup.
Choi YS, Youn HJ, Park CS, et al. High echogenic thickening of proximal coronary artery predicts the far advanced coronary atherosclerosis. Echocardiography. 2009;26(2):133-9. Full-text exclusion reason(s): No data for NITs of interest (ECG, ECHO, SPECT, PET, CMR, CTA). [pmid: 19017326].
Chotenimitkhun R, Hundley WG. Pharmacological stress cardiovascular magnetic resonance. Postgrad Med. 2011;123(3):162-70. Full-text exclusion reason(s): Not original peer-reviewed data or a secondary analysis of RCT, prospective or retrospective observational study, or registry. [pmid: 21566427].
Choudhary G, Shin V, Punjani S, et al. The role of calcium score and CT angiography in the medical management of patients with normal myocardial perfusion imaging. J Nucl Cardiol. 2010;17(1):45-51. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 19936862].
Chow BJ, Abraham A, Wells GA, et al. Diagnostic accuracy and impact of computed tomographic coronary angiography on utilization of invasive coronary angiography. Circ Cardiovasc Imaging. 2009;2(1):16-23. Full-text exclusion reason(s): No women with symptomatic chest pain, or results are not reported separately for symptomatic subgroup; Data for women not reported as a subgroup. [pmid: 19808560].
Chow BJ, Al Shammeri OM, Beanlands RS, et al. Prognostic value of treadmill exercise and dobutamine stress positron emission tomography. Can J Cardiol. 2009;25(7):e220-4. Full-text exclusion reason(s): No women with symptomatic chest pain, or results are not reported separately for symptomatic subgroup; Study does not compare one NIT to another or to diagnostic cardiac catheterization; Data for women not reported as a subgroup. [pmid: 19584976].
Chow BJ, Ananthasubramaniam K, dekemp RA, et al. Comparison of treadmill exercise versus dipyridamole stress with myocardial perfusion imaging using rubidium-82 positron emission tomography. J Am Coll Cardiol. 2005;45(8):1227-34. Full-text exclusion reason(s): All women in the study are known to have CAD; Study does not compare one NIT to another or to diagnostic cardiac catheterization; Data for women not reported as a subgroup. [pmid: 15837254].
Chow BJ, Dennie C, Hoffmann U, et al. Comparison of computed tomographic angiography versus rubidium-82 positron emission tomography for the detection of patients with anatomical coronary artery disease. Can J Cardiol. 2007;23(10):801-7. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 17703259].
Chow BJ, Joseph P, Yam Y, et al. Usefulness of computed tomographic coronary angiography in patients with acute chest pain with and without high-risk features. Am J Cardiol. 2010;106(4):463-9. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 20691302].
Chow BJ, Kass M, Gagne O, et al. Can differences in corrected coronary opacification measured with computed tomography predict resting coronary artery flow?. J Am Coll Cardiol. 2011;57(11):1280-8. Full-text exclusion reason(s): Data for women not reported as a subgroup; No outcomes of interest. [pmid: 21392642].
Chow BJW, Freeman MR, Bowen JM, et al. Ontario multidetector computed tomographic coronary angiography study: Field evaluation of diagnostic accuracy. Arch Intern Med. 2011;171(11):1021-1029. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 21403014].
Choy JB, Leslie WD. Clinical correlates of Tc-99m sestamibi lung uptake. J Nucl Cardiol. 2001;8(6):639-44. Full-text exclusion reason(s): No women with symptomatic chest pain, or results are not reported separately for symptomatic subgroup; Data for women not reported as a subgroup. [pmid: 11725259].
Christensen HW, Haghfelt T, Vach W, et al. Observer reproducibility and validity of systems for clinical classification of angina pectoris: comparison with radionuclide imaging and coronary angiography. Clin Physiol Funct Imaging. 2006;26(1):26-31. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 16398667].
Christian TF, Miller TD, Bailey KR, et al. Noninvasive identification of severe coronary artery disease using exercise tomographic thallium-201 imaging. Am J Cardiol. 1992;70(1):14-20. Full-text exclusion reason(s): All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 1615863].
Christiansen JP, Edwards C, Sinclair T, et al. Detection of myocardial scar by contrast-enhanced cardiac magnetic resonance imaging in patients with troponin-positive chest pain and minimal angiographic coronary artery disease. Am J Cardiol. 2006;97(6):768-71. Full-text exclusion reason(s): No women with symptomatic chest pain, or results are not reported separately for symptomatic subgroup; Data for women not reported as a subgroup. [pmid: 16516572].
Chu ZG, Yang ZG, Dong ZH, et al. Characteristics of coronary artery disease in symptomatic type 2 diabetic patients: evaluation with CT angiography. Cardiovasc Diabetol. 2010;9:74. Full-text exclusion reason(s): All women in the study are known to have CAD; Study does not compare one NIT to another or to diagnostic cardiac catheterization; Data for women not reported as a subgroup. [pmid: 21067585].
Chun EJ, Lee W, Choi YH, et al. Effects of nitroglycerin on the diagnostic accuracy of electrocardiogram-gated coronary computed tomography angiography. J Comput Assist Tomogr. 2008;32(1):86-92. Full-text exclusion reason(s): No women with symptomatic chest pain, or results are not reported separately for symptomatic subgroup; Data for women not reported as a subgroup. [pmid: 18303294].
Chung WY, Sir JJ, Cho YS, et al. Additive value of B-type natriuretic peptide on rest 201 Tl-dipyridamole stress 99m Tc-sestamibi gated myocardial SPECT in patients with normal left ventricular systolic function. Cardiol Res Pract. 2010;1(1). Full-text exclusion reason(s): Data for women not reported as a subgroup.
Ciaroni S, Bloch A, Hoffmann JL, et al. Prognostic value of dobutamine echocardiography in patients with intermediate coronary lesions at angiography. Echocardiography. 2002;19(7 Pt 1):549-53. Full-text exclusion reason(s): Study does not compare one NIT to another or to diagnostic cardiac catheterization; Data for women not reported as a subgroup. [pmid: 12376006].
Cilli A, Batmaz F, Demir I, et al. The diagnostic yield of exercise stress testing as a screening tool for subclinical coronary artery disease in patients with moderate to severe obstructive sleep apnea. J Clin Sleep Med. 2011;7(1):25-9. Full-text exclusion reason(s): No women with symptomatic chest pain, or results are not reported separately for symptomatic subgroup; Study does not compare one NIT to another or to diagnostic cardiac catheterization; Data for women not reported as a subgroup. [pmid: 21344047].
Clouse ME, Sabir A, Yam CS, et al. Measuring noncalcified coronary atherosclerotic plaque using voxel analysis with MDCT angiography: a pilot clinical study. AJR Am J Roentgenol. 2008;190(6):1553-60. Full-text exclusion reason(s): No women with symptomatic chest pain, or results are not reported separately for symptomatic subgroup; Data for women not reported as a subgroup. [pmid: 18492906].
Coffey JP, Hill JC. Cardiac output and index in obese and non-obese patients using gated single photon emission computed tomographysestamibi pertusion imaging. Journal of the Hong Kong College of Radiologists. 2005;8(4):226-232. Full-text exclusion reason(s): No women with symptomatic chest pain, or results are not reported separately for symptomatic subgroup; Data for women not reported as a subgroup.
Cohen JL, Greene TO, Ottenweller J, et al. Dobutamine digital echocardiography for detecting coronary artery disease. Am J Cardiol. 1991;67(16):1311-8. Full-text exclusion reason(s): All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 2042561].
Cohen JL, Ottenweller JE, George AK, et al. Comparison of dobutamine and exercise echocardiography for detecting coronary artery disease. Am J Cardiol. 1993;72(17):1226-31. Full-text exclusion reason(s): All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 8256696].
Cole JH, Chunn VM, Morrow JA, et al. Cost implications of initial computed tomography angiography as opposed to catheterization in patients with mildly abnormal or equivocal myocardial perfusion scans. J Cardiovasc Comput Tomogr. 2007;1(1):21-6. Full-text exclusion reason(s): No women with symptomatic chest pain, or results are not reported separately for symptomatic subgroup; Data for women not reported as a subgroup; No outcomes of interest. [pmid: 19083872].
Coles DR, Smail MA, Negus IS, et al. Comparison of radiation doses from multislice computed tomography coronary angiography and conventional diagnostic angiography. J Am Coll Cardiol. 2006;47(9):1840-5. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 16682310].
Coles DR, Wilde P, Oberhoff M, et al. Multislice computed tomography coronary angiography in patients admitted with a suspected acute coronary syndrome. Int J Cardiovasc Imaging. 2007;23(5):603-14. Full-text exclusion reason(s): All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 17164983].
Coma-Canella I, Martinez-Caro D, Cosin-Sales J, et al. Clandestine ischemia in patients with vasospastic angina. Coron Artery Dis. 2000;11(5):383-90. Full-text exclusion reason(s): Data for women not reported as a subgroup; No outcomes of interest. [pmid: 10895404].
Coma-Canella I, Palazuelos J, Bravo N, et al. Myocardial perfusion imaging with adenosine triphosphate predicts the rate of cardiovascular events. J Nucl Cardiol. 2006;13(3):316-323. Full-text exclusion reason(s): No women with symptomatic chest pain, or results are not reported separately for symptomatic subgroup; All women in the study are known to have CAD; Study does not compare one NIT to another or to diagnostic cardiac catheterization; Data for women not reported as a subgroup. [pmid: 16750775].
Comess KA, Choi JH, Xie Z, et al. Transthoracic coronary doppler vibrometry in the evaluation of normal volunteers and patients with coronary artery stenosis. Ultrasound in Medicine and Biology. 2011;37(5):679-687. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 21497717].
Conti A, Sammicheli L, Gallini C, et al. Assessment of patients with low-risk chest pain in the emergency department: Head-to-head comparison of exercise stress echocardiography and exercise myocardial SPECT. Am Heart J. 2005;149(5):894-901. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 15894974].
Conti A, Vanni S, Sammicheli L, et al. Yield of nuclear scan strategy in chest pain unit evaluation of special populations. Nucl Med Commun. 2008;29(12):1106-12. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 18987533].
Conti A, Zanobetti M, Grifoni S, et al. Implementation of myocardial perfusion imaging in the early triage of patients with suspected acute coronary syndromes. Nucl Med Commun. 2003;24(10):1055-60. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 14508161].
Cortigiani L, Bigi R, Landi P, et al. Prognostic implication of stress echocardiography in 6214 hypertensive and 5328 normotensive patients. Euro Heart J. 2011;32(12):1509-1518. Full-text exclusion reason(s): Data for women not reported as a subgroup.
Cortigiani L, Bigi R, Rigo F, et al. Diagnostic value of exercise electrocardiography and dipyridamole stress echocardiography in hypertensive and normotensive chest pain patients with right bundle branch block. J Hypertens. 2003;21(11):2189-94. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 14597864].
Cortigiani L, Coletta C, Bigi R, et al. Clinical, exercise electrocardiographic, and pharmacologic stress echocardiographic findings for risk stratification of hypertensive patients with chest pain. Am J Cardiol. 2003;91(8):941-5. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 12686332].
Cortigiani L, Rigo F, Gherardi S, et al. Prognostic effect of coronary flow reserve in women versus men with chest pain syndrome and normal dipyridamole stress echocardiography. Am J Cardiol. 2010;106(12):1703-8. Full-text exclusion reason(s): Study does not compare one NIT to another or to diagnostic cardiac catheterization. [pmid: 21126613].
Cosson E, Guimfack M, Paries J, et al. Are silent coronary stenoses predictable in diabetic patients and predictive of cardiovascular events?. Diabetes Metab. 2003;29(5):470-6. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 14631323].
Costa MA, Shoemaker S, Futamatsu H, et al. Quantitative magnetic resonance perfusion imaging detects anatomic and physiologic coronary artery disease as measured by coronary angiography and fractional flow reserve. J Am Coll Cardiol. 2007;50(6):514-22. Full-text exclusion reason(s): All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 17678734].
Cosyns B, Lancellotti P, Van Camp G, et al. Head to head comparison of transesophageal and transthoracic contrast-enhanced echocardiography during dobutamine administration for the detection of coronary artery disease. Int J Cardiol. 2008;129(1):105-10. Full-text exclusion reason(s): All women in the study are known to have CAD; Study does not compare one NIT to another or to diagnostic cardiac catheterization; Data for women not reported as a subgroup. [pmid: 17719663].
Coyne EP, Belvedere DA, Vande Streek PR, et al. Thallium-201 scintigraphy after intravenous infusion of adenosine compared with exercise thallium testing in the diagnosis of coronary artery disease. J Am Coll Cardiol. 1991;17(6):1289-94. Full-text exclusion reason(s): All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 2016445].
Cramer MJ, van der Wall EE, Jaarsma W, et al. Detection of coronary artery disease: comparison between technetium 99m-labeled sestamibi single-photon emission computed tomography and two-dimensional echocardiography with dipyridamole low-level exercise-stress. J Nucl Cardiol. 1996;3(5):389-94. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 8902670].
Crouse LJ, Harbrecht JJ, Vacek JL, et al. Exercise echocardiography as a screening test for coronary artery disease and correlation with coronary arteriography. Am J Cardiol. 1991;67(15):1213-8. Full-text exclusion reason(s): No women with symptomatic chest pain, or results are not reported separately for symptomatic subgroup; Data for women not reported as a subgroup. [pmid: 2035443].
Cury RC, Cattani CA, Gabure LA, et al. Diagnostic performance of stress perfusion and delayed-enhancement MR imaging in patients with coronary artery disease. Radiology. 2006;240(1):39-45. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 16793971].
Cury RC, Ferencik M, Achenbach S, et al. Accuracy of 16-slice multi-detector CT to quantify the degree of coronary artery stenosis: assessment of cross-sectional and longitudinal vessel reconstructions. Eur J Radiol. 2006;57(3):345-50. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 16442256].
Cury RC, Magalhaes TA, Borges AC, et al. Dipyridamole stress and rest myocardial perfusion by 64-detector row computed tomography in patients with suspected coronary artery disease. Am J Cardiol. 2010;106(3):310-5. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 20643238].
Cury RC, Pomerantsev EV, Ferencik M, et al. Comparison of the degree of coronary stenoses by multidetector computed tomography versus by quantitative coronary angiography. Am J Cardiol. 2005;96(6):784-7. Full-text exclusion reason(s): All women in the study are known to have CAD; Data for women not reported as a subgroup; No outcomes of interest. [pmid: 16169361].
Cury RC, Techasith T, Feuchtner G, et al. Cardiovascular disease and stroke in women: role of radiology. AJR Am J Roentgenol. 2011;196(2):265-73. Full-text exclusion reason(s): Not original peer-reviewed data or a secondary analysis of RCT, prospective or retrospective observational study, or registry. [pmid: 21257876].
Cwajg J, Xie F, O’Leary E, et al. Detection of angiographically significant coronary artery disease with accelerated intermittent imaging after intravenous administration of ultrasound contrast material. Am Heart J. 2000;139(4):675-83. Full-text exclusion reason(s): All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 10740151].
Dagianti A, Penco M, Agati L, et al. Stress echocardiography: comparison of exercise, dipyridamole and dobutamine in detecting and predicting the extent of coronary artery disease. J Am Coll Cardiol. 1995;26(1):18-25. Full-text exclusion reason(s): All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 7797748].
Dahan M, Viron BM, Poiseau E, et al. Combined dipyridamole-exercise stress echocardiography for detection of myocardial ischemia in hemodialysis patients: an alternative to stress nuclear imaging. Am J Kidney Dis. 2002;40(4):737-44. Full-text exclusion reason(s): No women with symptomatic chest pain, or results are not reported separately for symptomatic subgroup; Data for women not reported as a subgroup. [pmid: 12324908].
Daimon M, Watanabe H, Yamagishi H, et al. Physiologic assessment of coronary artery stenosis without stress tests: noninvasive analysis of phasic flow characteristics by transthoracic Doppler echocardiography. J Am Soc Echocardiogr. 2005;18(9):949-55. Full-text exclusion reason(s): No data for NITs of interest (ECG, ECHO, SPECT, PET, CMR, CTA). [pmid: 16153520].
Daimon M, Watanabe H, Yamagishi H, et al. Physiologic assessment of coronary artery stenosis by coronary flow reserve measurements with transthoracic Doppler echocardiography: comparison with exercise thallium-201 single piston emission computed tomography. J Am Coll Cardiol. 2001;37(5):1310-5. Full-text exclusion reason(s): All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 11300440].
Dal Porto R, Faletra F, Picano E, et al. Safety, feasibility, and diagnostic accuracy of accelerated high-dose dipyridamole stress echocardiography. Am J Cardiol. 2001;87(5):520-4. Full-text exclusion reason(s): All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 11230832].
Danciu SC, Herrera CJ, Stecy PJ, et al. Usefulness of multislice computed tomographic coronary angiography to identify patients with abnormal myocardial perfusion stress in whom diagnostic catheterization may be safely avoided. Am J Cardiol. 2007;100(11):1605-8. Full-text exclusion reason(s): All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 18036355].
Danias PG, Ahlberg AW, Travin MI, et al. Visual assessment of left ventricular perfusion and function with electrocardiography-gated SPECT has high intraobserver and interobserver reproducibility among experienced nuclear cardiologists and cardiology trainees. J Nucl Cardiol. 2002;9(3):263-70. Full-text exclusion reason(s): Study does not compare one NIT to another or to diagnostic cardiac catheterization; No outcomes of interest. [pmid: 12032474].
Daou D, Delahaye N, Vilain D, et al. Identification of extensive coronary artery disease: incremental value of exercise Tl-201 SPECT to clinical and stress test variables. J Nucl Cardiol. 2002;9(2):161-8. Full-text exclusion reason(s): All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 11986560].
Daoud EG, Pitt A, Armstrong WF. Electrocardiographic response during dobutamine stress echocardiography. Am Heart J. 1995;129(4):672-7. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 7900616].
Dart J, Yuda S, Cain P, et al. Use of myocardial backscatter as a quantitative tool for dobutamine echocardiography: feasibility, response to ischemia and accuracy compared with coronary angiography. Int J Cardiovasc Imaging. 2002;18(5):325-36. Full-text exclusion reason(s): All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 12194671].
Dash H, Massie BM, Botvinick EH, et al. The noninvasive identification of left main and three-vessel coronary artery disease by myocardial stress perfusion scintigraphy and treadmill exercise electrocardiography. Circulation. 1979;60(2):276-84. Full-text exclusion reason(s): All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 445745].
Dattilo G, Patane S, Zito C, et al. Handgrip exercise associated with dobutamine stress echocardiography. Int J Cardiol. 2010;143(3):298-301. Full-text exclusion reason(s): Study does not compare one NIT to another or to diagnostic cardiac catheterization; Data for women not reported as a subgroup; No outcomes of interest. [pmid: 19336270].
Daugherty SL, Peterson PN, Magid DJ, et al. The relationship between gender and clinical management after exercise stress testing. Am Heart J. 2008;156(2):301-7. Full-text exclusion reason(s): Study does not compare one NIT to another or to diagnostic cardiac catheterization. [pmid: 18657660].
Davar J, Roberts EB, Coghlan JG, et al. Pacing-dobutamine stress echocardiography is a method of choice for non-invasive diagnosis of coronary artery disease in selected patients. Eurecho 4, Lisbon (Portugal). 6–9 Dec 2000. (World Meeting Number 000 5377). 2000. Full-text exclusion reason(s): Conference abstract or trial registry posting.
Davin L, Lancellotti P, Bruyere PJ, et al. Diagnostic accuracy of computed tomography coronary angiography in routine practice. Acta Cardiol. 2007;62(4):339-44. Full-text exclusion reason(s): No women with symptomatic chest pain, or results are not reported separately for symptomatic subgroup; Data for women not reported as a subgroup. [pmid: 17824293].
Dawson D, Kaul S, Peters D, et al. Prognostic value of dipyridamole stress myocardial contrast echocardiography: comparison with single photon emission computed tomography. J Am Soc Echocardiogr. 2009;22(8):954-60. Full-text exclusion reason(s): No women with symptomatic chest pain, or results are not reported separately for symptomatic subgroup; All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 19553084].
Dawson D, Rinkevich D, Belcik T, et al. Measurement of myocardial blood flow velocity reserve with myocardial contrast echocardiography in patients with suspected coronary artery disease: comparison with quantitative gated Technetium 99m sestamibi single photon emission computed tomography. J Am Soc Echocardiogr. 2003;16(11):1171-7. Full-text exclusion reason(s): All women in the study are known to have CAD; Data for women not reported as a subgroup; No outcomes of interest. [pmid: 14608289].
de Albuquerque Fonseca L, Picano E. Comparison of dipyridamole and exercise stress echocardiography for detection of coronary artery disease (a meta-analysis). Am J Cardiol. 2001;87(10):1193-6. A4. Full-text exclusion reason(s): Not original peer-reviewed data or a secondary analysis of RCT, prospective or retrospective observational study, or registry. [pmid: 11356397].
De Almeida MC, Markman Filho B. Prognostic value of dipyridamole stress echocardiography in women. Arq Bras Cardiol. 2011;96(1):31-37. Full-text exclusion reason(s): Study does not compare one NIT to another or to diagnostic cardiac catheterization. [pmid: 21109908].
De Bello V, Bellina CR, Molea N, et al. Simultaneous dobutamine stress echocardiography and dobutamine scintigraphy (99mTc-MIBI-SPET) for assessment of coronary artery disease. Int J Card Imaging. 1996;12(3):185-90. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 8915719].
de Feyter PJ. Can multislice CT detect coronary artery disease accurately?. Nat Clin Pract Cardiovasc Med. 2005;2(11):560-1. Full-text exclusion reason(s): Full-text unobtainable. [pmid: 16258564].
de Graaf FR, Schuijf JD, Scholte AJ, et al. Usefulness of hypertriglyceridemic waist phenotype in type 2 diabetes mellitus to predict the presence of coronary artery disease as assessed by computed tomographic coronary angiography. Am J Cardiol. 2010;106(12):1747-53. Full-text exclusion reason(s): Study does not compare one NIT to another or to diagnostic cardiac catheterization; Data for women not reported as a subgroup. [pmid: 21126619].
De Graaf FR, Schuijf JD, Van Velzen JE, et al. Diagnostic accuracy of 320-row multidetector computed tomography coronary angiography in the non-invasive evaluation of significant coronary artery disease. Euro Heart J. 2010;31(15):1908-1915. Full-text exclusion reason(s): All women in the study are known to have CAD; Data for women not reported as a subgroup.
De Graaf FR, Schuijf JD, Van Velzen JE, et al. Assessment of global left ventricular function and volumes with 320-row multidetector computed tomography: A comparison with 2D-echocardiography. J Nucl Cardiol. 2010;17(2):225-231. Full-text exclusion reason(s): All women in the study are known to have CAD; Data for women not reported as a subgroup; No outcomes of interest. [pmid: 19953354].
de Leon G, Aguade-Bruix S, Aliaga V, et al. Submaximal exercise testing plus atropine in myocardial perfusion SPECT. Rev Esp Cardiol. 2010;63(10):1155-61. Full-text exclusion reason(s): Study does not compare one NIT to another or to diagnostic cardiac catheterization; Data for women not reported as a subgroup. [pmid: 20875355].
De Lima JJ, Sabbaga E, Vieira ML, et al. Coronary angiography is the best predictor of events in renal transplant candidates compared with noninvasive testing. Hypertension. 2003;42(3):263-8. Full-text exclusion reason(s): No women with symptomatic chest pain, or results are not reported separately for symptomatic subgroup; All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 12913060].
De Lorenzo A, Hachamovitch R, Kang X, et al. Prognostic value of myocardial perfusion SPECT versus exercise electrocardiography in patients with ST-segment depression on resting electrocardiography. J Nucl Cardiol. 2005;12(6):655-61. Full-text exclusion reason(s): No women with symptomatic chest pain, or results are not reported separately for symptomatic subgroup; All women in the study are known to have CAD; Data for women not reported as a subgroup; No outcomes of interest. [pmid: 16344227].
de Vries J, DeJongste MJ, Jessurun GA, et al. Myocardial perfusion quantification in patients suspected of cardiac syndrome X with positive and negative exercise testing: a [13N]ammonia positron emission tomography study. Nucl Med Commun. 2006;27(10):791-4. Full-text exclusion reason(s): Data for women not reported as a subgroup; No outcomes of interest. [pmid: 16969261].
De Vries ST, Kleijn SA, Van THAW J, et al. Impact of high altitude on echocardiographically determined cardiac morphology and function in patients with coronary artery disease and healthy controls. European Journal of Echocardiography. 2010;11(5):446-450. Full-text exclusion reason(s): No women with symptomatic chest pain, or results are not reported separately for symptomatic subgroup; All women in the study are known to have CAD; Study does not compare one NIT to another or to diagnostic cardiac catheterization; Data for women not reported as a subgroup; No outcomes of interest. [pmid: 20139441].
DeCara JM. Noninvasive cardiac testing in women. J Am Med Womens Assoc. 2003;58(4):254-63. Full-text exclusion reason(s): Not original peer-reviewed data or a secondary analysis of RCT, prospective or retrospective observational study, or registry. [pmid: 14640257].
Deetjen A, Mollmann S, Conradi G, et al. Use of automatic exposure control in multislice computed tomography of the coronaries: comparison of 16-slice and 64-slice scanner data with conventional coronary angiography. Heart. 2007;93(9):1040-3. Full-text exclusion reason(s): No women with symptomatic chest pain, or results are not reported separately for symptomatic subgroup; All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 17395667].
Deetjen AG, Conradi G, Mollmann S, et al. Diagnostic value of the 16-detector row multislice spiral computed tomography for the detection of coronary artery stenosis in comparison to invasive coronary angiography. Clin Cardiol. 2007;30(3):118-23. Full-text exclusion reason(s): No outcomes of interest. [pmid: 17385719].
deFilippi CR, Rosanio S, Tocchi M, et al. Randomized comparison of a strategy of predischarge coronary angiography versus exercise testing in low-risk patients in a chest pain unit: in-hospital and long-term outcomes. J Am Coll Cardiol. 2001;37(8):2042-9. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 11419885].
Del Val Gomez M, Gallardo FG, Salazar ML, et al. Prognostic value of normal myocardial radionuclide scan in patients with positive treadmill test. Rev Esp Cardiol. 2002;55(9):991-4. Full-text exclusion reason(s): Non-English. [pmid: 12236930].
Delcour KS, Khaja A, Chockalingam A, et al. Outcomes in patients with abnormal myocardial perfusion imaging and normal coronary angiogram. Angiology. 2009;60(3):318-21. Full-text exclusion reason(s): Population does not include women ≥ age 18. [pmid: 18796451].
Demer LL, Gould KL, Goldstein RA, et al. Assessment of coronary artery disease severity by positron emission tomography. Comparison with quantitative arteriography in 193 patients. Circulation. 1989;79(4):825-35. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 2784361].
Demir H, Erbay G, Kir KM, et al. Clinical validation of technetium-99m MIBI-gated single-photon emission computed tomography (SPECT) for avoiding false positive results in patients with left bundle-branch block: comparison with stress-rest nongated SPECT. Clin Cardiol. 2003;26(4):182-7. Full-text exclusion reason(s): No women with symptomatic chest pain, or results are not reported separately for symptomatic subgroup; Data for women not reported as a subgroup; No outcomes of interest. [pmid: 12708625].
Dendukuri N, Chiu K, Brophy JM. Validity of electron beam computed tomography for coronary artery disease: asystematic review and meta-analysis. BMC Med. 2007;5:35. Full-text exclusion reason(s): Not original peer-reviewed data or a secondary analysis of RCT, prospective or retrospective observational study, or registry. [pmid: 18036252].
DePuey EG, Guertler-Krawczynska E, D’Amato PH. Thallium-201 single photon emission computed tomography with intravenous dipyridamole to diagnose coronary artery disease. Coron Artery Dis. 1990:75-82. Full-text exclusion reason(s): Data for women not reported as a subgroup.
Derumeaux G, Redonnet M, Mouton-Schleifer D, et al. Dobutamine stress echocardiography in orthotopic heart transplant recipients. VACOMED Research Group. J Am Coll Cardiol. 1995;25(7):1665-72. Full-text exclusion reason(s): No women with symptomatic chest pain, or results are not reported separately for symptomatic subgroup; Data for women not reported as a subgroup. [pmid: 7759721].
Detrano R, Gianrossi R, Froelicher V. The diagnostic accuracy of the exercise electrocardiogram: a meta-analysis of 22 years of research. Prog Cardiovasc Dis. 1989;32(3):173-206. Full-text exclusion reason(s): Not original peer-reviewed data or a secondary analysis of RCT, prospective or retrospective observational study, or registry. [pmid: 2530605].
Detrano R, Hsiai T, Wang S, et al. Prognostic value of coronary calcification and angiographic stenoses in patients undergoing coronary angiography. J Am Coll Cardiol. 1996;27(2):285-90. Full-text exclusion reason(s): No data for NITs of interest (ECG, ECHO, SPECT, PET, CMR, CTA). [pmid: 8557895].
Deutsch HJ, Schenkel C, Klaer R, et al. Comparison of ergometer and dipyridamole echocardiography in patients with suspected coronary heart disease. Z Kardiol. 1994;83(6):446-53. Full-text exclusion reason(s): Non-English. [pmid: 8067047].
Dewey M, Dubel HP, Schink T, et al. Head-to-head comparison of multislice computed tomography and exercise electrocardiography for diagnosis of coronary artery disease. Eur Heart J. 2007;28(20):2485-90. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 16880194].
Dewey M, Hamm B. Cost effectiveness of coronary angiography and calcium scoring using CT and stress MRI for diagnosis of coronary artery disease. Eur Radiol. 2007;17(5):1301-9. Full-text exclusion reason(s): Not a clinical study report. [pmid: 17031453].
Dewey M, Rutsch W, Schnapauff D, et al. Coronary artery stenosis quantification using multislice computed tomography. Invest Radiol. 2007;42(2):78-84. Full-text exclusion reason(s): No women with symptomatic chest pain, or results are not reported separately for symptomatic subgroup; All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 17220725].
Dewey M, Schnapauff D, Laule M, et al. Multislice CT coronary angiography: evaluation of an automatic vessel detection tool. Rofo. 2004;176(4):478-83. Full-text exclusion reason(s): No women with symptomatic chest pain, or results are not reported separately for symptomatic subgroup; Data for women not reported as a subgroup; No outcomes of interest. [pmid: 15088170].
Dewey M, Teige F, Rutsch W, et al. CT coronary angiography: influence of different cardiac reconstruction intervals on image quality and diagnostic accuracy. Eur J Radiol. 2008;67(1):92-9. Full-text exclusion reason(s): No women with symptomatic chest pain, or results are not reported separately for symptomatic subgroup; Data for women not reported as a subgroup. [pmid: 17766074].
Dewey M, Zimmermann E, Deissenrieder F, et al. Noninvasive coronary angiography by 320-row computed tomography with lower radiation exposure and maintained diagnostic accuracy: comparison of results with cardiac catheterization in a head-to-head pilot investigation. Circulation. 2009;120(10):867-75. Full-text exclusion reason(s): No women with symptomatic chest pain, or results are not reported separately for symptomatic subgroup; Data for women not reported as a subgroup. [pmid: 19704093].
Di Bello V, Bellina CR, Gori E, et al. Incremental diagnostic value of dobutamine stress echocardiography and dobutamine scintigraphy (technetium 99m-labeled sestamibi single-photon emission computed tomography) for assessment of presence and extent of coronary artery disease. J Nucl Cardiol. 1996;3(3):212-20. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 8805741].
Di Bello V, Bellina CR, Molea N, et al. Simultaneous dobutamine stress echocardiography and dobutamine scintigraphy (99mTc-MIBI-SPET) for assessment of coronary artery disease. Int J Card Imaging. 1996;12(3):185-90. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 8915719].
Di Carli MF, Dorbala S, Cardiac PET-CT. J Thorac Imaging. 2007;22(1):101-106. Full-text exclusion reason(s): Not original peer-reviewed data or a secondary analysis of RCT, prospective or retrospective observational study, or registry. [pmid: 17325581].
Di Carli MF, Dorbala S, Curillova Z, et al. Relationship between CT coronary angiography and stress perfusion imaging in patients with suspected ischemic heart disease assessed by integrated PET-CT imaging. J Nucl Cardiol. 2007;14(6):799-809. Full-text exclusion reason(s): No women with symptomatic chest pain, or results are not reported separately for symptomatic subgroup; Data for women not reported as a subgroup. [pmid: 18022106].
Di Cesare E, Battisti S, Riva A, et al. Parallel imaging and dobutamine stress magnetic resonance imaging in patients with atypical chest pain or equivocal ECG not suitable for stress echocardiography. Radiol Med. 2009;114(2):216-28. Full-text exclusion reason(s): No women with symptomatic chest pain, or results are not reported separately for symptomatic subgroup; All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 19266261].
Di Pasquale P, Cannizzaro S, Scalzo S, et al. Sensitivity, specificity and predictive value of the echocardiography and troponin-T test combination in patients with non-ST elevation acute coronary syndromes. Int J Cardiovasc Imaging. 2004;20(1):37-46. Full-text exclusion reason(s): Study does not compare one NIT to another or to diagnostic cardiac catheterization; Data for women not reported as a subgroup; No outcomes of interest. [pmid: 15055819].
Di Pasquale P, Paterna S. Utility of the combination of echocardiography and troponin T test in patients with ST segment depression. HeartDrug. 2002;2(6):279-285. Full-text exclusion reason(s): Data for women not reported as a subgroup.
Diederichsen AC, Petersen H, Jensen LO, et al. Diagnostic value of cardiac 64-slice computed tomography: importance of coronary calcium. Scand Cardiovasc J. 2009;43(5):337-44. Full-text exclusion reason(s): No women with symptomatic chest pain, or results are not reported separately for symptomatic subgroup; All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 19266395].
Diederichsen ACP, Petersen H, Jensen LO, et al. Diagnostic value of cardiac 64-slice computed tomography: Importance of coronary calcium. Scand Cardiovasc J. 2009;43(5):337-344. Full-text exclusion reason(s): No women with symptomatic chest pain, or results are not reported separately for symptomatic subgroup; All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 19266395].
Dill T, Deetjen A, Ekinci O, et al. Radiation dose exposure in multislice computed tomography of the coronaries in comparison with conventional coronary angiography. Int J Cardiol. 2008;124(3):307-11. Full-text exclusion reason(s): No women with symptomatic chest pain, or results are not reported separately for symptomatic subgroup; All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 17408786].
Dirksen MS, Jukema JW, Bax JJ, et al. Cardiac multidetector-row computed tomography in patients with unstable angina. Am J Cardiol. 2005;95(4):457-61. Full-text exclusion reason(s): No women with symptomatic chest pain, or results are not reported separately for symptomatic subgroup; All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 15695128].
Djordjevic-Dikic AD, Ostojic MC, Beleslin BD, et al. High dose adenosine stress echocardiography for noninvasive detection of coronary artery disease. J Am Coll Cardiol. 1996;28(7):1689-95. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 8962553].
Dodd JD, Rieber J, Pomerantsev E, et al. Quantification of nonculprit coronary lesions: comparison of cardiac 64-MDCT and invasive coronary angiography. AJR Am J Roentgenol. 2008;191(2):432-8. Full-text exclusion reason(s): All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 18647913].
Dodla S, Xie F, Smith M, et al. Real-time perfusion echocardiography during treadmill exercise and dobutamine stress testing. Heart. 2010;96(3):220-5. Full-text exclusion reason(s): Study does not compare one NIT to another or to diagnostic cardiac catheterization; Data for women not reported as a subgroup. [pmid: 19713202].
Doesch C, Seeger A, Hoevelborn T, et al. Adenosine stress cardiac magnetic resonance imaging for the assessment of ischemic heart disease. Clin Res Cardiol. 2008;97(12):905-12. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 18777000].
Dolan MS, Riad K, El-Shafei A, et al. Effect of intravenous contrast for left ventricular opacification and border definition on sensitivity and specificity of dobutamine stress echocardiography compared with coronary angiography in technically difficult patients. Am Heart J. 2001;142(5):908-15. Full-text exclusion reason(s): No women with symptomatic chest pain, or results are not reported separately for symptomatic subgroup; All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 11685180].
Donati OF, Scheffel H, Stolzmann P, et al. Combined cardiac CT and MRI for the comprehensive workup of hemodynamically relevant coronary stenoses. AJR Am J Roentgenol. 2010;194(4):920-6. Full-text exclusion reason(s): All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 20308492].
Dong S, Liang X, Zhang S, et al. Assessment of coronary artery disease with second harmonic myocardial perfusion contrast echocardiography. Chin Med J (Engl). 2002;115(6):837-41. Full-text exclusion reason(s): All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 12123548].
Dorgelo J, Willems TP, Geluk CA, et al. Multidetector computed tomography-guided treatment strategy in patients with non-ST elevation acute coronary syndromes: a pilot study. Eur Radiol. 2005;15(4):708-13. Full-text exclusion reason(s): All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 15449001].
Dou KF, Yang MF, Yang YJ, et al. Myocardial 18F-FDG uptake after exercise-induced myocardial ischemia in patients with coronary artery disease. J Nucl Med. 2008;49(12):1986-91. Full-text exclusion reason(s): All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 18997035].
Douglas PS, Garcia MJ, Haines DE, et al. ACCF/ASE/AHA/ASNC/HFSA/HRS/SCAI/SCCM/SCCT/SCMR 2011 Appropriate Use Criteria for Echocardiography A Report of the American College of Cardiology Foundation Appropriate Use Criteria Task Force, American Society of Echocardiography, American Heart Association American Society of Nuclear Cardiology, Heart Failure Society of America, Heart Rhythm Society, Society for Cardiovascular Angiography and Interventions, Society of Critical Care Medicine, Society of Cardiovascular Computed Tomography, and Society for Cardiovascular Magnetic Resonance Endorsed by the American College of Chest Physicians. J Am Coll Cardiol. 2011;57(9):1126-66. Full-text exclusion reason(s): Not a clinical study report. [pmid: 21349406].
Downs SH, Black N. The feasibility of creating a checklist for the assessment of the methodological quality both of randomised and non-randomised studies of health care interventions. Journal of Epidemiology and Community Health. 1998;52(6):377-84. Full-text exclusion reason(s): No data for NITs of interest (ECG, ECHO, SPECT, PET, CMR, CTA). [pmid: 9764259].
Dragu R, Kerner A, Gruberg L, et al. Angiographically uncertain left main coronary artery narrowings: correlation with multidetector computed tomography and intravascular ultrasound. Int J Cardiovasc Imaging. 2008;24(5):557-63. Full-text exclusion reason(s): All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 18165931].
Dragu R, Rispler S, Ghersin E, et al. Contrast enhanced multi-detector computed tomography coronary angiography versus conventional invasive quantitative coronary angiography in acute coronary syndrome patients-correlation and bias. Acute Card Care. 2006;8(2):99-104. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 16885074].
Drosch T, Tsiflikas I, Brodoefel H, et al. Semi-automatic assessment of global left ventricular function and left ventricular parameters with dual-source computed tomography: comparison with invasive angiography. Heart Vessels. 2010;25(1):57-62. Full-text exclusion reason(s): No women with symptomatic chest pain, or results are not reported separately for symptomatic subgroup; All women in the study are known to have CAD; Data for women not reported as a subgroup; No outcomes of interest. [pmid: 20091400].
Duarte PS, Mastrocolla LE, Sampaio CR, et al. Indication of myocardial perfusion scintigraphy for coronary artery disease detection based on clinical-epidemiological and treadmill test evidences. Arq Bras Cardiol. 2006;87(4):415-22. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 17128309].
Duarte R, Bettencourt N, Costa JC, et al. Coronary computed tomography angiography in a single cardiac cycle with a mean radiation dose of approximately 1 mSv: initial experience. Rev Port Cardiol. 2010;29(11):1667-76. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 21309356].
Dubart AE, Carvalho da Silva KG Jr, Korosoglou G, et al. Real-time myocardial contrast echocardiography for the detection of stress-induced myocardial ischemia. Comparison with 99mTc-sestamibi single photon emission computed tomography. Z Kardiol. 2004;93(11):890-6. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 15568149].
Dunn RF, Kelly DT, Bailey IK, et al. Serial exercise thallium myocardial perfusion scanning and exercise electrocardiography in the diagnosis of coronary artery disease. Aust N Z J Med. 1979;9(5):547-53. Full-text exclusion reason(s): All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 294910].
Duvall WL, Croft LB, Corriel JS, et al. SPECT myocardial perfusion imaging in morbidly obese patients: image quality, hemodynamic response to pharmacologic stress, and diagnostic and prognostic value. J Nucl Cardiol. 2006;13(2):202-9. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 16580956].
Ebersole DG, Heironimus J, Toney MO, et al. Comparison of exercise and adenosine technetium-99m sestamibi myocardial scintigraphy for diagnosis of coronary artery disease in patients with left bundle branch block. Am J Cardiol. 1993;71(5):450-3. Full-text exclusion reason(s): No women with symptomatic chest pain, or results are not reported separately for symptomatic subgroup; Data for women not reported as a subgroup. [pmid: 8430639].
Eek C, Grenne B, Brunvand H, et al. Strain echocardiography predicts acute coronary occlusion in patients with non-ST-segment elevation acute coronary syndrome. European Journal of Echocardiography. 2010;11(6):501-508. Full-text exclusion reason(s): All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 20185525].
Egger M, Juni P, Bartlett C, et al. How important are comprehensive literature searches and the assessment of trial quality in systematic reviews? Empirical study. Health Technol Assess. 2003;7(1):1-76. Full-text exclusion reason(s): Not original peer-reviewed data or a secondary analysis of RCT, prospective or retrospective observational study, or registry. [pmid: 12583822].
Ehara M, Surmely JF, Kawai M, et al. Diagnostic accuracy of 64-slice computed tomography for detecting angiographically significant coronary artery stenosis in an unselected consecutive patient population: comparison with conventional invasive angiography. Circ J. 2006;70(5):564-71. Full-text exclusion reason(s): No women with symptomatic chest pain, or results are not reported separately for symptomatic subgroup; All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 16636491].
Eisenberg MJ, Afilalo J, Lawler PR, et al. Cancer risk related to low-dose ionizing radiation from cardiac imaging in patients after acute myocardial infarction. CMAJ. 2011;183(4):430-6. Full-text exclusion reason(s): All women in the study are known to have CAD. [pmid: 21324846].
Elamin MS, Boyle R, Kardash MM, et al. Accurate detection of coronary heart disease by new exercise test. Br Heart J. 1982;48(4):311-20. Full-text exclusion reason(s): All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 6127094].
Elhendy A, Bax JJ, van Domburg RT, et al. Dobutamine stress thallium-201 single-photon emission tomography versus echocardiography for evaluation of the extent and location of coronary artery disease late after myocardial infarction. Eur J Nucl Med. 1999;26(5):467-73. Full-text exclusion reason(s): All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 10382089].
Elhendy A, Geleijnse L, Salustri A, et al. T wave normalization during dobutamine stress testing in patients with non-Q wave myocardial infarction. A marker of myocardial ischaemia?. Eur Heart J. 1996;17(4):526-31. Full-text exclusion reason(s): All women in the study are known to have CAD. [pmid: 8733084].
Elhendy A, Geleijnse ML, Roelandt JR, et al. Comparison of dobutamine stress echocardiography and 99m-technetium sestamibi SPECT myocardial perfusion scintigraphy for predicting extent of coronary artery disease in patients with healed myocardial infarction. Am J Cardiol. 1997;79(1):7-12. Full-text exclusion reason(s): All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 9024727].
Elhendy A, Geleijnse ML, van Domburg RT, et al. Comparison of dobutamine stress echocardiography and technetium-99m sestamibi single-photon emission tomography for the diagnosis of coronary artery disease in hypertensive patients with and without left ventricular hypertrophy. Eur J Nucl Med. 1998;25(1):69-78. Full-text exclusion reason(s): All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 9396877].
Elhendy A, O’Leary EL, Xie F, et al. Comparative accuracy of real-time myocardial contrast perfusion imaging and wall motion analysis during dobutamine stress echocardiography for the diagnosis of coronary artery disease. J Am Coll Cardiol. 2004;44(11):2185-91. Full-text exclusion reason(s): No women with symptomatic chest pain, or results are not reported separately for symptomatic subgroup; All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 15582317].
Elhendy A, Roelandt J, Geleijnse ML, et al. Non-invasive diagnosis of coronary artery disease in hypertensive patients. Comparison of dobutamine stress echocardiography and technetium sestamibi SPECT imaging. XIXth Congress of the European Society of Cardiology. Stockholm (Sweden). 24–28 August 1997. (World Meeting Number 973 0006). 1997.
Elhendy A, van Domburg RT, Bax JJ, et al. Optimal criteria for the diagnosis of coronary artery disease by dobutamine stress echocardiography. Am J Cardiol. 1998;82(11):1339-44. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 9856916].
Elhendy A, van Domburg RT, Bax JJ, et al. Accuracy of dobutamine technetium 99m sestamibi SPECT imaging for the diagnosis of single-vessel coronary artery disease: comparison with echocardiography. Am Heart J. 2000;139(2 Pt 1):224-30. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 10650294].
Elhendy A, van Domburg RT, Bax JJ, et al. Significance of resting wall motion abnormalities in 2-dimensional echocardiography in patients without previous myocardial infarction referred for pharmacologic stress testing. J Am Soc Echocardiogr. 2000;13(1):1-8. Full-text exclusion reason(s): Data for women not reported as a subgroup; No outcomes of interest. [pmid: 10625825].
Elhendy A, van Domburg RT, Poldermans D, et al. Safety and feasibility of dobutamine-atropine stress echocardiography for the diagnosis of coronary artery disease in diabetic patients unable to perform an exercise stress test. Diabetes Care. 1998;21(11):1797-802. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 9802723].
Elhendy A, van Domburg RT, Roelandt JR, et al. Safety and feasibility of dobutamine-atropine stress testing in hypertensive patients. Hypertension. 1997;29(6):1232-9. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 9180623].
Elhendy A, van Domburg RT, Sozzi FB, et al. Impact of hypertension on the accuracy of exercise stress myocardial perfusion imaging for the diagnosis of coronary artery disease. Heart. 2001;85(6):655-61. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 11359747].
Elhendy A, yan Domburg RT, Roelandt JR, et al. Accuracy of dobutamine stress echocardiography for the diagnosis of coronary artery stenosis in patients with myocardial infarction: the impact of extent and severity of left ventricular dysfunction. Heart. 1996;76(2):123-8. Full-text exclusion reason(s): All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 8795473].
Ellestad MH, Crump R, Surber M. The significance of lead strength on ST changes during treadmill stress tests. J Electrocardiol. 1992;25(Suppl):31-4. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 1297705].
El-Mahalawy N, Abdel-Salam Z, Samir A, et al. Left ventricular transient ischemic dilation during dobutamine stress echocardiography predicts multi-vessel coronary artery disease. J Cardiol. 2009;54(2):255-61. Full-text exclusion reason(s): All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 19782263].
Emre A, Ersek B, Gursurer M, et al. Angiographic and scintigraphic (perfusion and electrocardiogram-gated SPECT) correlates of clinical presentation in unstable angina. Clin Cardiol. 2000;23(7):495-500. Full-text exclusion reason(s): All women in the study are known to have CAD; Data for women not reported as a subgroup; No outcomes of interest. [pmid: 10894437].
Epstein M, Gin K, Sterns L, et al. Dobutamine stress echocardiography: initial experience of a Canadian centre. Can J Cardiol. 1992;8(3):273-9. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 1576561].
Erbel R, Budde T, Kerkhoff G, et al. Understanding the pathophysiology of the arterial wall: Which method should we choose? Electron beam computed tomography. Euro Heart J. 2002;4(6). Full-text exclusion reason(s): Not original peer-reviewed data or a secondary analysis of RCT, prospective or retrospective observational study, or registry.
Erdogan N, Akar N, Vural M, et al. Diagnostic value of 16-slice multidetector computed tomography in symptomatic patients with suspected significant obstructive coronary artery disease. Heart Vessels. 2006;21(5):278-84. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 17151814].
Eren S, Bayram E, Fil F, et al. An investigation of the association between coronary artery dominance and coronary artery variations with coronary arterial disease by multidetector computed tomographic coronary angiography. J Comput Assist Tomogr. 2008;32(6):929-33. Full-text exclusion reason(s): No women with symptomatic chest pain, or results are not reported separately for symptomatic subgroup; Study does not compare one NIT to another or to diagnostic cardiac catheterization; Data for women not reported as a subgroup; No outcomes of interest. [pmid: 19204457].
Erhard I, Rieber J, Jung P, et al. The validation of fractional flow reserve in patients with coronary multivessel disease: a comparison with SPECT and contrast-enhanced dobutamine stress echocardiography. Z Kardiol. 2005;94(5):321-7. Full-text exclusion reason(s): All women in the study are known to have CAD; Data for women not reported as a subgroup; No outcomes of interest. [pmid: 15868360].
Eriksson SV. Vectorcardiography: A tool for non-invasive detection of reperfusion and reocclusion?. Thromb Haemost. 1999;82(SUPPL 1):64-67. Full-text exclusion reason(s): Not original peer-reviewed data or a secondary analysis of RCT, prospective or retrospective observational study, or registry. [pmid: 10695489].
Eroglu E, Bayrak F, Gemici G, et al. Prevalence of coronary artery disease in low to moderate-risk asymptomatic women: a multislice computed tomography study. Turk Kardiyol Dern Ars. 2008;36(7):439-45. Full-text exclusion reason(s): No women with symptomatic chest pain, or results are not reported separately for symptomatic subgroup. [pmid: 19155656].
Eroglu E, D’Hooge J, Herbots L, et al. Comparison of real-time tri-plane and conventional 2D dobutamine stress echocardiography for the assessment of coronary artery disease. Eur Heart J. 2006;27(14):1719-24. Full-text exclusion reason(s): Data for women not reported as a subgroup; No outcomes of interest. [pmid: 16720687].
Eskola MJ, Nikus KC, Holmvang L, et al. Value of the 12-lead electrocardiogram to define the level of obstruction in acute anterior wall myocardial infarction: correlation to coronary angiography and clinical outcome in the DANAMI-2 trial. Int J Cardiol. 2009;(3):378-83. Full-text exclusion reason(s): No data for NITs of interest (ECG, ECHO, SPECT, PET, CMR, CTA). [pmid: 18191483].
Esteves FP, Khan A, Correia LCL, et al. Absent coronary artery calcium excludes inducible myocardial ischemia on computed tomography/positron emission tomography. Int J Cardiol. 2011;147(3):424-427. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 19892417].
Esteves FP, Sanyal R, Nye JA, et al. Adenosine stress rubidium-82 PET/computed tomography in patients with known and suspected coronary artery disease. Nucl Med Commun. 2008;29(8):674-8. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 18753818].
Esteves FP, Sanyal R, Santana CA, et al. Potential impact of noncontrast computed tomography as gatekeeper for myocardial perfusion positron emission tomography in patients admitted to the chest pain unit. Am J Cardiol. 2008;101(2):149-52. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 18178397].
Fallahi B, Beiki D, Fard-Esfahani A, et al. The additive value of transient left ventricular dilation using two-day dipyridamole 99mTc-MIBI SPET for screening coronary artery disease in patients with otherwise normal myocardial perfusion: a comparison between diabetic and non-diabetic cases. Hell J Nucl Med. 2010;13(3):246-52. Full-text exclusion reason(s): Study does not compare one NIT to another or to diagnostic cardiac catheterization; Data for women not reported as a subgroup. [pmid: 21193879].
Fallahi B, Beiki D, Gholamrezanezhad A, et al. Single Tc99m Sestamibi injection, double acquisition gated SPECT after stress and during low-dose dobutamine infusion: a new suggested protocol for evaluation of myocardial perfusion. Int J Cardiovasc Imaging. 2008;24(8):825-35. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 18563624].
Fang XM, Chen HW, Hu XY, et al. Dual-source CT coronary angiography without heart rate or rhythm control in comparison with conventional coronary angiography. Int J Cardiovasc Imaging. 2010;26(3):323-31. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 19888670].
Farzaneh-Far A, Kwong RY. Detecting acute coronary syndromes by magnetic resonance imaging. Heart and Metabolism. 2011;(50):15-19. Full-text exclusion reason(s): Not a clinical study report; Not original peer-reviewed data or a secondary analysis of RCT, prospective or retrospective observational study, or registry; Data for women not reported as a subgroup.
Fazel P, Peterman MA, Schussler JM. Three-year outcomes and cost analysis in patients receiving 64-slice computed tomographic coronary angiography for chest pain. Am J Cardiol. 2009;104(4):498-500. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 19660601].
Feldman C, Vitola D, Schiavo N. Detection of coronary artery disease based on the calcification index obtained by helical computed tomography. Arq Bras Cardiol. 2000;75(6):471-80. Full-text exclusion reason(s): All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 11175472].
Feldman JA, Bernard S, Mitchell P, et al. Effects of cardiology review of the electrocardiogram in patients with suspected acute coronary syndromes. Am J Emerg Med. 2011;29(3):309-15. e2. Full-text exclusion reason(s): Study does not compare one NIT to another or to diagnostic cardiac catheterization; Data for women not reported as a subgroup. [pmid: 21109380].
Felsher J, Meissner MD, Hakki AH, et al. Exercise thallium imaging in patients with diabetes mellitus. Prognostic implications. Arch Intern Med. 1987;147(2):313-7. Full-text exclusion reason(s): Study does not compare one NIT to another or to diagnostic cardiac catheterization; Data for women not reported as a subgroup. [pmid: 3813750].
Fenchel M, Franow A, Martirosian P, et al. 1 M Gd-chelate (gadobutrol) for multislice first-pass magnetic resonance myocardial perfusion imaging. Br J Radiol. 2007;80(959):884-92. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 17875598].
Feola M, Biggi A, Ribichini F, et al. The diagnosis of coronary artery disease in hypertensive patients with chest pain and complete left bundle branch block: utility of adenosine Tc-99m tetrofosmin SPECT. Clin Nucl Med. 2002;27(7):510-5. Full-text exclusion reason(s): No women with symptomatic chest pain, or results are not reported separately for symptomatic subgroup; Data for women not reported as a subgroup. [pmid: 12072779].
Feola M, Biggi A, Vado A, et al. The usefulness of adenosine 99mTc tetrofosmin SPECT for the diagnosis of left anterior descending coronary artery disease in patients with chest pain and left bundle branch block. Nucl Med Commun. 2004;25(3):265-9. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 15094445].
Ferencik M, Nomura CH, Maurovich-Horvat P, et al. Quantitative parameters of image quality in 64-slice computed tomography angiography of the coronary arteries. Eur J Radiol. 2006;57(3):373-9. Full-text exclusion reason(s): No women with symptomatic chest pain, or results are not reported separately for symptomatic subgroup; Study does not compare one NIT to another or to diagnostic cardiac catheterization; Data for women not reported as a subgroup; No outcomes of interest. [pmid: 16439091].
Ferencik M, Ropers D, Abbara S, et al. Diagnostic accuracy of image postprocessing methods for the detection of coronary artery stenoses by using multidetector CT. Radiology. 2007;243(3):696-702. Full-text exclusion reason(s): No women with symptomatic chest pain, or results are not reported separately for symptomatic subgroup; Study does not compare one NIT to another or to diagnostic cardiac catheterization; Data for women not reported as a subgroup; No outcomes of interest. [pmid: 17517929].
Fernandes LP, Tardif JC, Arsenault A, et al. Detection of myocardial perfusion abnormalities after a recent acute coronary syndrome by quantitative Levovist myocardial contrast echocardiography: comparison with 99m Tc-Myoview SPECT imaging. Can J Cardiol. 2003;19(3):251-6. Full-text exclusion reason(s): No women with symptomatic chest pain, or results are not reported separately for symptomatic subgroup; All women in the study are known to have CAD; Study does not compare one NIT to another or to diagnostic cardiac catheterization; Data for women not reported as a subgroup. [pmid: 12677280].
Fernandez-Friera L, Garcia-Alvarez A, Bagheriannejad-Esfahani F, et al. Diagnostic value of coronary artery calcium scoring in low-intermediate risk patients evaluated in the emergency department for acute coronary syndrome. Am J Cardiol. 2011;107(1):17-23. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 21146680].
Ferrara N, Leosco D, Abete P, et al. Dipyridamole echocardiography as a useful and safe test in the assessment of coronary artery disease in the elderly. J Am Geriatr Soc. 1991;39(10):993-9. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 1918787].
Fesmire FM, Hughes AD, Stout PK, et al. Selective dual nuclear scanning in low-risk patients with chest pain to reliably identify and exclude acute coronary syndromes. Ann Emerg Med. 2001;38(3):207-15. Full-text exclusion reason(s): No women with symptomatic chest pain, or results are not reported separately for symptomatic subgroup; All women in the study are known to have CAD; Study does not compare one NIT to another or to diagnostic cardiac catheterization; Data for women not reported as a subgroup. [pmid: 11524638].
Feuchtner G, Postel T, Weidinger F, et al. Is there a relation between non-calcifying coronary plaques and acute coronary syndromes? A retrospective study using multislice computed tomography. Cardiology. 2008;110(4):241-8. Full-text exclusion reason(s): No women with symptomatic chest pain, or results are not reported separately for symptomatic subgroup; All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 18073479].
Feuchtner GM, Cury RC, Jodocy D, et al. Differences in coronary plaque composition by noninvasive computed tomography angiography in individuals with and without obstructive coronary artery disease. Atherosclerosis. 2011;215(1):90-5. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 21227421].
Fine JJ, Hopkins CB, Hall PA, et al. Noninvasive coronary angiography: agreement of multi-slice spiral computed tomography and selective catheter angiography. Int J Cardiovasc Imaging. 2004;20(6):549-52. Full-text exclusion reason(s): No women with symptomatic chest pain, or results are not reported separately for symptomatic subgroup; Data for women not reported as a subgroup. [pmid: 15856641].
Fine JJ, Hopkins CB, Ruff N, et al. Comparison of accuracy of 64-slice cardiovascular computed tomography with coronary angiography in patients with suspected coronary artery disease. Am J Cardiol. 2006;97(2):173-4. Full-text exclusion reason(s): All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 16442357].
Finkelhor RS, Newhouse KE, Vrobel TR, et al. The ST segment/heart rate slope as a predictor of coronary artery disease: comparison with quantitative thallium imaging and conventional ST segment criteria. Am Heart J. 1986;112(2):296-304. Full-text exclusion reason(s): All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 3739881].
Fleischmann KE, Hunink MG, Kuntz KM, et al. Exercise echocardiography or exercise SPECT imaging? A meta-analysis of diagnostic test performance. JAMA. 1998;280(10):913-20. Full-text exclusion reason(s): Not original peer-reviewed data or a secondary analysis of RCT, prospective or retrospective observational study, or registry. [pmid: 9739977].
Fleischmann S, Koepfli P, Namdar M, et al. Gated (99m)Tc-tetrofosmin SPECT for discriminating infarct from artifact in fixed myocardial perfusion defects. J Nucl Med. 2004;45(5):754-9. Full-text exclusion reason(s): No women with symptomatic chest pain, or results are not reported separately for symptomatic subgroup; All women in the study are known to have CAD; Study does not compare one NIT to another or to diagnostic cardiac catheterization; Data for women not reported as a subgroup. [pmid: 15136622].
Fleming RM. High-dose dipyridamole and gated sestamibi SPECT imaging provide diagnostic resting and stress ejection fractions useful for predicting extent of coronary artery disease. Angiology. 2002;53(4):415-21. Full-text exclusion reason(s): No women with symptomatic chest pain, or results are not reported separately for symptomatic subgroup; Study does not compare one NIT to another or to diagnostic cardiac catheterization; Data for women not reported as a subgroup. [pmid: 12143946].
Fleming RM, Kirkeeide RL, Taegtmeyer H, et al. Comparison of technetium-99m teboroxime tomography with automated quantitative coronary arteriography and thallium-201 tomographic imaging. J Am Coll Cardiol. 1991;17(6):1297-302. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 2016447].
Flohr TG, McCollough CH, Bruder H, et al. First performance evaluation of a dual-source CT (DSCT) system. Eur Radiol. 2006;16(2):256-68. Full-text exclusion reason(s): No women with symptomatic chest pain, or results are not reported separately for symptomatic subgroup; Study does not compare one NIT to another or to diagnostic cardiac catheterization; Data for women not reported as a subgroup; No outcomes of interest. [pmid: 16341833].
Flohr TG, Schoepf UJ, Kuettner A, et al. Advances in cardiac imaging with 16-section CT systems. Acad Radiol. 2003;10(4):386-401. Full-text exclusion reason(s): Not a clinical study report. [pmid: 12678178].
Florenciano-Sanchez R, de la Morena-Valenzuela G, Villegas-Garcia M, et al. Noninvasive assessment of coronary flow velocity reserve in left anterior descending artery adds diagnostic value to both clinical variables and dobutamine echocardiography: a study based on clinical practice. Eur J Echocardiogr. 2005;6(4):251-9. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 15992707].
Forberg JL, Hilmersson CE, Carlsson M, et al. Negative predictive value and potential cost savings of acute nuclear myocardial perfusion imaging in low risk patients with suspected acute coronary syndrome: a prospective single blinded study. BMC Emerg Med. 2009;9:12. Full-text exclusion reason(s): Study does not compare one NIT to another or to diagnostic cardiac catheterization; Data for women not reported as a subgroup. [pmid: 19545365].
Forster S, Rieber J, Ubleis C, et al. Tc-99m sestamibi single photon emission computed tomography for guiding percutaneous coronary intervention in patients with multivessel disease: a comparison with quantitative coronary angiography and fractional flow reserve. Int J Cardiovasc Imaging. 2010;26(2):203-13. Full-text exclusion reason(s): All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 19760091].
Forster T, McNeill AJ, Salustri A, et al. Simultaneous dobutamine stress echocardiography and technetium-99m isonitrile single-photon emission computed tomography in patients with suspected coronary artery disease. J Am Coll Cardiol. 1993;21(7):1591-6. Full-text exclusion reason(s): All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 8496524].
Fragasso G, Lu C, Dabrowski P, et al. Comparison of stress/rest myocardial perfusion tomography, dipyridamole and dobutamine stress echocardiography for the detection of coronary disease in hypertensive patients with chest pain and positive exercise test. J Am Coll Cardiol. 1999;34(2):441-7. Full-text exclusion reason(s): All women in the study are known to have CAD. [pmid: 10440157].
Freedman N, Schechter D, Klein M, et al. SPECT attenuation artifacts in normal and overweight persons: insights from a retrospective comparison of Rb-82 positron emission tomography and TI-201 SPECT myocardial perfusion imaging. Clin Nucl Med. 2000;25(12):1019-23. Full-text exclusion reason(s): No women with symptomatic chest pain, or results are not reported separately for symptomatic subgroup. [pmid: 11129138].
Freeman JA, Corbin M, Dunn M, et al. Correlation of single lead telemetric treadmill exercise testing with coronary angiography. J Electrocardiol. 1973;6(3):231-4. Full-text exclusion reason(s): All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 4727907].
Frohwein S, Klein JL, Lane A, et al. Transesophageal dobutamine stress echocardiography in the evaluation of coronary artery disease. J Am Coll Cardiol. 1995;25(4):823-9. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 7884083].
From AM, Kane G, Bruce C, et al. Characteristics and outcomes of patients with abnormal stress echocardiograms and angiographically mild coronary artery disease (<50% stenoses) or normal coronary arteries. J Am Soc Echocardiogr. 2010;23(2):207-14. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 20152703].
Fujitaka K, Nakamura S, Sugiura T, et al. Combined analysis of multislice computed tomography coronary angiography and stress-rest myocardial perfusion imaging in detecting patients with significant proximal coronary artery stenosis. Nucl Med Commun. 2009;30(10):789-96. Full-text exclusion reason(s): All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 19641477].
Fukai T, Koyanagi S, Tashiro H, et al. Adenosine triphosphate stress echocardiography in the detection of myocardial ischemia. Am J Card Imaging. 1995;9(4):237-44. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 8680139].
Fukuoka S, Maeno M, Nakagawa S, et al. Feasibility of myocardial dual-isotope perfusion imaging combined with gated single photon emission tomography for assessing coronary artery disease. Nucl Med Commun. 2002;23(1):19-29. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 11748434].
Futamatsu H, Klassen C, Pilla M, et al. Diagnostic accuracy of quantitative cardiac MRI evaluation compared to stress single-photon-emission computed tomography. Int J Cardiovasc Imaging. 2008;24(3):293-9. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 17849235].
Futamatsu H, Wilke N, Klassen C, et al. Evaluation of cardiac magnetic resonance imaging parameters to detect anatomically and hemodynamically significant coronary artery disease. Am Heart J. 2007;154(2):298-305. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 17643580].
Gaddi O, Tortorella G, Picano E, et al. Diagnostic and prognostic value of vasodilator stress echocardiography in asymptomatic Type 2 diabetic patients with positive exercise thallium scintigraphy: a pilot study. Diabet Med. 1999;16(9):762-6. Full-text exclusion reason(s): No women with symptomatic chest pain, or results are not reported separately for symptomatic subgroup; Data for women not reported as a subgroup. [pmid: 10510953].
Gaemperli O, Schepis T, Koepfli P, et al. Accuracy of 64-slice CT angiography for the detection of functionally relevant coronary stenoses as assessed with myocardial perfusion SPECT. Eur J Nucl Med Mol Imaging. 2007;34(8):1162-71. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 17219136].
Gaemperli O, Schepis T, Valenta I, et al. Functionally relevant coronary artery disease: comparison of 64-section CT angiography with myocardial perfusion SPECT. Radiology. 2008;248(2):414-23. Full-text exclusion reason(s): All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 18552310].
Gaemperli O, Valenta I, Schepis T, et al. Coronary 64-slice CT angiography predicts outcome in patients with known or suspected coronary artery disease. Eur Radiol. 2008;18(6):1162-73. Full-text exclusion reason(s): No women with symptomatic chest pain, or results are not reported separately for symptomatic subgroup; All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 18286291].
Gaibazzi N, Reverberi C, Badano L. Usefulness of contrast stress-echocardiography or exercise-electrocardiography to predict long-term acute coronary syndromes in patients presenting with chest pain without electrocardiographic abnormalities or 12-hour troponin elevation. Am J Cardiol. 2011;107(2):161-7. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 21129709].
Gaibazzi N, Reverberi C, Squeri A, et al. Contrast stress echocardiography for the diagnosis of coronary artery disease in patients with chest pain but without acute coronary syndrome: incremental value of myocardial perfusion. J Am Soc Echocardiogr. 2009;22(4):404-10. Full-text exclusion reason(s): All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 19345309].
Gaibazzi N, Rigo F, Reverberi C. Detection of coronary artery disease by combined assessment of wall motion, myocardial perfusion and coronary flow reserve: a multiparametric contrast stress-echocardiography study. J Am Soc Echocardiogr. 2010;23(12):1242-50. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 20951000].
Gaibazzi N, Rigo F, Squeri A, et al. Incremental value of contrast myocardial perfusion to detect intermediate versus severe coronary artery stenosis during stress-echocardiography. Cardiovasc Ultrasound. 2010;8:16. Full-text exclusion reason(s): All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 20459632].
Galanti G, Sciagra R, Comeglio M, et al. Diagnostic accuracy of peak exercise echocardiography in coronary artery disease: comparison with thallium-201 myocardial scintigraphy. Am Heart J. 1991;122(6):1609-16. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 1957756].
Galassi AR, Azzarelli S, Lupo L, et al. Accuracy of exercise testing in the assessment of the severity of myocardial ischemia as determined by means of technetium-99m tetrofosmin SPECT scintigraphy. J Nucl Cardiol. 2000;7(6):575-83. Full-text exclusion reason(s): All women in the study are known to have CAD; Study does not compare one NIT to another or to diagnostic cardiac catheterization; Data for women not reported as a subgroup. [pmid: 11144472].
Gallagher MJ, Ross MA, Raff GL, et al. The diagnostic accuracy of 64-slice computed tomography coronary angiography compared with stress nuclear imaging in emergency department low-risk chest pain patients. Ann Emerg Med. 2007;49(2):125-36. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 16978738].
Garber AM, Solomon NA. Cost-effectiveness of alternative test strategies for the diagnosis of coronary artery disease. Ann Intern Med. 1999;130(9):719-28. Full-text exclusion reason(s): Not original peer-reviewed data or a secondary analysis of RCT, prospective or retrospective observational study, or registry. [pmid: 10357690].
Garcia MJ, Lessick J, Hoffmann MH. Accuracy of 16-row multidetector computed tomography for the assessment of coronary artery stenosis. JAMA. 2006;296(4):403-11. Full-text exclusion reason(s): All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 16868298].
Gaspar T, Dvir D, Peled N. The role of 16-slice computed tomography angiography in the diagnosis of coronary artery disease: large sample analysis. Isr Med Assoc J. 2005;7(7):424-7. Full-text exclusion reason(s): No women with symptomatic chest pain, or results are not reported separately for symptomatic subgroup; All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 16011055].
Gaudio C, Mirabelli F, Alessandra L, et al. Noninvasive assessment of coronary artery stenoses by multidetector-row spiral computed tomography: comparison with conventional angiography. Eur Rev Med Pharmacol Sci. 2005;9(1):13-21. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 15850140].
Gaudio C, Tanzilli G, Vittore A, et al. Detection of coronary artery stenoses using breath-hold magnetic resonance coronary angiography. Comparison with conventional x-ray angiography. Eur Rev Med Pharmacol Sci. 2004;8(3):121-8. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 15368796].
Gebker R, Jahnke C, Manka R, et al. Additional value of myocardial perfusion imaging during dobutamine stress magnetic resonance for the assessment of coronary artery disease. Circ Cardiovasc Imaging. 2008;1(2):122-30. Full-text exclusion reason(s): All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 19808529].
Gebker R, Jahnke C, Paetsch I, et al. Diagnostic performance of myocardial perfusion MR at 3 T in patients with coronary artery disease. Radiology. 2008;247(1):57-63. Full-text exclusion reason(s): All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 18305188].
Geleijns J, Joemai RM, Dewey M, et al. Radiation exposure to patients in a multicenter coronary angiography trial (CORE 64). AJR Am J Roentgenol. 2011;196(5):1126-32. Full-text exclusion reason(s): Not original peer-reviewed data or a secondary analysis of RCT, prospective or retrospective observational study, or registry. [pmid: 21512080].
Geleijnse ML, Elhendy A. Can stress echocardiography compete with perfusion scintigraphy in the detection of coronary artery disease and cardiac risk assessment?. Eur J Echocardiogr. 2000;1(1):12-21. Full-text exclusion reason(s): Not original peer-reviewed data or a secondary analysis of RCT, prospective or retrospective observational study, or registry. [pmid: 11916581].
Geleijnse ML, Krenning BJ, Soliman OI, et al. Dobutamine stress echocardiography for the detection of coronary artery disease in women. Am J Cardiol. 2007;99(5):714-7. Full-text exclusion reason(s): Not original peer-reviewed data or a secondary analysis of RCT, prospective or retrospective observational study, or registry. [pmid: 17317379].
Geleijnse ML, Marwick TH, Boersma E, et al. Optimal pharmacological stress testing for the diagnosis of coronary artery disease: a probabilistic approach. Eur Heart J. Suppl M. 1995;16:3-10. Full-text exclusion reason(s): Not original peer-reviewed data or a secondary analysis of RCT, prospective or retrospective observational study, or registry; Data for women not reported as a subgroup. [pmid: 8869117].
Geleijnse ML, Vigna C, Kasprzak JD, et al. Usefulness and limitations of dobutamine-atropine stress echocardiography for the diagnosis of coronary artery disease in patients with left bundle branch block. A multicentre study. Eur Heart J. 2000;21(20):1666-73. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 11032693].
Geluk CA, Dikkers R, Perik PJ, et al. Measurement of coronary calcium scores by electron beam computed tomography or exercise testing as initial diagnostic tool in low-risk patients with suspected coronary artery disease. Eur Radiol. 2008;18(2):244-52. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 17901959].
Genovesi D, Giorgetti A, Gimelli A, et al. Impact of attenuation correction and gated acquisition in SPECT myocardial perfusion imaging: results of the multicentre SPAG (SPECT Attenuation Correction vs Gated) study. Eur J Nucl Med Mol Imaging. 2011. Full-text exclusion reason(s): No outcomes of interest.
George RT, Arbab-Zadeh A, Miller JM, et al. Adenosine stress 64- and 256-row detector computed tomography angiography and perfusion imaging: a pilot study evaluating the transmural extent of perfusion abnormalities to predict atherosclerosis causing myocardial ischemia. Circ Cardiovasc Imaging. 2009;2(3):174-82. Full-text exclusion reason(s): All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 19808590].
Gerber BL, Coche E, Pasquet A, et al. Coronary artery stenosis: direct comparison of four-section multi-detector row CT and 3D navigator MR imaging for detection—initial results. Radiology. 2005;234(1):98-108. Full-text exclusion reason(s): No women with symptomatic chest pain, or results are not reported separately for symptomatic subgroup; Data for women not reported as a subgroup. [pmid: 15550371].
Gerber TC, Sheedy PF, Bell MR, et al. Evaluation of the coronary venous system using electron beam computed tomography. Int J Cardiovasc Imaging. 2001;17(1):65-75. Full-text exclusion reason(s): No data for NITs of interest (ECG, ECHO, SPECT, PET, CMR, CTA). [pmid: 11495511].
Ghadri JR, Pazhenkottil AP, Nkoulou RN, et al. Very high coronary calcium score unmasks obstructive coronary artery disease in patients with normal SPECT MPI. Heart. 2011;97(12):998-1003. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 21487127].
Ghaffari S, Toufan M. The value of endothelium dependent vasodilatation in diagnosing coronary artery disease and its comparison with the results of routine diagnostic tests. Saudi Med J. 2007;28(9):1344-9. Full-text exclusion reason(s): Not original peer-reviewed data or a secondary analysis of RCT, prospective or retrospective observational study, or registry. [pmid: 17768457].
Ghersin E, Litmanovich D, Dragu R, et al. 16-MDCT coronary angiography versus invasive coronary angiography in acute chest pain syndrome: a blinded prospective study. AJR Am J Roentgenol. 2006;186(1):177-84. Full-text exclusion reason(s): No women with symptomatic chest pain, or results are not reported separately for symptomatic subgroup; All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 16357399].
Ghostine S, Caussin C, Daoud B, et al. Non-invasive detection of coronary artery disease in patients with left bundle branch block using 64-slice computed tomography. J Am Coll Cardiol. 2006;48(10):1929-34. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 17112979].
Ghostine S, Caussin C, Daoud B, et al. Noninvasive Detection of Coronary Artery Disease in Patients with Left Bundle Branch Block Using 64-Slice Computed Tomography. 55th Annual Scientific Session of the American College of Cardiology, Georgia World Congress Center. Atlanta, Georgia (USA). 11–14 Mar 2006. 2006. Full-text exclusion reason(s): No women with symptomatic chest pain, or results are not reported separately for symptomatic subgroup; Data for women not reported as a subgroup.
Giardina A, De Castro S, Fedele F, et al. Noninvasive testing for coronary artery disease in women. Minerva Cardioangiol. 2006;54(3):323-30. Full-text exclusion reason(s): Not a clinical study report. [pmid: 16733506].
Gibbons RJ, Balady GJ, Beasley JW, et al. ACC/AHA Guidelines for Exercise Testing A report of the American College of Cardiology/American Heart Association. Task Force on Practice Guidelines (Committee on Exercise Testing). J Am Coll Cardiol. 1997;30(1):260-311. Full-text exclusion reason(s): Not original peer-reviewed data or a secondary analysis of RCT, prospective or retrospective observational study, or registry. [pmid: 9207652].
Gibson CM, Kirtane AJ, Murphy SA, et al. Early initiation of eptifibatide in the emergency department before primary percutaneous coronary intervention for ST-segment elevation myocardial infarction: results of the Time to Integrilin Therapy in Acute Myocardial Infarction (TITAN)-TIMI 34 trial. Am Heart J. 2006;152(4):668-75. Full-text exclusion reason(s): No data for NITs of interest (ECG, ECHO, SPECT, PET, CMR, CTA). [pmid: 16996831].
Gibson PB, Demus D, Noto R, et al. Low event rate for stress-only perfusion imaging in patients evaluated for chest pain. J Am Coll Cardiol. 2002;39(6):999-1004. Full-text exclusion reason(s): No women with symptomatic chest pain, or results are not reported separately for symptomatic subgroup; Data for women not reported as a subgroup. [pmid: 11897442].
Gigli G, Cortigiani L, Vallebona A, et al. Vasodilator stress echocardiography for risk stratification of medically stabilized unstable angina. Eur J Echocardiogr. 2002;3(1):59-66. Full-text exclusion reason(s): All women in the study are known to have CAD; Study does not compare one NIT to another or to diagnostic cardiac catheterization; Data for women not reported as a subgroup. [pmid: 12067536].
Gill JB, Ruddy TD, Newell JB, et al. Prognostic importance of thallium uptake by the lungs during exercise in coronary artery disease. N Engl J Med. 1987;317(24):1486-9. Full-text exclusion reason(s): Study does not compare one NIT to another or to diagnostic cardiac catheterization; Data for women not reported as a subgroup. [pmid: 3683484].
Ginzton LE, Conant R, Brizendine M, et al. Exercise subcostal two-dimensional echocardiography: a new method of segmental wall motion analysis. Am J Cardiol. 1984;53(6):805-11. Full-text exclusion reason(s): All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 6702629].
Giorgetti A, Marzullo P, Sambuceti G, et al. Baseline/post-nitrate Tc-99m tetrofosmin mismatch for the assessment of myocardial viability in patients with severe left ventricular dysfunction: comparison with baseline Tc-99m tetrofosmin scintigraphy/FDG PET imaging. J Nucl Cardiol. 2004;11(2):142-51. Full-text exclusion reason(s): All women in the study are known to have CAD. [pmid: 15052245].
Giorgetti A, Rossi M, Stanislao M, et al. Feasibility and diagnostic accuracy of a gated SPECT early-imaging protocol: a multicenter study of the Myoview Imaging Optimization Group. J Nucl Med. 2007;48(10):1670-5. Full-text exclusion reason(s): No women with symptomatic chest pain, or results are not reported separately for symptomatic subgroup; All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 17873126].
Girotra S, Keelan M, Weinstein AR, et al. Relation of heart rate response to exercise with prognosis and atherosclerotic progression after coronary artery bypass grafting. Am J Cardiol. 2009;103(10):1386-90. Full-text exclusion reason(s): No women with symptomatic chest pain, or results are not reported separately for symptomatic subgroup; All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 19427433].
Go RT, Marwick TH, MacIntyre WJ, et al. A prospective comparison of rubidium-82 PET and thallium-201 SPECT myocardial perfusion imaging utilizing a single dipyridamole stress in the diagnosis of coronary artery disease. J Nucl Med. 1990;31(12):1899-905. Full-text exclusion reason(s): No women with symptomatic chest pain, or results are not reported separately for symptomatic subgroup; All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 2266384].
Goldschlager N, Selzer A, Cohn K. Treadmill stress tests as indicators of presence and severity of coronary artery disease. Ann Intern Med. 1976;85(3):277-86. Full-text exclusion reason(s): Population does not include women ≥ age 18; All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 962219].
Goldstein JA, Gallagher MJ, O’Neill WW, et al. A randomized controlled trial of multi-slice coronary computed tomography for evaluation of acute chest pain. J Am Coll Cardiol. 2007;49(8):863-71. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 17320744].
Gonzalez P, Massardo T, Jofre MJ, et al. (201)T1 myocardial SPECT detects significant coronary artery disease between 50% and 75% angiogram stenosis. Revista Espanola de Medicina Nuclear. 2005;24(5):305-311. Full-text exclusion reason(s): All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 16194462].
Gonzalez P, Massardo T, Jofre MJ, et al. 201Tl myocardial SPECT detects significant coronary artery disease between 50% and 75% angiogram stenosis. Rev Esp Med Nucl. 2005;24(5):305-11. Full-text exclusion reason(s): No women with symptomatic chest pain, or results are not reported separately for symptomatic subgroup; All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 16194462].
Gopal A, Nasir K, Ahmadi N, et al. Cardiac computed tomographic angiography in an outpatient setting: an analysis of clinical outcomes over a 40-month period. J Cardiovasc Comput Tomogr. 2009;3(2):90-5. Full-text exclusion reason(s): No women with symptomatic chest pain, or results are not reported separately for symptomatic subgroup; Data for women not reported as a subgroup. [pmid: 19269915].
Gottdiener JS. Overview of stress echocardiography: uses, advantages, and limitations. Prog Cardiovasc Dis. 2001;43(4):315-34. Full-text exclusion reason(s): Not a clinical study report. [pmid: 11235847].
Gould KL. Positron emission tomography and interventional cardiology. Am J Cardiol. 1990;66(14):51F-58F. Full-text exclusion reason(s): Not original peer-reviewed data or a secondary analysis of RCT, prospective or retrospective observational study, or registry.
Gould KL, Goldstein RA, Mullani NA, et al. Noninvasive assessment of coronary stenoses by myocardial perfusion imaging during pharmacologic coronary vasodilation. VIII. Clinical feasibility of positron cardiac imaging without a cyclotron using generator-produced rubidium-82. J Am Coll Cardiol. 1986;7(4):775-89. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 3485669].
Gouya H, Varenne O, Trinquart L, et al. Coronary artery stenosis in high-risk patients: 64-section CT and coronary angiography—prospective study and analysis of discordance. Radiology. 2009;252(2):377-85. Full-text exclusion reason(s): No women with symptomatic chest pain, or results are not reported separately for symptomatic subgroup; All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 19546426].
Greenland P, Abrams J, Aurigemma GP, et al. Prevention Conference V: Beyond secondary prevention: identifying the high-risk patient for primary prevention: noninvasive tests of atherosclerotic burden: Writing Group III. Circulation. 2000;101(1). Full-text exclusion reason(s): Not a clinical study report.
Greenland P, Alpert JS, Beller GA, et al. ACCF/AHA guideline for assessment of cardiovascular risk in asymptomatic adults: a report of the American College of Cardiology Foundation/American Heart Association. Task Force on Practice Guidelines. J Am Coll Cardiol. 2010. 2010;56(25):e50-103. Full-text exclusion reason(s): Not a clinical study report. [pmid: 21144964].
Greenland P, Smith SC Jr, Grundy SM. Improving coronary heart disease risk assessment in asymptomatic people: role of traditional risk factors and noninvasive cardiovascular tests. Circulation. 2001;104(15):1863-7. Full-text exclusion reason(s): Not a clinical study report. [pmid: 11591627].
Gregoire J, Theroux P. Detection and assessment of unstable angina using myocardial perfusion imaging: Comparison between technetium-99m sestamibi SPECT and 12-lead electrocardiogram. Am J Cardiol. 1990;66(13):42E-46E. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 2113764].
Groothuis JG, Beek AM, Brinckman SL, et al. Low to intermediate probability of coronary artery disease: comparison of coronary CT angiography with first-pass MR myocardial perfusion imaging. Radiology. 2010;254(2):384-92. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 20089723].
Grosse C, Globits S, Hergan K. Forty-slice spiral computed tomography of the coronary arteries: assessment of image quality and diagnostic accuracy in a non-selected patient population. Acta Radiol. 2007;48(1):36-44. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 17325923].
Grossman GB, Garcia EV, Bateman TM, et al. Quantitative Tc-99m sestamibi attenuation-corrected SPECT: development and multicenter trial validation of myocardial perfusion stress gender-independent normal database in an obese population. J Nucl Cardiol. 2004;11(3):263-72. Full-text exclusion reason(s): Study does not compare one NIT to another or to diagnostic cardiac catheterization; Data for women not reported as a subgroup. [pmid: 15173773].
Groutars RG, Verzijlbergen JF, Tiel-van Buul MM, et al. The accuracy of 1-day dual-isotope myocardial SPECT in a population with high prevalence of coronary artery disease. Int J Cardiovasc Imaging. 2003;19(3):229-38. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 12834160].
Grover-McKay M, Milne N, Atwood JE, et al. Comparison of thallium-201 single-photon emission computed tomographic scintigraphy with intravenous dipyridamole and arm exercise. Am Heart J. 1994;127(6):1516-20. Full-text exclusion reason(s): No women with symptomatic chest pain, or results are not reported separately for symptomatic subgroup; All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 8197977].
Grover-McKay M, Ratib O, Schwaiger M, et al. Detection of coronary artery disease with positron emission tomography and rubidium 82. Am Heart J. 1992;123(3):646-52. Full-text exclusion reason(s): All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 1539516].
Groves AM, Speechly-Dick ME, Dickson JC, et al. Cardiac 82Rubidium PET/CT: initial European experience. Eur J Nucl Med Mol Imaging. 2007;34(12):1965-72. Full-text exclusion reason(s): Study does not compare one NIT to another or to diagnostic cardiac catheterization; Data for women not reported as a subgroup. [pmid: 17768620].
Groves AM, Speechly-Dick ME, Kayani I, et al. First experience of combined cardiac PET/64-detector CT angiography with invasive angiographic validation. Eur J Nucl Med Mol Imaging. 2009;36(12):2027-33. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 19618180].
Grunig E, Mereles D, Benz A, et al. Contribution of stress echocardiography to clinical decision making in unselected ambulatory patients with known or suspected coronary artery disease. Int J Cardiol. 2002;84(2–3):179-85. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 12127370].
Gu X, He Y, Li Z, et al. Relation between the incidence, location, and extent of thoracic aortic atherosclerosis detected by transesophageal echocardiography and the extent of coronary artery disease by angiography. Am J Cardiol. 2011;107(2):175-8. Full-text exclusion reason(s): All women in the study are known to have CAD. [pmid: 21129720].
Gudmundsson P, Shahgaldi K, Winter R, et al. Head to head comparisons of two modalities of perfusion adenosine stress echocardiography with simultaneous SPECT. Cardiovasc Ultrasound. 2009;7:19. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 19379491].
Gulati GS, Seth S, Kurian S, et al. Non-invasive diagnosis of coronary artery disease with 16-slice computed tomography. Natl Med J India. 2005;18(5):236-41. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 16433135].
Gunalp B, Dokumaci B, Uyan C, et al. Value of dobutamine technetium-99m-sestamibi SPECT and echocardiography in the detection of coronary artery disease compared with coronary angiography. J Nucl Med. 1993;34(6):889-94. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 8509853].
Gunes Y, Gumrukcuoglu HA, Kaya Y, et al. Incremental diagnostic value of color M-mode propagation velocity of the descending thoracic aorta to exercise electrocardiography. Turk Kardiyoloji Dernegi Arsivi. 2010;38(8):551-557. Full-text exclusion reason(s): Study does not compare one NIT to another or to diagnostic cardiac catheterization; Data for women not reported as a subgroup. [pmid: 21248455].
Guo SZ, Shu XH, Pan CZ, et al. Usefulness of dobutamine stress myocardial contrast echocardiography for assessing coronary artery disease. Chin Med J (Engl). 2005;118(21):1766-72. Full-text exclusion reason(s): All women in the study are known to have CAD; Data for women not reported as a subgroup; No outcomes of interest. [pmid: 16336812].
Gupta NC, Esterbrooks DJ, Hilleman DE, et al. Comparison of adenosine and exercise thallium-201 single-photon emission computed tomography (SPECT) myocardial perfusion imaging. The GE SPECT Multicenter Adenosine Study Group. J Am Coll Cardiol. 1992;19(2):248-57. Full-text exclusion reason(s): All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 1732349].
Haberl R, Becker A, Leber A, et al. Correlation of coronary calcification and angiographically documented stenoses in patients with suspected coronary artery disease: results of 1,764 patients. J Am Coll Cardiol. 2001;37(2):451-7. Full-text exclusion reason(s): No outcomes of interest. [pmid: 11216962].
Haberl R, Tittus J, Bohme E, et al. Multislice spiral computed tomographic angiography of coronary arteries in patients with suspected coronary artery disease: an effective filter before catheter angiography?. Am Heart J. 2005;149(6):1112-9. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 15976796].
Hachamovitch R, Berman DS, Shaw LJ, et al. Incremental prognostic value of myocardial perfusion single photon emission computed tomography for the prediction of cardiac death: differential stratification for risk of cardiac death and myocardial infarction. Circulation. 1998;97(6):535-43. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 9494023].
Hachamovitch R, Hayes SW, Friedman JD, et al. Stress myocardial perfusion single-photon emission computed tomography is clinically effective and cost effective in risk stratification of patients with a high likelihood of coronary artery disease (CAD) but no known CAD. J Am Coll Cardiol. 2004;43(2):200-8. Full-text exclusion reason(s): Study does not compare one NIT to another or to diagnostic cardiac catheterization; Data for women not reported as a subgroup. [pmid: 14736438].
Hachamovitch R, Johnson JR, Hlatky MA, et al. The study of myocardial perfusion and coronary anatomy imaging roles in CAD (SPARC): design, rationale, and baseline patient characteristics of a prospective, multicenter observational registry comparing PET, SPECT, and CTA for resource utilization and clinical outcomes. J Nucl Cardiol. 2009;16(6):935-48. Full-text exclusion reason(s): All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 19760338].
Hacker M, Jakobs T, Hack N, et al. Sixty-four slice spiral CT angiography does not predict the functional relevance of coronary artery stenoses in patients with stable angina. Eur J Nucl Med Mol Imaging. 2007;34(1):4-10. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 16951954].
Hacker M, Jakobs T, Hack N, et al. Combined use of 64-slice computed tomography angiography and gated myocardial perfusion SPECT for the detection of functionally relevant coronary artery stenoses. First results in a clinical setting concerning patients with stable angina. Nuklearmedizin. 2007;46(1):29-35. Full-text exclusion reason(s): No women with symptomatic chest pain, or results are not reported separately for symptomatic subgroup; All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 17299652].
Hacker M, Jakobs T, Matthiesen F, et al. Comparison of spiral multidetector CT angiography and myocardial perfusion imaging in the noninvasive detection of functionally relevant coronary artery lesions: first clinical experiences. J Nucl Med. 2005;46(8):1294-300. Full-text exclusion reason(s): All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 16085585].
Hadamitzky M, Distler R, Meyer T, et al. Prognostic value of coronary computed tomographic angiography in comparison with calcium scoring and clinical risk scores. Circ Cardiovasc Imaging. 2011;4(1):16-23. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 20884832].
Hage FG, Dubovsky EV, Heo J, et al. Outcome of patients with adenosine-induced ST-segment depression but with normal perfusion on tomographic imaging. Am J Cardiol. 2006;98(8):1009-11. Full-text exclusion reason(s): No women with symptomatic chest pain, or results are not reported separately for symptomatic subgroup; Study does not compare one NIT to another or to diagnostic cardiac catheterization; Data for women not reported as a subgroup. [pmid: 17027561].
Hajduczki I, Berenyi I, Enghoff E, et al. Qualitative and quantitative evaluation of the exercise electrocardiogram in assessing the degree of coronary heart disease. J Electrocardiol. 1985;18(1):55-62. Full-text exclusion reason(s): No women with symptomatic chest pain, or results are not reported separately for symptomatic subgroup; Data for women not reported as a subgroup. [pmid: 2857760].
Hajjiri MM, Leavitt MB, Zheng H, et al. Comparison of positron emission tomography measurement of adenosine-stimulated absolute myocardial blood flow versus relative myocardial tracer content for physiological assessment of coronary artery stenosis severity and location. JACC Cardiovasc Imaging. 2009;2(6):751-8. Full-text exclusion reason(s): All women in the study are known to have CAD; Study does not compare one NIT to another or to diagnostic cardiac catheterization; Data for women not reported as a subgroup; No outcomes of interest. [pmid: 19520347].
Halon DA, Gaspar T, Adawi S, et al. Uses and limitations of 40 slice multi-detector row spiral computed tomography for diagnosing coronary lesions in unselected patients referred for routine invasive coronary angiography. Cardiology. 2007;108(3):200-9. Full-text exclusion reason(s): All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 17095866].
Halpern EJ, Halpern DJ. Diagnosis of coronary stenosis with CT angiography comparison of automated computer diagnosis with expert readings. Acad Radiol. 2011;18(3):324-33. Full-text exclusion reason(s): Study does not compare one NIT to another or to diagnostic cardiac catheterization; Data for women not reported as a subgroup. [pmid: 21215663].
Haluska B, Case C, Short L, et al. Effect of power Doppler and digital subtraction techniques on the comparison of myocardial contrast echocardiography with SPECT. Heart. 2001;85(5):549-55. Full-text exclusion reason(s): All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 11303008].
Hambye AS, Vervaet A, Lieber S, et al. Diagnostic value and incremental contribution of bicycle exercise, first-pass radionuclide angiography, and 99mTc-labeled sestamibi single-photon emission computed tomography in the identification of coronary artery disease in patients without infarction. J Nucl Cardiol. 1996;3(6 Pt 1):464-74. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 8989671].
Hamdan A, Asbach P, Wellnhofer E, et al. A prospective study for comparison of MR and CT imaging for detection of coronary artery stenosis. JACC Cardiovasc Imaging. 2011;4(1):50-61. Full-text exclusion reason(s): All women in the study are known to have CAD; Data for women not reported as a subgroup; No outcomes of interest. [pmid: 21232704].
Hamirani YS, Isma’eel H, Larijani V, et al. The diagnostic accuracy of 64-detector cardiac computed tomography compared with stress nuclear imaging in patients undergoing invasive cardiac catheterization. J Comput Assist Tomogr. 2010;34(5):645-51. Full-text exclusion reason(s): All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 20861764].
Hamon M, Fau G, Nee G, et al. Meta-analysis of the diagnostic performance of stress perfusion cardiovascular magnetic resonance for detection of coronary artery disease. J Cardiovasc Magn Reson. 2010;12(1):29. Full-text exclusion reason(s): Not original peer-reviewed data or a secondary analysis of RCT, prospective or retrospective observational study, or registry. [pmid: 20482819].
Hamon M, Morello R, Riddell JW. Coronary arteries: diagnostic performance of 16- versus 64-section spiral CT compared with invasive coronary angiography—meta-analysis. Radiology. 2007;245(3):720-31. Full-text exclusion reason(s): Not original peer-reviewed data or a secondary analysis of RCT, prospective or retrospective observational study, or registry. [pmid: 17951354].
Han PP, Tian YQ, Fang W, et al. Impact of myocardial perfusion imaging on in-hospital coronary angiography and revascularization of patients with suspected coronary artery disease. Chin Med J (Engl). 2011;124(11):1603-9. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 21740763].
Han SC, Fang CC, Chen Y, et al. Coronary computed tomography angiography—a promising imaging modality in diagnosing coronary artery disease. J Chin Med Assoc. 2008;71(5):241-6. Full-text exclusion reason(s): No women with symptomatic chest pain, or results are not reported separately for symptomatic subgroup; All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 18490228].
Hansen M, Ginns J, Seneviratne S, et al. The value of dual-source 64-slice CT coronary angiography in the assessment of patients presenting to an acute chest pain service. Heart Lung and Circulation. 2010;19(4):213-218. Full-text exclusion reason(s): Data for women not reported as a subgroup.
Hansen PR, Jacobsen TN. Contrast echocardiography as a new non-invasive diagnostic method for assessment of coronary artery disease: from endocardial border detection (EBD) to myocardial perfusion (MCE). Ugeskrift for laeger. 1998;160(36):5209-5210. Full-text exclusion reason(s): Non-English. [pmid: 9741287].
Haramati LB, Levsky JM, Jain VR, et al. CT angiography for evaluation of coronary artery disease in inner-city outpatients: an initial prospective comparison with stress myocardial perfusion imaging. Int J Cardiovasc Imaging. 2009;25(3):303-13. Full-text exclusion reason(s): All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 18979224].
Haraphongse M, Kappagoda T, Tymchak W, et al. The value of sum of ST segment depression in 12-lead electrocardiogram in relation to change in heart rate during exercise to predict the extent of coronary artery disease. Can J Cardiol. 1986;2(2):64-7. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 3635421].
Harinstein ME, Flaherty JD, Ansari AH, et al. Predictive value of dobutamine stress echocardiography for coronary artery disease detection in liver transplant candidates. American Journal of Transplantation. 2008;8(7):1523-1528. Full-text exclusion reason(s): No women with symptomatic chest pain, or results are not reported separately for symptomatic subgroup; Data for women not reported as a subgroup. [pmid: 18510630].
Harshad K, Sathyamurthy I, Ashish G, et al. Myocardial perfusion single photon emission computed tomography in asymptomatic diabetics. Indian Heart J. 2010;62(1):29-34. Full-text exclusion reason(s): Full-text unobtainable. [pmid: 21180031].
Hart CY, Miller TD, Hodge DO, et al. Specificity of the stress electrocardiogram during adenosine myocardial perfusion imaging in patients taking digoxin. Am Heart J. 2000;140(6):937-40. Full-text exclusion reason(s): No women with symptomatic chest pain, or results are not reported separately for symptomatic subgroup; Data for women not reported as a subgroup. [pmid: 11099998].
Hatanaka K, Doi M, Hirohata S, et al. Safety of and tolerance to adenosine infusion for myocardial perfusion single-photon emission computed tomography in a Japanese population. Circ J. 2007;71(6):904-10. Full-text exclusion reason(s): All women in the study are known to have CAD; Study does not compare one NIT to another or to diagnostic cardiac catheterization; Data for women not reported as a subgroup. [pmid: 17526988].
Hausleiter J, Martinoff S, Hadamitzky M, et al. Image quality and radiation exposure with a low tube voltage protocol for coronary CT angiography results of the PROTECTION II Trial. JACC Cardiovasc Imaging. 2010;3(11):1113-23. Full-text exclusion reason(s): Data for women not reported as a subgroup; No outcomes of interest. [pmid: 21070998].
Hausleiter J, Meyer T, Hadamitzky M, et al. Non-invasive coronary computed tomographic angiography for patients with suspected coronary artery disease: the Coronary Angiography by Computed Tomography with the Use of a Submillimeter resolution (CACTUS) trial. Eur Heart J. 2007;28(24):3034-41. Full-text exclusion reason(s): No women with symptomatic chest pain, or results are not reported separately for symptomatic subgroup; Data for women not reported as a subgroup. [pmid: 17540851].
Hausleiter J, Meyer T, Hermann F, et al. Estimated radiation dose associated with cardiac CT angiography. JAMA. 2009;301(5):500-7. Full-text exclusion reason(s): Study does not compare one NIT to another or to diagnostic cardiac catheterization; Data for women not reported as a subgroup. [pmid: 19190314].
Hayashi M, Kambara H, Nohara R, et al. Evaluation and clinical use of early washout ratio of thallium-201 in normal and ischemic myocardium after dipyridamole-induced vasodilation using ring-type emission computed tomography. Jpn Circ J. 1991;55(3):194-203. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 2030546].
Hayashino Y, Nagata-Kobayashi S, Morimoto T, et al. Cost-effectiveness of screening for coronary artery disease in asymptomatic patients with Type 2 diabetes and additional atherogenic risk factors. J Gen Intern Med. 2004;19(12):1181-91. Full-text exclusion reason(s): Not original peer-reviewed data or a secondary analysis of RCT, prospective or retrospective observational study, or registry. [pmid: 15610328].
He Q, Yao Z, Yu X, et al. Evaluation of (99m)Tc-MIBI myocardial perfusion imaging with intravenous infusion of adenosine triphosphate in diagnosis of coronary artery disease. Chin Med J (Engl). 2002;115(11):1603-7. Full-text exclusion reason(s): No women with symptomatic chest pain, or results are not reported separately for symptomatic subgroup; All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 12609070].
He ZX, Shi RF, Wu YJ, et al. Direct imaging of exercise-induced myocardial ischemia with fluorine-18-labeled deoxyglucose and Tc-99m-sestamibi in coronary artery disease. Circulation. 2003;108(10):1208-13. Full-text exclusion reason(s): No women with symptomatic chest pain, or results are not reported separately for symptomatic subgroup; All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 12939208].
Hecht HS, Blumfield DE, Hopkins JM, et al. Single dose exercise and redistribution 201thallium scanning in the diagnosis of myocardial ischemia and coronary artery disease. Comparison with exercise and rest electrocardiography, coronary arteriography and left ventriculography. Chest. 1980;77(3):359-68. Full-text exclusion reason(s): All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 7357939].
Hecht HS, DeBord L, Shaw R, et al. Supine bicycle stress echocardiography versus tomographic thallium-201 exercise imaging for the detection of coronary artery disease. J Am Soc Echocardiogr. 1993;6(2):177-85. Full-text exclusion reason(s): All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 8481246].
Heiba SI, Hayat NJ, Salman HS, et al. Technetium-99m-MIBI myocardial SPECT: supine versus right lateral imaging and comparison with coronary arteriography. J Nucl Med. 1997;38(10):1510-4. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 9379184].
Heijenbrok-Kal MH, Fleischmann KE, Hunink MG. Stress echocardiography, stress single-photon-emission computed tomography and electron beam computed tomography for the assessment of coronary artery disease: a meta-analysis of diagnostic performance. Am Heart J. 2007;154(3):415-23. Full-text exclusion reason(s): Not original peer-reviewed data or a secondary analysis of RCT, prospective or retrospective observational study, or registry. [pmid: 17719283].
Heinicke N, Benesch B, Kaiser T, et al. Mechanisms of regional wall motion abnormalities in contrast-enhanced dobutamine stress echocardiography. Clin Res Cardiol. 2006;95(12):650-6. Full-text exclusion reason(s): No women with symptomatic chest pain, or results are not reported separately for symptomatic subgroup; All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 16998740].
Heinle SK, Noblin J, Goree-Best P, et al. Assessment of myocardial perfusion by harmonic power Doppler imaging at rest and during adenosine stress: comparison with (99m)Tc-sestamibi SPECT imaging. Circulation. 2000;102(1):55-60. Full-text exclusion reason(s): No women with symptomatic chest pain, or results are not reported separately for symptomatic subgroup; All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 10880415].
Hendel RC, Layden JJ, Leppo JA. Prognostic value of dipyridamole thallium scintigraphy for evaluation of ischemic heart disease. J Am Coll Cardiol. 1990;15(1):109-16. Full-text exclusion reason(s): Study does not compare one NIT to another or to diagnostic cardiac catheterization; Data for women not reported as a subgroup. [pmid: 2295718].
Hennessy TG, Codd MB, Hennessy MS, et al. Comparison of dobutamine stress echocardiography and treadmill exercise electrocardiography for detection of coronary artery disease. Coron Artery Dis. 1997;8(11–12):689-95. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 9472457].
Hennessy TG, Codd MB, Kane G, et al. Dobutamine stress echocardiography in the detection of coronary artery disease: importance of the pretest likelihood of disease. Am Heart J. 1997;134(4):685-92. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 9351736].
Hennessy TG, Codd MB, Kane G, et al. Evaluation of patients with diabetes mellitus for coronary artery disease using dobutamine stress echocardiography. Coron Artery Dis. 1997;8(3–4):171-4. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 9237027].
Hennessy TG, Codd MB, McCarthy C, et al. Dobutamine stress echocardiography in the detection of coronary artery disease in a clinical practice setting. Int J Cardiol. 1997;62(1):55-62. Full-text exclusion reason(s): No women with symptomatic chest pain, or results are not reported separately for symptomatic subgroup; Data for women not reported as a subgroup. [pmid: 9363503].
Hennessy TG, Siobhan Hennessy M, Codd MB, et al. Detection of coronary artery disease using dobutamine stress echocardiography in patients with an abnormal resting electrocardiograph. Int J Cardiol. 1998;64(3):293-8. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 9672411].
Henrikson CA, Howell EE, Bush DE, et al. Female sex: A protective role in suspected myocardial ischemia. Coron Artery Dis. 2006;17(2):153-158. Full-text exclusion reason(s): All women in the study are known to have CAD; Study does not compare one NIT to another or to diagnostic cardiac catheterization. [pmid: 16474234].
Hernandez R, Vale L. The value of myocardial perfusion scintigraphy in the diagnosis and management of angina and myocardial infarction: a probabilistic economic analysis. Med Decis Making. 2007;27(6):772-88. Full-text exclusion reason(s): Not original peer-reviewed data or a secondary analysis of RCT, prospective or retrospective observational study, or registry. [pmid: 17989429].
Herzog BA, Husmann L, Burkhard N, et al. Accuracy of low-dose computed tomography coronary angiography using prospective electrocardiogram-triggering: first clinical experience. Eur Heart J. 2008;29(24):3037-42. Full-text exclusion reason(s): No women with symptomatic chest pain, or results are not reported separately for symptomatic subgroup; Data for women not reported as a subgroup. [pmid: 18996954].
Herzog BA, Wyss CA, Husmann L, et al. First head-to-head comparison of effective radiation dose from low-dose 64-slice CT with prospective ECG-triggering versus invasive coronary angiography. Heart. 2009;95(20):1656-61. Full-text exclusion reason(s): No women with symptomatic chest pain, or results are not reported separately for symptomatic subgroup; Data for women not reported as a subgroup. [pmid: 19581273].
Herzog C, Ay M, Engelmann K, et al. Visualization techniques in multislice CT-coronary angiography of the heart. Correlations of axial, multiplanar, three-dimensional and virtual endoscopic imaging with the invasive diagnosis. Rofo. 2001;173(4):341-9. Full-text exclusion reason(s): Non-English. [pmid: 11367844].
Herzog C, Britten M, Balzer JO, et al. Multidetector-row cardiac CT: diagnostic value of calcium scoring and CT coronary angiography in patients with symptomatic, but atypical, chest pain. Eur Radiol. 2004;14(2):169-77. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 14689229].
Herzog C, Nguyen SA, Savino G, et al. Does two-segment image reconstruction at 64-section CT coronary angiography improve image quality and diagnostic accuracy?. Radiology. 2007;244(1):121-9. Full-text exclusion reason(s): No women with symptomatic chest pain, or results are not reported separately for symptomatic subgroup; Data for women not reported as a subgroup. [pmid: 17495177].
Herzog C, Zwerner PL, Doll JR, et al. Significant coronary artery stenosis: comparison on per-patient and per-vessel or per-segment basis at 64-section CT angiography. Radiology. 2007;244(1):112-20. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 17581898].
Herzog CA, Marwick TH, Pheley AM, et al. Dobutamine stress echocardiography for the detection of significant coronary artery disease in renal transplant candidates. Am J Kidney Dis. 1999;33(6):1080-90. Full-text exclusion reason(s): No women with symptomatic chest pain, or results are not reported separately for symptomatic subgroup; Data for women not reported as a subgroup. [pmid: 10352196].
Heuschmid M, Burgstahler C, Reimann A, et al. Usefulness of noninvasive cardiac imaging using dual-source computed tomography in an unselected population with high prevalence of coronary artery disease. Am J Cardiol. 2007;100(4):587-92. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 17697811].
Heuschmid M, Kuettner A, Schroeder S, et al. ECG-gated 16-MDCT of the coronary arteries: assessment of image quality and accuracy in detecting stenoses. AJR Am J Roentgenol. 2005;184(5):1413-9. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 15855088].
Hida S, Chikamori T, Tanaka H, et al. Diagnostic value of left ventricular function after adenosine triphosphate loading and at rest in the detection of multi-vessel coronary artery disease using myocardial perfusion imaging. J Nucl Cardiol. 2009;16(1):20-7. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 19152125].
Hida S, Chikamori T, Tanaka H, et al. Sex-specific approach to gated SPECT volumetric analysis after stress and at rest to detect high-risk coronary artery disease. Nucl Med Commun. 2010;31(9):800-6. Full-text exclusion reason(s): No women with symptomatic chest pain, or results are not reported separately for symptomatic subgroup; All women in the study are known to have CAD; Data for women not reported as a subgroup; No outcomes of interest. [pmid: 20634768].
Hida S, Chikamori T, Tanaka H, et al. Diagnostic value of left ventricular function after stress and at rest in the detection of multivessel coronary artery disease as assessed by electrocardiogram-gated SPECT. J Nucl Cardiol. 2007;14(1):68-74. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 17276308].
Higashiue S, Watanabe H, Yokoi Y, et al. Simple detection of severe coronary stenosis using transthoracic Doppler echocardiography at rest. Am J Cardiol. 2001;87(9):1064-8. Full-text exclusion reason(s): No data for NITs of interest (ECG, ECHO, SPECT, PET, CMR, CTA). [pmid: 11348603].
Hirai N, Horiguchi J, Fujioka C, et al. Prospective versus retrospective ECG-gated 64-detector coronary CT angiography: assessment of image quality, stenosis, and radiation dose. Radiology. 2008;248(2):424-30. Full-text exclusion reason(s): Study does not compare one NIT to another or to diagnostic cardiac catheterization; Data for women not reported as a subgroup. [pmid: 18574140].
Hirano Y, Ozasa Y, Yamamoto T, et al. Diagnosis of vasospastic angina by hyperventilation and cold-pressor stress echocardiography: comparison to I-MIBG myocardial scintigraphy. J Am Soc Echocardiogr. 2002;15(6):617-23. Full-text exclusion reason(s): All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 12050603].
Hirano Y, Ozasa Y, Yamamoto T, et al. Hyperventilation and cold-pressor stress echocardiography for noninvasive diagnosis of coronary artery spasm. J Am Soc Echocardiogr. 2001;14(6):626-33. Full-text exclusion reason(s): No data for NITs of interest (ECG, ECHO, SPECT, PET, CMR, CTA). [pmid: 11391292].
Hirano Y, Uehara H, Nakamura H, et al. Efficacy of ultrasound-assisted stress testing using a hand-carried ultrasound device for diagnosis of coronary artery disease. J Am Soc Echocardiogr. 2006;19(5):536-9. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 16644437].
Hlaihel C, Boussel L, Cochet H, et al. Dose and image quality comparison between prospectively gated axial and retrospectively gated helical coronary CT angiography. Br J Radiol. 2011;84(997):51-7. Full-text exclusion reason(s): No women with symptomatic chest pain, or results are not reported separately for symptomatic subgroup; Study does not compare one NIT to another or to diagnostic cardiac catheterization; Data for women not reported as a subgroup. [pmid: 21172966].
Ho FM, Huang PJ, Liau CS, et al. Dobutamine stress echocardiography compared with dipyridamole thallium-201 single-photon emission computed tomography in detecting coronary artery disease. Eur Heart J. 1995;16(4):570-5. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 7671905].
Ho JS, Barlow CE, Reinhardt DB, et al. Effect of increasing body mass index on image quality and positive predictive value of 100-kV coronary computed tomographic angiography. Am J Cardiol. 2010;106(8):1182-1186. Full-text exclusion reason(s): No women with symptomatic chest pain, or results are not reported separately for symptomatic subgroup; Data for women not reported as a subgroup. [pmid: 20920661].
Ho KT, Chua KC, Klotz E, et al. Stress and rest dynamic myocardial perfusion imaging by evaluation of complete time-attenuation curves with dual-source CT. JACC: Cardiovascular Imaging. 2010;3(8):811-820. Full-text exclusion reason(s): No women with symptomatic chest pain, or results are not reported separately for symptomatic subgroup; All women in the study are known to have CAD; Data for women not reported as a subgroup; No outcomes of interest. [pmid: 20705260].
Ho YL, Wu CC, Chao CL, et al. Localizing individual coronary artery obstructions with the dobutamine stress echocardiography. Cardiology. 1997;88(2):197-202. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 9096922].
Ho YL, Wu CC, Huang PJ, et al. Dobutamine stress echocardiography compared with exercise thallium-201 single-photon emission computed tomography in detecting coronary artery disease-effect of exercise level on accuracy. Cardiology. 1997;88(4):379-85. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 9197434].
Ho YL, Wu CC, Lin LC, et al. Assessment of the coronary artery disease and systolic dysfunction in hypertensive patients with the dobutamine-atropine stress echocardiography: effect of the left ventricular hypertrophy. Cardiology. 1998;89(1):52-8. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 9452158].
Ho YL, Wu CC, Lin LC, et al. Assessment of the functional significance of coronary artery stenosis by dobutamine-atropine stress echocardiography. Cardiology. 1997;88(4):386-92. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 9197435].
Hoekema R, Gürlek C, Brouwer MA, et al. The use of magnetocardiography and body surface potential mapping in the detection of coronary artery disease in chest pain patients with a normal electrocardiogram. Computers in Cardiology. 2004;31:389-392. Full-text exclusion reason(s): Data for women not reported as a subgroup.
Hoffmann MH, Shi H, Schmid FT, et al. Noninvasive coronary imaging with MDCT in comparison to invasive conventional coronary angiography: a fast-developing technology. AJR Am J Roentgenol. 2004;182(3):601-8. Full-text exclusion reason(s): Not a clinical study report. [pmid: 14975955].
Hoffmann MH, Shi H, Schmitz BL, et al. Noninvasive coronary angiography with multislice computed tomography. JAMA. 2005;293(20):2471-8. Full-text exclusion reason(s): All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 15914747].
Hoffmann R, Borges AC, Kasprzak JD, et al. Analysis of myocardial perfusion or myocardial function for detection of regional myocardial abnormalities. An echocardiographic multicenter comparison study using myocardial contrast echocardiography and 2D echocardiography. Eur J Echocardiogr. 2007;8(6):438-48. Full-text exclusion reason(s): All women in the study are known to have CAD; Data for women not reported as a subgroup; No outcomes of interest. [pmid: 17011829].
Hoffmann R, Lethen H, Falter F, et al. Dobutamine stress echocardiography after coronary artery bypass grafting. Transthoracic vs biplane transoesophageal imaging. Eur Heart J. 1996;17(2):222-9. Full-text exclusion reason(s): No women with symptomatic chest pain, or results are not reported separately for symptomatic subgroup; Data for women not reported as a subgroup. [pmid: 8732375].
Hoffmann R, Lethen H, Kleinhans E, et al. Comparative evaluation of bicycle and dobutamine stress echocardiography with perfusion scintigraphy and bicycle electrocardiogram for identification of coronary artery disease. Am J Cardiol. 1993;72(7):555-9. Full-text exclusion reason(s): No women with symptomatic chest pain, or results are not reported separately for symptomatic subgroup; Data for women not reported as a subgroup; No outcomes of interest. [pmid: 8362770].
Hoffmann R, Lethen H, Kuhl H, et al. Extent and severity of test positivity during dobutamine stress echocardiography. Influence on the predictive value for coronary artery disease. Eur Heart J. 1999;20(20):1485-92. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 10493847].
Hoffmann R, Lethen H, Marwick T, et al. Analysis of interinstitutional observer agreement in interpretation of dobutamine stress echocardiograms. J Am Coll Cardiol. 1996;27(2):330-6. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 8557902].
Hoffmann R, Marwick TH, Poldermans D, et al. Refinements in stress echocardiographic techniques improve inter-institutional agreement in interpretation of dobutamine stress echocardiograms. Eur Heart J. 2002;23(10):821-9. Full-text exclusion reason(s): All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 12009723].
Hoffmann S, Mogelvang R, Sogaard P, et al. Tissue Doppler echocardiography reveals impaired cardiac function in patients with reversible ischaemia. European Journal of Echocardiography. 2011;12(8):628-634. Full-text exclusion reason(s): All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 21757478].
Hoffmann U, Bamberg F, Chae CU, et al. Coronary computed tomography angiography for early triage of patients with acute chest pain: the ROMICAT (Rule Out Myocardial Infarction using Computer Assisted Tomography) trial. J Am Coll Cardiol. 2009;53(18):1642-50. Full-text exclusion reason(s): Study does not compare one NIT to another or to diagnostic cardiac catheterization; Data for women not reported as a subgroup. [pmid: 19406338].
Hoffmann U, Moselewski F, Cury RC, et al. Predictive value of 16-slice multidetector spiral computed tomography to detect significant obstructive coronary artery disease in patients at high risk for coronary artery disease: patient-versus segment-based analysis. Circulation. 2004;110(17):2638-43. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 15492297].
Hoffmann U, Nagurney JT, Moselewski F, et al. Coronary multidetector computed tomography in the assessment of patients with acute chest pain. Circulation. 2006;114(21):2251-60. Full-text exclusion reason(s): Study does not compare one NIT to another or to diagnostic cardiac catheterization; Data for women not reported as a subgroup. [pmid: 17075011].
Hoilund-Carlsen PF, Johansen A, Christensen HW, et al. Potential impact of myocardial perfusion scintigraphy as gatekeeper for invasive examination and treatment in patients with stable angina pectoris: observational study without post-test referral bias. Eur Heart J. 2006;27(1):29-34. Full-text exclusion reason(s): All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 16183689].
Hollander JE, Chang AM, Shofer FS, et al. One-year outcomes following coronary computerized tomographic angiography for evaluation of emergency department patients with potential acute coronary syndrome. Acad Emerg Med. 2009;16(8):693-8. Full-text exclusion reason(s): All women in the study are known to have CAD; Study does not compare one NIT to another or to diagnostic cardiac catheterization; Data for women not reported as a subgroup. [pmid: 19594460].
Hollander JE, Litt HI, Chase M, et al. Computed tomography coronary angiography for rapid disposition of low-risk emergency department patients with chest pain syndromes. Acad Emerg Med. 2007;14(2):112-6. Full-text exclusion reason(s): Study does not compare one NIT to another or to diagnostic cardiac catheterization. [pmid: 17267528].
Holubkov R, Pepine CJ, Rickens C, et al. Electrocardiogram abnormalities predict angiographic coronary artery disease in women with chest pain: results from the NHLBI WISE Study. Clin Cardiol. 2002;25(12):553-8. Full-text exclusion reason(s): Study does not compare one NIT to another or to diagnostic cardiac catheterization. [pmid: 12492124].
Hong YJ, Kim SJ, Lee SM, et al. Low-dose coronary computed tomography angiography using prospective ECG-triggering compared to invasive coronary angiography. Int J Cardiovasc Imaging. 2010. Full-text exclusion reason(s): All women in the study are known to have CAD; Data for women not reported as a subgroup.
Hong YJ, Kim SJ, Lee SM, et al. Low-dose coronary computed tomography angiography using prospective ECG-triggering compared to invasive coronary angiography. Int J Cardiovasc Imaging. 2011;27(3):425-431. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 20680462].
Hoppe H, Spagnuolo S, Froehlich JM, et al. Retrospective analysis of patients for development of nephrogenic systemic fibrosis following conventional angiography using gadolinium-based contrast agents. Euro Radiol. 2010;20(3):595-603. Full-text exclusion reason(s): No women with symptomatic chest pain, or results are not reported separately for symptomatic subgroup; Data for women not reported as a subgroup.
Hosoi M, Sato T, Yamagami K, et al. Impact of diabetes on coronary stenosis and coronary artery calcification detected by electron-beam computed tomography in symptomatic patients. Diabetes Care. 2002;25(4):696-701. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 11919127].
Hou Y, Yue Y, Guo W, et al. Prospectively versus retrospectively ECG-gated 256-slice coronary CT angiography: image quality and radiation dose over expanded heart rates. Int J Cardiovasc Imaging. 2010. Full-text exclusion reason(s): No women with symptomatic chest pain, or results are not reported separately for symptomatic subgroup; Study does not compare one NIT to another or to diagnostic cardiac catheterization; Data for women not reported as a subgroup.
Hovland A, Staub UH, Bjornstad H, et al. Gated SPECT offers improved interobserver agreement compared with echocardiography. Clin Nucl Med. 2010;35(12):927-30. Full-text exclusion reason(s): Data for women not reported as a subgroup; No outcomes of interest. [pmid: 21206222].
Hozumi T, Yoshida K, Ogata Y, et al. Noninvasive assessment of significant left anterior descending coronary artery stenosis by coronary flow velocity reserve with transthoracic color Doppler echocardiography. Circulation. 1998;97(16):1557-62. Full-text exclusion reason(s): No women with symptomatic chest pain, or results are not reported separately for symptomatic subgroup; All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 9593560].
Hsu CC, Chen YW, Hao CL, et al. Comparison of automated 4D-MSPECT and visual analysis for evaluating myocardial perfusion in coronary artery disease. Kaohsiung J Med Sci. 2008;24(9):445-52. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 19073376].
Htwe Htwe S, Edell SL, Cacciabaudo JM. Noninvasive assessment of coronary artery disease in women after menopause: Gated single proton emission computed tomography myocardial perfusion imaging versus stress echocardiography. Ultrasound Quarterly. 2000;16(3):151-160. Full-text exclusion reason(s): Not original peer-reviewed data or a secondary analysis of RCT, prospective or retrospective observational study, or registry.
Hu SJ, Liu SX, Katus HA, et al. The value of contrast dobutamine stress echocardiography on detecting coronary artery disease in overweight and obese patients. Can J Cardiol. 2007;23(11):885-9. Full-text exclusion reason(s): All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 17876380].
Huang PJ, Ho YL, Wu CC, et al. Simultaneous dobutamine stress echocardiography and thallium-201 perfusion imaging for the detection of coronary artery disease. Cardiology. 1997;88(6):556-62. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 9397312].
Huang PJ, Yen RF, Chieng PU, et al. Do beta-blockers affect the diagnostic sensitivity of dobutamine stress thallium-201 single photon emission computed tomographic imaging?. J Nucl Cardiol. 1998;5(1):34-9. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 9504871].
Huber S, Huber M, Dees D, et al. Usefulness of multislice spiral computed tomography coronary angiography in patients with acute chest pain in the emergency department. J Cardiovasc Comput Tomogr. 2007;1(1):29-37. Full-text exclusion reason(s): Study does not compare one NIT to another or to diagnostic cardiac catheterization; Data for women not reported as a subgroup. [pmid: 19083874].
Huikuri HV, Airaksinen KE, Ikaheimo MJ, et al. Detection of coronary artery disease by dipyridamole thallium tomography in mitral valve stenosis. Am J Cardiol. 1989;63(1):124-6. Full-text exclusion reason(s): No women with symptomatic chest pain, or results are not reported separately for symptomatic subgroup. [pmid: 2783295].
Huixing D, Aiqun M, Aimin Y, et al. Clinical evaluation of Technetium-99m sestamibi myocardial perfusion SPECT in diabetes with suspected coronary artery diseases. Journal of Medical Colleges of PLA. 2010;25(4):220-225. Full-text exclusion reason(s): No women with symptomatic chest pain, or results are not reported separately for symptomatic subgroup; Data for women not reported as a subgroup.
Hung GU, Lee KW, Chen CP, et al. Relationship of transient ischemic dilation in dipyridamole myocardial perfusion imaging and stress-induced changes of functional parameters evaluated by Tl-201 gated SPECT. J Nucl Cardiol. 2005;12(3):268-75. Full-text exclusion reason(s): All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 15944531].
Hung GU, Lee KW, Chen CP, et al. Worsening of left ventricular ejection fraction induced by dipyridamole on Tl-201 gated myocardial perfusion imaging predicts significant coronary artery disease. J Nucl Cardiol. 2006;13(2):225-32. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 16580959].
Hur J, Kim YJ, Lee HJ, et al. Quantification and characterization of obstructive coronary plaques using 64-slice computed tomography: a comparison with intravascular ultrasound. J Comput Assist Tomogr. 2009;33(2):186-92. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 19346843].
Husmann L, Gaemperli O, Schepis T, et al. Accuracy of quantitative coronary angiography with computed tomography and its dependency on plaque composition: plaque composition and accuracy of cardiac CT. Int J Cardiovasc Imaging. 2008;24(8):895-904. Full-text exclusion reason(s): No women with symptomatic chest pain, or results are not reported separately for symptomatic subgroup; All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 18563625].
Husmann L, Herzog BA, Burger IA, et al. Usefulness of additional coronary calcium scoring in low-dose CT coronary angiography with prospective ECG-triggering impact on total effective radiation dose and diagnostic accuracy. Acad Radiol. 2010;17(2):201-6. Full-text exclusion reason(s): No women with symptomatic chest pain, or results are not reported separately for symptomatic subgroup; Data for women not reported as a subgroup. [pmid: 19944630].
Husmann L, Herzog BA, Gaemperli O, et al. Diagnostic accuracy of computed tomography coronary angiography and evaluation of stress-only single-photon emission computed tomography/computed tomography hybrid imaging: comparison of prospective electrocardiogram-triggering vs. retrospective gating. Eur Heart J. 2009;30(5):600-7. Full-text exclusion reason(s): No women with symptomatic chest pain, or results are not reported separately for symptomatic subgroup; All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 19106197].
Husmann L, Scheffel H, Valenta I, et al. Impact of hypertension on the diagnostic accuracy of coronary angiography with computed tomography. Int J Cardiovasc Imaging. 2008;24(7):763-70. Full-text exclusion reason(s): No women with symptomatic chest pain, or results are not reported separately for symptomatic subgroup; Data for women not reported as a subgroup. [pmid: 18369738].
Husmann L, Schepis T, Scheffel H, et al. Comparison of diagnostic accuracy of 64-slice computed tomography coronary angiography in patients with low, intermediate, and high cardiovascular risk. Acad Radiol. 2008;15(4):452-61. Full-text exclusion reason(s): No women with symptomatic chest pain, or results are not reported separately for symptomatic subgroup; Data for women not reported as a subgroup. [pmid: 18342770].
Husmann L, Valenta I, Gaemperli O, et al. Feasibility of low-dose coronary CT angiography: first experience with prospective ECG-gating. Eur Heart J. 2008;29(2):191-7. Full-text exclusion reason(s): No women with symptomatic chest pain, or results are not reported separately for symptomatic subgroup; All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 18089704].
Husmann L, Wiegand M, Valenta I, et al. Diagnostic accuracy of myocardial perfusion imaging with single photon emission computed tomography and positron emission tomography: a comparison with coronary angiography. Int J Cardiovasc Imaging. 2008;24(5):511-8. Full-text exclusion reason(s): No women with symptomatic chest pain, or results are not reported separately for symptomatic subgroup; All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 18158612].
Husser O, Bodi V, Sanchis J, et al. Additional diagnostic value of systolic dysfunction induced by dipyridamole stress cardiac magnetic resonance used in detecting coronary artery disease. Rev Esp Cardiol. 2009;62(4):383-91. Full-text exclusion reason(s): No women with symptomatic chest pain, or results are not reported separately for symptomatic subgroup; All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 19401123].
Hwang Y, Kim Y, Chung IM, et al. Coronary heart disease risk assessment and characterization of coronary artery disease using coronary CT angiography: comparison of asymptomatic and symptomatic groups. Clin Radiol. 2010;65(8):601-8. Full-text exclusion reason(s): Study does not compare one NIT to another or to diagnostic cardiac catheterization; No outcomes of interest. [pmid: 20599061].
Iglesias-Garriz I, Rodriguez MA, Garcia-Porrero E, et al. Emergency nontraumatic chest pain: use of stress echocardiography to detect significant coronary artery stenosis. J Am Soc Echocardiogr. 2005;18(11):1181-6. Full-text exclusion reason(s): Study does not compare one NIT to another or to diagnostic cardiac catheterization; Data for women not reported as a subgroup. [pmid: 16275527].
Ikonen AE, Manninen HI, Vainio P, et al. Three-dimensional respiratory-gated coronary MR angiography with reference to X-ray coronary angiography. Acta Radiol. 2003;44(6):583-9. Full-text exclusion reason(s): All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 14616201].
Imamura Y, Fukuyama T, Nishimura S, et al. Normal myocardial perfusion scan portends a benign prognosis independent from the pretest probability of coronary artery disease. Sub-analysis of the J-ACCESS study. J Cardiol. 2009;54(1):93-100. Full-text exclusion reason(s): No women with symptomatic chest pain, or results are not reported separately for symptomatic subgroup; Data for women not reported as a subgroup. [pmid: 19632527].
Ingul CB, Stoylen A, Slordahl SA, et al. Automated analysis of myocardial deformation at dobutamine stress echocardiography: an angiographic validation. J Am Coll Cardiol. 2007;49(15):1651-9. Full-text exclusion reason(s): No women with symptomatic chest pain, or results are not reported separately for symptomatic subgroup; Data for women not reported as a subgroup. [pmid: 17433958].
Isaac D, Walling A. Clinical evaluation of women with ischemic heart disease: diagnosis and noninvasive testing. Can J Cardiol. Suppl D. 2001;17:38D-48D. Full-text exclusion reason(s): Not a clinical study report.
Ishida N, Sakuma H, Motoyasu M, et al. Noninfarcted myocardium: correlation between dynamic first-pass contrast-enhanced myocardial MR imaging and quantitative coronary angiography. Radiology. 2003;229(1):209-16. Full-text exclusion reason(s): No women with symptomatic chest pain, or results are not reported separately for symptomatic subgroup; Data for women not reported as a subgroup. [pmid: 12944596].
Ishii K, Imai M, Suyama T, et al. Exercise-induced post-ischemic left ventricular delayed relaxation or diastolic stunning: is it a reliable marker in detecting coronary artery disease?. J Am Coll Cardiol. 2009;53(8):698-705. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 19232903].
Iskandrian AE, Heo J, Nallamothu N. Detection of coronary artery disease in women with use of stress single-photon emission computed tomography myocardial perfusion imaging. J Nucl Cardiol. 1997;4(4):329-35. Full-text exclusion reason(s): Not original peer-reviewed data or a secondary analysis of RCT, prospective or retrospective observational study, or registry. [pmid: 9278880].
Iskandrian AS, Chae SC, Heo J, et al. Independent and incremental prognostic value of exercise single-photon emission computed tomographic (SPECT) thallium imaging in coronary artery disease. J Am Coll Cardiol. 1993;22(3):665-70. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 8354796].
Iskandrian AS, Hakki AH, Kane-Marsch S. Exercise thallium-201 scintigraphy in men with nondiagnostic exercise electrocardiograms. Prognostic implications. Arch Intern Med. 1986;146(11):2189-93. Full-text exclusion reason(s): Population does not include women ≥ age 18; Data for women not reported as a subgroup. [pmid: 3778048].
Iskandrian AS, Hakki AH, Kane-Marsch S. Prognostic implications of exercise thallium-201 scintigraphy in patients with suspected or known coronary artery disease. Am Heart J. 1985;110(1 Pt 1):135-43. Full-text exclusion reason(s): Study does not compare one NIT to another or to diagnostic cardiac catheterization; Data for women not reported as a subgroup. [pmid: 4013972].
Iskandrian AS, Heo J, Decoskey D, et al. Use of exercise thallium-201 imaging for risk stratification of elderly patients with coronary artery disease. Am J Cardiol. 1988;61(4):269-72. Full-text exclusion reason(s): Study does not compare one NIT to another or to diagnostic cardiac catheterization; Data for women not reported as a subgroup. [pmid: 3341202].
Iskandrian AS, Heo J, Kong B, et al. Effect of exercise level on the ability of thallium-201 tomographic imaging in detecting coronary artery disease: analysis of 461 patients. J Am Coll Cardiol. 1989;14(6):1477-86. Full-text exclusion reason(s): All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 2809007].
Iskandrian AS, Johnson J, Le TT, et al. Comparison of the treadmill exercise score and single-photon emission computed tomographic thallium imaging in risk assessment. J Nucl Cardiol. 1994;1(2 Pt 1):144-9. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 9420681].
Isma’eel H, Shamseddeen W, El Khoury M, et al. Diabetes supersedes dobutamine stress echocardiography in predicting cardiac events in female patients. Clin Exp Obstet Gynecol. 2010;37(3):197-200. Full-text exclusion reason(s): Study does not compare one NIT to another or to diagnostic cardiac catheterization. [pmid: 21077524].
Ismail G, Lo E, Sada M, et al. Long-term prognosis of patients with a normal exercise echocardiogram and clinical suspicion of myocardial ischemia. Am J Cardiol. 1995;75(14):934-6. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 7733004].
Isobe S, Sato K, Sugiura K, et al. Feasibility of intravenous administration of landiolol hydrochloride for multislice computed tomography coronary angiography: initial experience. Circ J. 2008;72(11):1814-20. Full-text exclusion reason(s): All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 18827370].
Iwasaki K, Matsumoto T, Aono H, et al. Prevalence of subclinical atherosclerosis in asymptomatic patients with low-to-intermediate risk by 64-slice computed tomography. Coron Artery Dis. 2011;22(1):18-25. Full-text exclusion reason(s): No women with symptomatic chest pain, or results are not reported separately for symptomatic subgroup; Data for women not reported as a subgroup. [pmid: 21160291].
Iwasaki K, Matsumoto T, Aono H, et al. Relationship between epicardial fat measured by 64-multidetector computed tomography and coronary artery disease. Clin Cardiol. 2011;34(3):166-71. Full-text exclusion reason(s): Data for women not reported as a subgroup; No outcomes of interest. [pmid: 21337349].
Iwase M, Fukui M, Tamagaki H, et al. Advantages and disadvantages of dobutamine stress echocardiography compared with treadmill exercise electrocardiography in detecting ischemia. Jpn Circ J. 1996;60(12):954-60. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 8996686].
Jahnke C, Gebker R, Manka R, et al. Navigator-gated 3D blood oxygen level-dependent CMR at 3.0-T for detection of stress-induced myocardial ischemic reactions. JACC Cardiovasc Imaging. 2010;3(4):375-84. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 20394899].
Jahnke C, Paetsch I, Nehrke K, et al. Rapid and complete coronary arterial tree visualization with magnetic resonance imaging: feasibility and diagnostic performance. Eur Heart J. 2005;26(21):2313-9. Full-text exclusion reason(s): All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 15987709].
Jahnke C, Paetsch I, Schnackenburg B, et al. Coronary MR angiography with steady-state free precession: individually adapted breath-hold technique versus free-breathing technique. Radiology. 2004;232(3):669-76. Full-text exclusion reason(s): All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 15284430].
Jahnke C, Paetsch I, Schnackenburg B, et al. Comparison of radial and Cartesian imaging techniques for MR coronary angiography. J Cardiovasc Magn Reson. 2004;6(4):865-75. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 15646890].
Jain A, McClelland RL, Polak JF, et al. Cardiovascular imaging for assessing cardiovascular risk in asymptomatic men versus women: the multi-ethnic study of atherosclerosis (MESA). Circ Cardiovasc Imaging. 2011;4(1):8-15. Full-text exclusion reason(s): No data for NITs of interest (ECG, ECHO, SPECT, PET, CMR, CTA). [pmid: 21068189].
Janne d’Othee B, Siebert U, Cury R, et al. A systematic review on diagnostic accuracy of CT-based detection of significant coronary artery disease. Eur J Radiol. 2008;65(3):449-61. Full-text exclusion reason(s): Not original peer-reviewed data or a secondary analysis of RCT, prospective or retrospective observational study, or registry. [pmid: 17590554].
Javadrashid R, Salehi A, Tarzamni MK, et al. Diagnostic efficacy of coronary calcium score in the assessment of significant coronary artery stenosis. Kardiol Pol. 2010;68(3):285-91. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 20411452].
Jeetley P, Burden L, Greaves K, et al. Prognostic value of myocardial contrast echocardiography in patients presenting to hospital with acute chest pain and negative troponin. Am J Cardiol. 2007;99(10):1369-73. Full-text exclusion reason(s): All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 17493462].
Jeetley P, Burden L, Senior R. Stress echocardiography is superior to exercise ECG in the risk stratification of patients presenting with acute chest pain with negative Troponin. Eur J Echocardiogr. 2006;7(2):155-64. Full-text exclusion reason(s): All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 15967730].
Jeetley P, Burden L, Stoykova B, et al. Clinical and economic impact of stress echocardiography compared with exercise electrocardiography in patients with suspected acute coronary syndrome but negative troponin: a prospective randomized controlled study. Eur Heart J. 2007;28(2):204-11. Full-text exclusion reason(s): All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 17227784].
Jeetley P, Hickman M, Kamp O, et al. Myocardial contrast echocardiography for the detection of coronary artery stenosis: a prospective multicenter study in comparison with single-photon emission computed tomography. J Am Coll Cardiol. 2006;47(1):141-5. Full-text exclusion reason(s): All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 16386678].
Jelinek JS, Murphey MD, Welker JA, et al. Diagnosis of primary bone tumors with image-guided percutaneous biopsy: experience with 110 tumors. Radiology. 2002;223(3):731-7. Full-text exclusion reason(s): No data for NITs of interest (ECG, ECHO, SPECT, PET, CMR, CTA). [pmid: 12034942].
Jengo JA, Freeman R, Brizendine M, et al. Detection of coronary artery disease: comparison of exercise stress radionuclide angiocardiography and thallium stress perfusion scanning. Am J Cardiol. 1980;45(3):535-41. Full-text exclusion reason(s): All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 7355750].
Jeong DW, Choo KS, Baik SK, et al. Step-and-shoot prospectively ECG-gated versus retrospectively ECG-gated with tube current modulation coronary CT angiography using the 128-slice MDCT: comparison of image quality and radiation dose. Acta Radiol. 2011;52(2):155-60. Full-text exclusion reason(s): No women with symptomatic chest pain, or results are not reported separately for symptomatic subgroup; Study does not compare one NIT to another or to diagnostic cardiac catheterization; Data for women not reported as a subgroup. [pmid: 21498343].
Jeong HC, Ahn Y, Ko JS, et al. The role of 64-slice multi-detector computed tomography in the detection of subclinical atherosclerosis of the coronary artery. Int J Cardiovasc Imaging. 2010;26(Suppl 2):253-9. Full-text exclusion reason(s): No women with symptomatic chest pain, or results are not reported separately for symptomatic subgroup; Study does not compare one NIT to another or to diagnostic cardiac catheterization; Data for women not reported as a subgroup. [pmid: 20922490].
Jiang B, Gai L, Sun Z, et al. The combination of 64 multislice CT angiography and optical coherence tomography optimally characterizes coronary plaques. Acta Cardiol. 2011;66(2):213-8. Full-text exclusion reason(s): All women in the study are known to have CAD; Data for women not reported as a subgroup; No outcomes of interest. [pmid: 21591580].
Jimenez-Hoyuela Garcia, JM Robledo, Carmona J, Ortega Lozano S, et al. Myocardial perfusion scintigraphy in the emergency department for the evaluation and triage of patients with chest pain and a non-diagnostic electrocardiogram. Gammagrafia de perfusion miocardica en el servicio de urgencias para la evaluacion y triage de pacientes con dolor toracico y electrocardiograma no diagnostico. Investigacion Cardiovascular. 2006;9(1):7-18. Full-text exclusion reason(s): Full-text unobtainable.
Jinzaki M, Sato K, Tanami Y, et al. Diagnostic accuracy of angiographic view image for the detection of coronary artery stenoses by 64-detector row CT: a pilot study comparison with conventional post-processing methods and axial images alone. Circ J. 2009;73(4):691-8. Full-text exclusion reason(s): All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 19225204].
Johansen AH, Poulsen TS, Hoilund-Carlsen PF, et al. Myocardial perfusion imaging and coronary angiography in patients with known or suspected stable angina pectoris. Dan Med Bull. 2001;48(2):80-3. Full-text exclusion reason(s): All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 11414123].
John RM, Taggart PI, Sutton PM, et al. Vasodilator myocardial perfusion imaging: demonstration of local electrophysiological changes of ischaemia. Br Heart J. 1992;68(1):21-30. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 1515287].
Johnson NP, Schimmel DR Jr, Dyer SP, et al. Survival by stress modality in patients with a normal myocardial perfusion study. Am J Cardiol. 2011;107(7):986-9. Full-text exclusion reason(s): All women in the study are known to have CAD; Study does not compare one NIT to another or to diagnostic cardiac catheterization; Data for women not reported as a subgroup. [pmid: 21256467].
Johnson TR, Nikolaou K, Busch S, et al. Diagnostic accuracy of dual-source computed tomography in the diagnosis of coronary artery disease. Invest Radiol. 2007;42(10):684-91. Full-text exclusion reason(s): All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 17984765].
Johnson TR, Nikolaou K, Wintersperger BJ, et al. ECG-gated 64-MDCT angiography in the differential diagnosis of acute chest pain. AJR Am J Roentgenol. 2007;188(1):76-82. Full-text exclusion reason(s): All women in the study are known to have CAD; Study does not compare one NIT to another or to diagnostic cardiac catheterization; Data for women not reported as a subgroup. [pmid: 17179348].
Joint Commission. Radiation risks of diagnostic imaging. Sentinel Event Alert. 2011;(47):1-4. Full-text exclusion reason(s): Not a clinical study report.
Jonsbu E, Dammen T, Morken G, et al. Cardiac and psychiatric diagnoses among patients referred for chest pain and palpitations. Scand Cardiovasc J. 2009;43(4):256-9. Full-text exclusion reason(s): Study does not compare one NIT to another or to diagnostic cardiac catheterization; Data for women not reported as a subgroup; No outcomes of interest. [pmid: 19431049].
Kachenoura N, Gaspar T, Lodato JA, et al. Combined assessment of coronary anatomy and myocardial perfusion using multidetector computed tomography for the evaluation of coronary artery disease. Am J Cardiol. 2009;103(11):1487-94. Full-text exclusion reason(s): No women with symptomatic chest pain, or results are not reported separately for symptomatic subgroup; Data for women not reported as a subgroup. [pmid: 19463504].
Kaiser C, Bremerich J, Haller S, et al. Limited diagnostic yield of non-invasive coronary angiography by 16-slice multi-detector spiral computed tomography in routine patients referred for evaluation of coronary artery disease. Eur Heart J. 2005;26(19):1987-92. Full-text exclusion reason(s): All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 15972287].
Kajander S, Joutsiniemi E, Saraste M, et al. Cardiac positron emission tomography/computed tomography imaging accurately detects anatomically and functionally significant coronary artery disease. Circulation. 2010;122(6):603-13. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 20660808].
Kajinami K, Seki H, Takekoshi N, et al. Noninvasive prediction of coronary atherosclerosis by quantification of coronary artery calcification using electron beam computed tomography: comparison with electrocardiographic and thallium exercise stress test results. J Am Coll Cardiol. 1995;26(5):1209-21. Full-text exclusion reason(s): No women with symptomatic chest pain, or results are not reported separately for symptomatic subgroup. [pmid: 7594034].
Kaltenbach M, Martin KL, Hopf R. Accuracy of exercise tests in the recognition of coronary-artery stenosis. Comparison between post-exercise ECG and coronary arteriogram (author’s transl). Dtsch Med Wochenschr. 1976;101(52):1907-11. Full-text exclusion reason(s): Non-English. [pmid: 1001216].
Kamal AM, Fattah AA, Pancholy S, et al. Prognostic value of adenosine single-photon emission computed tomographic thallium imaging in medically treated patients with angiographic evidence of coronary artery disease. J Nucl Cardiol. 1994;1(3):254-61. Full-text exclusion reason(s): All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 9420708].
Kaminek M, Myslivecek M, Skvarilova M, et al. Prognostic significance of stress tomographic scintigraphy of myocardial perfusion in diabetic patients. Vnitr Lek. 2001;47(11):739-43. Full-text exclusion reason(s): Non-English. [pmid: 11795177].
Kaneko K, Ito M, Takanashi T, et al. Computed tomography and scintigraphy vs. cardiac catheterization for coronary disease screening prior to noncardiac surgery. Internal Medicine. 2010;49(16):1703-1710. Full-text exclusion reason(s): No women with symptomatic chest pain, or results are not reported separately for symptomatic subgroup; All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 20720346].
Kang DH, Kang SJ, Song JM, et al. Efficacy of myocardial contrast echocardiography in the diagnosis and risk stratification of acute coronary syndrome. Am J Cardiol. 2005;96(11):1498-502. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 16310429].
Kang DK, Im NJ, Park SM, et al. CT comparison of visual and computerised quantification of coronary stenosis according to plaque composition. Eur Radiol. 2011;21(4):712-21. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 20890706].
Kang HJ, Lee HY, Na SH, et al. Differential effect of intracoronary infusion of mobilized peripheral blood stem cells by granulocyte colony-stimulating factor on left ventricular function and remodeling in patients with acute myocardial infarction versus old myocardial infarction: the MAGIC Cell-3-DES randomized, controlled trial. Circulation. 2006;114(1 Suppl):I145-51. Full-text exclusion reason(s): No data for NITs of interest (ECG, ECHO, SPECT, PET, CMR, CTA). [pmid: 16820564].
Kanzaki H, Nakatani S, Kandori A, et al. A new screening method to diagnose coronary artery disease using multichannel magnetocardiogram and simple exercise. Basic Res Cardiol. 2003;98(2):124-32. Full-text exclusion reason(s): All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 12607134].
Karabinos IK, Papadopoulos A, Karvouni E, et al. Reliability and safety of dobutamine stress echocardiography for detection of myocardial ischemia-viability: Experience from 802 consecutive studies. Hellenic Journal of Cardiology. 2004;45(2):71-83. Full-text exclusion reason(s): No women with symptomatic chest pain, or results are not reported separately for symptomatic subgroup; Data for women not reported as a subgroup.
Karagiannis SE, Bax JJ, Elhendy A, et al. Enhanced sensitivity of dobutamine stress echocardiography by observing wall motion abnormalities during the recovery phase after acute beta-blocker administration. Am J Cardiol. 2006;97(4):462-5. Full-text exclusion reason(s): All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 16461037].
Karamitsos TD, Arnold JR, Pegg TJ, et al. Tolerance and safety of adenosine stress perfusion cardiovascular magnetic resonance imaging in patients with severe coronary artery disease. Int J Cardiovasc Imaging. 2009;25(3):277-83. Full-text exclusion reason(s): No women with symptomatic chest pain, or results are not reported separately for symptomatic subgroup; All women in the study are known to have CAD; Study does not compare one NIT to another or to diagnostic cardiac catheterization; Data for women not reported as a subgroup. [pmid: 19037746].
Kasalicky J, Kovac I, Lanska V. Pretest clinical diagnosis of coronary artery disease and stress myocardial perfusion scintigram. Nucl Med Rev Cent East Eur. 2001;4(2):89-92. Full-text exclusion reason(s): No women with symptomatic chest pain, or results are not reported separately for symptomatic subgroup; All women in the study are known to have CAD; Data for women not reported as a subgroup; No outcomes of interest. [pmid: 14600891].
Kasprzak JD, Ciesielczyk M, Krzeminska-Pakula M, et al. Myocardial contrast echocardiography using dipyridamole-atropine stress - Preliminary report. Polski Przeglad Kardiologiczny. 2002;4(2):141-148. Full-text exclusion reason(s): Non-English.
Katayama T, Ogata N, Tsuruya Y. Diagnostic accuracy of supine and prone thallium-201 stress myocardial perfusion single-photon emission computed tomography to detect coronary artery disease in inferior wall of left ventricle. Ann Nucl Med. 2008;22(4):317-21. Full-text exclusion reason(s): No women with symptomatic chest pain, or results are not reported separately for symptomatic subgroup; All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 18535883].
Kato S, Kitagawa K, Ishida N, et al. Assessment of coronary artery disease using magnetic resonance coronary angiography: A national multicenter trial. J Am Coll Cardiol. 2010;56(12):983-991. Full-text exclusion reason(s): All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 20828652].
Kaul S, Boucher CA, Newell JB, et al. Determination of the quantitative thallium imaging variables that optimize detection of coronary artery disease. J Am Coll Cardiol. 1986;7(3):527-37. Full-text exclusion reason(s): All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 3950232].
Kaul S, Finkelstein DM, Homma S, et al. Superiority of quantitative exercise thallium-201 variables in determining long-term prognosis in ambulatory patients with chest pain: a comparison with cardiac catheterization. J Am Coll Cardiol. 1988;12(1):25-34. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 3379211].
Kaul S, Lilly DR, Gascho JA, et al. Prognostic utility of the exercise thallium-201 test in ambulatory patients with chest pain: comparison with cardiac catheterization. Circulation. 1988;77(4):745-58. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 3258193].
Kawai Y, Morita K, Nozaki Y, et al. Diagnostic value of (123)I-betamethyl-p-iodophenyl-pentadecanoic acid (BMIPP) single photon emission computed tomography (SPECT) in patients with chest pain - Comparison with rest-stress (99m)Tc-tetrofosmin SPECT and coronary angiography. Circ J. 2004;68(6):547-552. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 15170090].
Kawase Y, Nishimoto M, Hato K, et al. Assessment of coronary artery disease with nicorandil stress magnetic resonance imaging. Osaka City Med J. 2004;50(2):87-94. Full-text exclusion reason(s): No women with symptomatic chest pain, or results are not reported separately for symptomatic subgroup; Data for women not reported as a subgroup. [pmid: 15819303].
Kefer J, Coche E, Legros G, et al. Head-to-head comparison of three-dimensional navigator-gated magnetic resonance imaging and 16-slice computed tomography to detect coronary artery stenosis in patients. J Am Coll Cardiol. 2005;46(1):92-100. Full-text exclusion reason(s): No women with symptomatic chest pain, or results are not reported separately for symptomatic subgroup; Data for women not reported as a subgroup; No outcomes of interest. [pmid: 15992641].
Kelle S, Hamdan A, Schnackenburg B, et al. Dobutamine stress cardiovascular magnetic resonance at 3 Tesla. J Cardiovasc Magn Reson. 2008;10:44. Full-text exclusion reason(s): All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 18844984].
Ketelsen D, Fenchel M, Thomas C, et al. Estimation of radiation exposure of retrospective gated and prospective triggered 128-slice triple-rule-out CT angiography. Acta Radiol. 2011. Full-text exclusion reason(s): Not a clinical study report; Population does not include women ≥ age 18.
Khan A, Nasir K, Khosa F, et al. Prospective gating with 320-MDCT angiography: effect of volume scan length on radiation dose. AJR Am J Roentgenol. 2011;196(2):407-11. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 21257894].
Khan MF, Wesarg S, Gurung J, et al. Facilitating coronary artery evaluation in MDCT using a 3D automatic vessel segmentation tool. Eur Radiol. 2006;16(8):1789-95. Full-text exclusion reason(s): No women with symptomatic chest pain, or results are not reported separately for symptomatic subgroup; All women in the study are known to have CAD; Data for women not reported as a subgroup; No outcomes of interest. [pmid: 16528555].
Khare RK, Courtney DM, Powell ES, et al. Sixty-four-slice computed tomography of the coronary arteries: cost-effectiveness analysis of patients presenting to the emergency department with low-risk chest pain. Acad Emerg Med. 2008;15(7):623-32. Full-text exclusion reason(s): Not original peer-reviewed data or a secondary analysis of RCT, prospective or retrospective observational study, or registry. [pmid: 19086322].
Khattar RS, Senior R, Lahiri A. Assessment of myocardial perfusion and contractile function by inotropic stress Tc-99m sestamibi SPECT imaging and echocardiography for optimal detection of multivessel coronary artery disease. Heart. 1998;79(3):274-80. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 9602662].
Khorsand A, Graf S, Sochor H, et al. Automated assessment of myocardial SPECT perfusion scintigraphy: a comparison of different approaches of case-based reasoning. Artif Intell Med. 2007;40(2):103-13. Full-text exclusion reason(s): No women with symptomatic chest pain, or results are not reported separately for symptomatic subgroup; Data for women not reported as a subgroup; No outcomes of interest. [pmid: 17451921].
Khorsand A, Haddad M, Graf S, et al. Automated assessment of dipyridamole 201Tl myocardial SPECT perfusion scintigraphy by case-based reasoning. J Nucl Med. 2001;42(2):189-93. Full-text exclusion reason(s): No women with symptomatic chest pain, or results are not reported separately for symptomatic subgroup; Data for women not reported as a subgroup; No outcomes of interest. [pmid: 11216515].
Kiat H, Maddahi J, Roy LT, et al. Comparison of technetium 99m methoxy isobutyl isonitrile and thallium 201 for evaluation of coronary artery disease by planar and tomographic methods. Am Heart J. 1989;117(1):1-11. Full-text exclusion reason(s): Study does not compare one NIT to another or to diagnostic cardiac catheterization; Data for women not reported as a subgroup. [pmid: 2643279].
Kim C, Kwok YS, Heagerty P, et al. Pharmacologic stress testing for coronary disease diagnosis: A meta-analysis. Am Heart J. 2001;142(6):934-44. Full-text exclusion reason(s): Not original peer-reviewed data or a secondary analysis of RCT, prospective or retrospective observational study, or registry. [pmid: 11717594].
Kim J, Lee H, Song S, et al. Efficacy and safety of the computed tomography coronary angiography based approach for patients with acute chest pain at an emergency department: one month clinical follow-up study. J Korean Med Sci. 2010;25(3):466-71. Full-text exclusion reason(s): All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 20191049].
Kim SY, Kim KS, Seung MJ, et al. The culprit lesion score on multi-detector computed tomography can detect vulnerable coronary artery plaque. Int J Cardiovasc Imaging. 2010;26(Suppl 2):245-52. Full-text exclusion reason(s): Data for women not reported as a subgroup; No outcomes of interest. [pmid: 20924792].
Kim TH, Yu SH, Choi SH, et al. Pericardial fat amount is an independent risk factor of coronary artery stenosis assessed by multidetector-row computed tomography: The korean atherosclerosis study 2. Obesity. 2011;19(5):1028-1034. Full-text exclusion reason(s): Study does not compare one NIT to another or to diagnostic cardiac catheterization; Data for women not reported as a subgroup. [pmid: 20948524].
Kim WY, Danias PG, Stuber M, et al. Coronary magnetic resonance angiography for the detection of coronary stenoses. N Engl J Med. 2001;345(26):1863-9. Full-text exclusion reason(s): No women with symptomatic chest pain, or results are not reported separately for symptomatic subgroup; All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 11756576].
Kim YJ, Seo JS, Choi BW, et al. Feasibility and diagnostic accuracy of whole heart coronary MR angiography using free-breathing 3D balanced turbo-field-echo with SENSE and the half-fourier acquisition technique. Korean J Radiol. 2006;7(4):235-42. Full-text exclusion reason(s): All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 17143026].
Kirchin MA, Pirovano G, Venetianer C, et al. Safety assessment of gadobenate dimeglumine (MultiHance): extended clinical experience from phase I studies to post-marketing surveillance. J Magn Reson Imaging. 2001;14(3):281-94. Full-text exclusion reason(s): All women in the study are known to have CAD; Study does not compare one NIT to another or to diagnostic cardiac catheterization. [pmid: 11536405].
Kiriyama T, Toba M, Fukushima Y, et al. Discordance between the morphological and physiological information of 64-slice MSCT coronary angiography and myocardial perfusion imaging in patients with intermediate to high probability of coronary artery disease. Circ J. 2011;75(7):1670-1677. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 21566340].
Kirschbaum SW, Nieman K, Springeling T, et al. Non-invasive diagnostic workup of patients with suspected stable angina by combined computed tomography coronary angiography and magnetic resonance perfusion imaging. Circ J. 2011;75(7):1678-1684. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 21666369].
Kisacik HL, Ozdemir K, Altinyay E, et al. Comparison of exercise stress testing with simultaneous dobutamine stress echocardiography and technetium-99m isonitrile single-photon emission computerized tomography for diagnosis of coronary artery disease. Eur Heart J. 1996;17(1):113-9. Full-text exclusion reason(s): All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 8682117].
Kitagawa K, Sakuma H, Nagata M, et al. Diagnostic accuracy of stress myocardial perfusion MRI and late gadolinium-enhanced MRI for detecting flow-limiting coronary artery disease: a multicenter study. Eur Radiol. 2008;18(12):2808-16. Full-text exclusion reason(s): All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 18651152].
Klein AJ, Garcia JA, Hudson PA, et al. Safety and efficacy of dual-axis rotational coronary angiography vs. standard coronary angiography. Catheter Cardiovasc Interv. 2011;77(6):820-7. Full-text exclusion reason(s): No data for NITs of interest (ECG, ECHO, SPECT, PET, CMR, CTA); Data for women not reported as a subgroup. [pmid: 20853352].
Klein C, Gebker R, Kokocinski T, et al. Combined magnetic resonance coronary artery imaging, myocardial perfusion and late gadolinium enhancement in patients with suspected coronary artery disease. J Cardiovasc Magn Reson. 2008;10:45. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 18928521].
Klem I, Heitner JF, Shah DJ, et al. Improved detection of coronary artery disease by stress perfusion cardiovascular magnetic resonance with the use of delayed enhancement infarction imaging. J Am Coll Cardiol. 2006;47(8):1630-8. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 16631001].
Klumpp B, Hoevelborn T, Fenchel M, et al. Magnetic resonance myocardial perfusion imaging-First experience at 3.0T. Eur J Radiol. 2009;69(1):165-72. Full-text exclusion reason(s): All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 18024045].
Klumpp BD, Seeger A, Doesch C, et al. High resolution myocardial magnetic resonance stress perfusion imaging at 3 T using a 1 M contrast agent. Eur Radiol. 2010;20(3):533-41. Full-text exclusion reason(s): All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 19760241].
Knez A, Becker CR, Leber A, et al. Usefulness of multislice spiral computed tomography angiography for determination of coronary artery stenoses. Am J Cardiol. 2001;88(10):1191-4. Full-text exclusion reason(s): No women with symptomatic chest pain, or results are not reported separately for symptomatic subgroup; All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 11703970].
Ko SM, Kim NR, Kim DH, et al. Assessment of image quality and radiation dose in prospective ECG-triggered coronary CT angiography compared with retrospective ECG-gated coronary CT angiography. Int J Cardiovasc Imaging. Suppl 1. 2010;26:93-101. Full-text exclusion reason(s): Study does not compare one NIT to another or to diagnostic cardiac catheterization; Data for women not reported as a subgroup. [pmid: 20033490].
Koh AS, Flores JLS, Keng FYJ, et al. Evaluation of the American College of Cardiology Foundation/American Society of Nuclear Cardiology appropriateness criteria for SPECT myocardial perfusion imaging in an Asian tertiary cardiac center. J Nucl Cardiol. 2011;18(2):323-330. Full-text exclusion reason(s): Study does not compare one NIT to another or to diagnostic cardiac catheterization; Data for women not reported as a subgroup; No outcomes of interest.
Koide Y, Yotsukura M, Yoshino H, et al. Usefulness of QT dispersion immediately after exercise as an indicator of coronary stenosis independent of gender or exercise-induced ST-segment depression. Am J Cardiol. 2000;86(12):1312-7. Full-text exclusion reason(s): Not original peer-reviewed data or a secondary analysis of RCT, prospective or retrospective observational study, or registry. [pmid: 11113404].
Koide Y, Yotsukura M, Yoshino H, et al. Value of QT dispersion in the interpretation of treadmill exercise electrocardiograms of patients without exercise-induced chest pain or ST-segment depression. Am J Cardiol. 2000;85(9):1094-9. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 10781758].
Kolnes K, Velle OH, Hareide S, et al. Multislice computed tomography coronary angiography at a local hospital: Pitfalls and potential. Acta Radiol. 2006;47(7):680-6. Full-text exclusion reason(s): All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 16950705].
Kong G, Lichtenstein M, Gunawardana D, et al. Fixed defect on rest/stress Tc-99m sestamibi study underestimates myocardial ischemia: comparison with 24-hour thallium-201 study for short- and intermediate-term follow-up. Clin Nucl Med. 2008;33(3):168-71. Full-text exclusion reason(s): All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 18287837].
Konieczynska M, Tracz W, Pasowicz M, et al. Use of coronary calcium score in the assessment of atherosclerotic lesions in coronary arteries. Kardiol Pol. 2006;64(10):1073-9. discussion 1080–1. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 17089239].
Kontos MC, Dilsizian V, Weiland F, et al. Iodofiltic acid I 123 (BMIPP) fatty acid imaging improves initial diagnosis in emergency department patients with suspected acute coronary syndromes: a multicenter trial. J Am Coll Cardiol. 2010;56(4):290-9. Full-text exclusion reason(s): All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 20633821].
Kontos MC, Hinchman D, Cunningham M, et al. Comparison of contrast echocardiography with single-photon emission computed tomographic myocardial perfusion imaging in the evaluation of patients with possible acute coronary syndromes in the emergency department. Am J Cardiol. 2003;91(9):1099-102. Full-text exclusion reason(s): All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 12714154].
Kontos MC, Jesse RL, Tatum JL, et al. Coronary angiographic findings in patients with cocaine-associated chest pain. J Emerg Med. 2003;24(1):9-13. Full-text exclusion reason(s): All women in the study are known to have CAD; Study does not compare one NIT to another or to diagnostic cardiac catheterization; Data for women not reported as a subgroup; No outcomes of interest. [pmid: 12554033].
Kontos MC, Schmidt KL, McCue M, et al. A comprehensive strategy for the evaluation and triage of the chest pain patient: a cost comparison study. J Nucl Cardiol. 2003;10(3):284-90. Full-text exclusion reason(s): All women in the study are known to have CAD; Study does not compare one NIT to another or to diagnostic cardiac catheterization; Data for women not reported as a subgroup; No outcomes of interest. [pmid: 12794627].
Kopp AF, Schroeder S, Kuettner A, et al. Non-invasive coronary angiography with high resolution multidetector-row computed tomography. Results in 102 patients. Eur Heart J. 2002;23(21):1714-25. Full-text exclusion reason(s): All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 12398830].
Korosoglou G, da Silva KG Jr, Labadze N, et al. Real-time myocardial contrast echocardiography for pharmacologic stress testing: is quantitative estimation of myocardial blood flow reserve necessary?. J Am Soc Echocardiogr. 2004;17(1):1-9. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 14712180].
Korosoglou G, Dubart AE, DaSilva KG Jr, et al. Real-time myocardial perfusion imaging for pharmacologic stress testing: added value to single photon emission computed tomography. Am Heart J. 2006;151(1):131-8. Full-text exclusion reason(s): All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 16368304].
Korosoglou G, Elhmidi Y, Steen H, et al. Prognostic value of high-dose dobutamine stress magnetic resonance imaging in 1,493 consecutive patients: assessment of myocardial wall motion and perfusion. J Am Coll Cardiol. 2010;56(15):1225-34. Full-text exclusion reason(s): Study does not compare one NIT to another or to diagnostic cardiac catheterization; Data for women not reported as a subgroup. [pmid: 20883929].
Korosoglou G, Labadze N, Hansen A, et al. Usefulness of real-time myocardial perfusion imaging in the evaluation of patients with first time chest pain. Am J Cardiol. 2004;94(10):1225-31. Full-text exclusion reason(s): All women in the study are known to have CAD. [pmid: 15541235].
Korosoglou G, Lehrke S, Wochele A, et al. Strain-encoded CMR for the detection of inducible ischemia during intermediate stress. JACC Cardiovasc Imaging. 2010;3(4):361-71. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 20394897].
Kostkiewicz M, Konieczynska M, Szot WM, et al. Comparison between (99m)Tc-MIBI myocardial perfusion SPECT and multi-slice computed tomography for identifying and assessing coronary artery disease. Hellenic Journal of Nuclear Medicine. 2004;7(1):48-51. Full-text exclusion reason(s): All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 16868642].
Kowatsch I, Tsutsui JM, Osorio AF, et al. Head-to-head comparison of dobutamine and adenosine stress real-time myocardial perfusion echocardiography for the detection of coronary artery disease. J Am Soc Echocardiogr. 2007;20(9):1109-17. Full-text exclusion reason(s): All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 17566697].
Krenning BJ, Geleijnse ML, Poldermans D, et al. Methodological analysis of diagnostic dobutamine stress echocardiography studies. Echocardiography. 2004;21(8):725-36. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 15546374].
Krenning BJ, Nemes A, Soliman OI, et al. Contrast-enhanced three-dimensional dobutamine stress echocardiography: between Scylla and Charybdis?. Eur J Echocardiogr. 2008;9(6):757-60. Full-text exclusion reason(s): All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 18490296].
Krishnam MS, Tomasian A, Iv M, et al. Left ventricular ejection fraction using 64-slice CT coronary angiography and new evaluation software: initial experience. Br J Radiol. 2008;81(966):450-5. Full-text exclusion reason(s): All women in the study are known to have CAD; Study does not compare one NIT to another or to diagnostic cardiac catheterization; Data for women not reported as a subgroup; No outcomes of interest. [pmid: 18347027].
Krittayaphong R, Boonyasirinant T, Saiviroonporn P, et al. Myocardial perfusion cardiac magnetic resonance for the diagnosis of coronary artery disease: do we need rest images?. Int J Cardiovasc Imaging. Suppl 1. 2009;25:139-48. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 19132546].
Krittayaphong R, Chaithiraphan V, Maneesai A, et al. Prognostic value of combined magnetic resonance myocardial perfusion imaging and late gadolinium enhancement. Int J Cardiovasc Imaging. 2011;27(5):705-14. Full-text exclusion reason(s): Study does not compare one NIT to another or to diagnostic cardiac catheterization; Data for women not reported as a subgroup. [pmid: 21479846].
Krittayaphong R, Mahanonda N, Kangkagate C, et al. Accuracy of magnetic resonance imaging in the diagnosis of coronary artery disease. J Med Assoc Thai. Suppl 1. 2003;86:S59-66. Full-text exclusion reason(s): No women with symptomatic chest pain, or results are not reported separately for symptomatic subgroup; Data for women not reported as a subgroup. [pmid: 12866770].
Krittayaphong R, Saiviroonporn P, Boonyasirinant T, et al. Prevalence and prognosis of myocardial scar in patients with known or suspected coronary artery disease and normal wall motion. J Cardiovasc Magn Reson. 2011;13(1):2. Full-text exclusion reason(s): Study does not compare one NIT to another or to diagnostic cardiac catheterization; Data for women not reported as a subgroup. [pmid: 21211011].
Krzanowski M, Bodzon W, Brzostek T, et al. Value of transthoracic echocardiography for the detection of high-grade coronary artery stenosis: prospective evaluation in 50 consecutive patients scheduled for coronary angiography. J Am Soc Echocardiogr. 2000;13(12):1091-9. Full-text exclusion reason(s): No data for NITs of interest (ECG, ECHO, SPECT, PET, CMR, CTA). [pmid: 11119277].
Kuettner A, Beck T, Drosch T, et al. Diagnostic accuracy of noninvasive coronary imaging using 16-detector slice spiral computed tomography with 188 ms temporal resolution. J Am Coll Cardiol. 2005;45(1):123-7. Full-text exclusion reason(s): No outcomes of interest. [pmid: 15629385].
Kuettner A, Beck T, Drosch T, et al. Image quality and diagnostic accuracy of non-invasive coronary imaging with 16 detector slice spiral computed tomography with 188 ms temporal resolution. Heart. 2005;91(7):938-41. Full-text exclusion reason(s): All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 15958366].
Kuettner A, Trabold T, Schroeder S, et al. Noninvasive detection of coronary lesions using 16-detector multislice spiral computed tomography technology: initial clinical results. J Am Coll Cardiol. 2004;44(6):1230-7. Full-text exclusion reason(s): No women with symptomatic chest pain, or results are not reported separately for symptomatic subgroup; Data for women not reported as a subgroup. [pmid: 15364324].
Kuijpers D, van Dijkman PR, Janssen CH, et al. Dobutamine stress MRI. Part II. Risk stratification with dobutamine cardiovascular magnetic resonance in patients suspected of myocardial ischemia. Eur Radiol. 2004;14(11):2046-52. Full-text exclusion reason(s): No women with symptomatic chest pain, or results are not reported separately for symptomatic subgroup; All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 15278416].
Kumar R, Patel CD, Marwah A, et al. Detection of coronary artery disease by stress thallium scintigraphy in diabetic patients. Nucl Med Commun. 2001;22(3):287-9. Full-text exclusion reason(s): No women with symptomatic chest pain, or results are not reported separately for symptomatic subgroup; Data for women not reported as a subgroup. [pmid: 11314761].
Kunimasa T, Sato Y, Matsumoto N, et al. Detection of coronary artery disease by free-breathing, whole heart coronary magnetic resonance angiography: our initial experience. Heart Vessels. 2009;24(6):429-33. Full-text exclusion reason(s): No women with symptomatic chest pain, or results are not reported separately for symptomatic subgroup; All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 20108075].
Kuntz KM, Fleischmann KE, Hunink MG, et al. Cost-effectiveness of diagnostic strategies for patients with chest pain. Ann Intern Med. 1999;130(9):709-18. Full-text exclusion reason(s): Not original peer-reviewed data or a secondary analysis of RCT, prospective or retrospective observational study, or registry. [pmid: 10357689].
Kurita A, Chaitman BR, Bourassa MG. Significance of exercise-induced junctional S-T depression in evaluation of coronary artery disease. Am J Cardiol. 1977;40(4):492-7. Full-text exclusion reason(s): All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 910713].
Kurrelmeyer KM. Noninvasive evaluation of women with coronary artery disease. Curr Opin Cardiol. 2002;17(5):464-9. Full-text exclusion reason(s): Not original peer-reviewed data or a secondary analysis of RCT, prospective or retrospective observational study, or registry. [pmid: 12357121].
Kurt M, Shaikh KA, Peterson L, et al. Impact of contrast echocardiography on evaluation of ventricular function and clinical management in a large prospective cohort. J Am Coll Cardiol. 2009;53(9):802-10. Full-text exclusion reason(s): No women with symptomatic chest pain, or results are not reported separately for symptomatic subgroup; All women in the study are known to have CAD; Study does not compare one NIT to another or to diagnostic cardiac catheterization; Data for women not reported as a subgroup; No outcomes of interest. [pmid: 19245974].
Kwok Y, Kim C, Grady D, et al. Meta-analysis of exercise testing to detect coronary artery disease in women. Am J Cardiol. 1999;83(5):660-6. Full-text exclusion reason(s): Not original peer-reviewed data or a secondary analysis of RCT, prospective or retrospective observational study, or registry. [pmid: 10080415].
Kwon SW, Kim YJ, Shim J, et al. Coronary artery calcium scoring does not add prognostic value to standard 64-section CT angiography protocol in low-risk patients suspected of having coronary artery disease. Radiology. 2011;259(1):92-9. Full-text exclusion reason(s): Study does not compare one NIT to another or to diagnostic cardiac catheterization; Data for women not reported as a subgroup. [pmid: 21324842].
Kwong RY, Schussheim AE, Rekhraj S, et al. Detecting acute coronary syndrome in the emergency department with cardiac magnetic resonance imaging. Circulation. 2003;107(4):531-7. Full-text exclusion reason(s): All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 12566362].
La Grutta L, Runza G, Gentile G, et al. Prognostic outcome of routine clinical noninvasive multidetector-row computed tomography coronary angiography in patients with suspected coronary artery disease: a 2-year follow-up study. Radiol Med. 2011;116(4):521-31. Full-text exclusion reason(s): Study does not compare one NIT to another or to diagnostic cardiac catheterization; Data for women not reported as a subgroup. [pmid: 21424315].
LaBounty TM, Earls JP, Leipsic J, et al. Effect of a standardized quality-improvement protocol on radiation dose in coronary computed tomographic angiography. Am J Cardiol. 2010;106(11):1663-7. Full-text exclusion reason(s): No women with symptomatic chest pain, or results are not reported separately for symptomatic subgroup; Study does not compare one NIT to another or to diagnostic cardiac catheterization; Data for women not reported as a subgroup. [pmid: 21094371].
LaBounty TM, Kim RJ, Lin FY, et al. Diagnostic accuracy of coronary computed tomography angiography as interpreted on a mobile handheld phone device. JACC Cardiovasc Imaging. 2010;3(5):482-90. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 20466343].
LaBounty TM, Leipsic J Sr, ichai MB, et al. What is the optimal number of readers needed to achieve high diagnostic accuracy in coronary computed tomographic angiography? A comparison of alternate reader combinations. J Cardiovasc Comput Tomogr. 2010;4(6):384-90. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 21030335].
Ladenheim ML, Pollock BH, Rozanski A, et al. Extent and severity of myocardial hypoperfusion as predictors of prognosis in patients with suspected coronary artery disease. J Am Coll Cardiol. 1986;7(3):464-71. Full-text exclusion reason(s): Study does not compare one NIT to another or to diagnostic cardiac catheterization; Data for women not reported as a subgroup. [pmid: 3950226].
LaManna MM, Mohama R, Slavich IL 3rd, et al. Intravenous adenosine (adenoscan) versus exercise in the noninvasive assessment of coronary artery disease by SPECT. Clin Nucl Med. 1990;15(11):804-5. Full-text exclusion reason(s): All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 2292152].
Lamont DH, Budoff MJ, Shavelle DM, et al. Coronary calcium scanning adds incremental value to patients with positive stress tests. Am Heart J. 2002;143(5):861-7. Full-text exclusion reason(s): No women with symptomatic chest pain, or results are not reported separately for symptomatic subgroup; Data for women not reported as a subgroup. [pmid: 12040349].
Lancellotti P, Benoit T, Rigo P, et al. Dobutamine stress echocardiography versus quantitative technetium-99m sestamibi SPECT for detecting residual stenosis and multivessel disease after myocardial infarction. Heart. 2001;86(5):510-5. Full-text exclusion reason(s): No women with symptomatic chest pain, or results are not reported separately for symptomatic subgroup; All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 11602542].
Lancellotti P, Lebois F, Simon M, et al. Prognostic importance of quantitative exercise Doppler echocardiography in asymptomatic valvular aortic stenosis. Circulation. 2005;112(9 Suppl):I377-82. Full-text exclusion reason(s): No data for NITs of interest (ECG, ECHO, SPECT, PET, CMR, CTA). [pmid: 16159850].
Langer C, Wiemer M, Peterschroder A, et al. Stratification for noninvasive coronary angiography: patient preselection considering atypical angina pectoris, conventional cardiovascular risk assessment, and calcium scoring. Eur J Cardiovasc Prev Rehabil. 2009;16(2):201-9. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 19305353].
Langerak SE, Vliegen HW, Jukema JW, et al. Value of magnetic resonance imaging for the noninvasive detection of stenosis in coronary artery bypass grafts and recipient coronary arteries. Circulation. 2003;107(11):1502-8. Full-text exclusion reason(s): All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 12654607].
Lanza GA, Buffon A, Sestito A, et al. Relation between stress-induced myocardial perfusion defects on cardiovascular magnetic resonance and coronary microvascular dysfunction in patients with cardiac syndrome X. J Am Coll Cardiol. 2008;51(4):466-72. Full-text exclusion reason(s): Study does not compare one NIT to another or to diagnostic cardiac catheterization; Data for women not reported as a subgroup; No outcomes of interest. [pmid: 18222358].
Lanzarini L, Fetiveau R, Poli A, et al. Results of dipyridamole plus atropine echo stress test for the diagnosis of coronary artery disease. Int J Card Imaging. 1995;11(4):233-40. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 8596061].
Laraudogoitia Zaldumbide E, Perez-David E, Larena JA, et al. The value of cardiac magnetic resonance in patients with acute coronary syndrome and normal coronary arteries. Rev Esp Cardiol. 2009;62(9):976-83. Full-text exclusion reason(s): Study does not compare one NIT to another or to diagnostic cardiac catheterization; Data for women not reported as a subgroup; No outcomes of interest. [pmid: 19712618].
Larsen J, Brekke M, Sandvik L, et al. Silent coronary atheromatosis in type 1 diabetic patients and its relation to long-term glycemic control. Diabetes. 2002;51(8):2637-41. Full-text exclusion reason(s): No women with symptomatic chest pain, or results are not reported separately for symptomatic subgroup; Data for women not reported as a subgroup. [pmid: 12145181].
Laspas F, Tsantioti D, Roussakis A, et al. Correlation of radiation dose and heart rate in dual-source computed tomography coronary angiography. Acta Radiol. 2011;52(3):273-7. Full-text exclusion reason(s): Study does not compare one NIT to another or to diagnostic cardiac catheterization; Data for women not reported as a subgroup. [pmid: 21498362].
Latcham AP, Orsinelli DA, Pearson AC. Recognition of the segmental tendency of false-positive dobutamine stress echocardiograms and its effects on test sensitivity and specificity. Am Heart J. 1995;129(5):1047-50. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 7732970].
Lattanzi F, Picano E, Frugoli A, et al. Oral vs intravenous dipyridamole echocardiography for detecting coronary artery disease. Chest. 1992;102(4):1189-92. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 1395766].
Lau GT, Ridley LJ, Schieb MC, et al. Coronary artery stenoses: detection with calcium scoring, CT angiography, and both methods combined. Radiology. 2005;235(2):415-22. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 15858083].
Laufer E, Wahi S, Lim YL. Cost-effectiveness and accuracy of exercise stress echocardiography in the non-invasive diagnosis of coronary heart disease. Aust N Z J Med. 2000;30(6):660-7. Full-text exclusion reason(s): All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 11198573].
Lavoie KL, Fleet RP, Lesperance F, et al. Are exercise stress tests appropriate for assessing myocardial ischemia in patients with major depressive disorder?. Am Heart J. 2004;148(4):621-7. Full-text exclusion reason(s): No women with symptomatic chest pain, or results are not reported separately for symptomatic subgroup; All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 15459592].
Law WY, Yang CC, Chen LK, et al. Retrospective gating vs. prospective triggering for noninvasive coronary angiography: Assessment of image quality and radiation dose using a 256-slice CT scanner with 270 ms gantry rotation. Acad Radiol. 2011;18(1):31-9. Full-text exclusion reason(s): Study does not compare one NIT to another or to diagnostic cardiac catheterization; Data for women not reported as a subgroup. [pmid: 21145027].
Lazoura O, Vlychou M, Vassiou K, et al. 128-detector-row computed tomography coronary angiography evaluating coronary artery disease: who avoids cardiac catheterization?. Angiology. 2010;61(2):174-8. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 19625270].
le Polain de Waroux JB, Pouleur AC, Goffinet C, et al. Combined coronary and late-enhanced multidetector-computed tomography for delineation of the etiology of left ventricular dysfunction: comparison with coronary angiography and contrast-enhanced cardiac magnetic resonance imaging. Eur Heart J. 2008;29(20):2544-51. Full-text exclusion reason(s): No women with symptomatic chest pain, or results are not reported separately for symptomatic subgroup; All women in the study are known to have CAD; Data for women not reported as a subgroup; No outcomes of interest. [pmid: 18762553].
Leao Lima, Rde S, De Lorenzo A, Issa A. Reduced adverse effects with an accelerated dobutamine stress protocol compared with the conventional protocol: a prospective, randomized myocardial perfusion scintigraphy study. Int J Cardiovasc Imaging. 2008;24(1):55-9. Full-text exclusion reason(s): No women with symptomatic chest pain, or results are not reported separately for symptomatic subgroup; All women in the study are known to have CAD; Study does not compare one NIT to another or to diagnostic cardiac catheterization; Data for women not reported as a subgroup. [pmid: 17429754].
Leber AW, Becker A, Knez A, et al. Accuracy of 64-slice computed tomography to classify and quantify plaque volumes in the proximal coronary system: a comparative study using intravascular ultrasound. J Am Coll Cardiol. 2006;47(3):672-7. Full-text exclusion reason(s): All women in the study are known to have CAD; Data for women not reported as a subgroup; No outcomes of interest. [pmid: 16458154].
Leber AW, Johnson T, Becker A, et al. Diagnostic accuracy of dual-source multi-slice CT-coronary angiography in patients with an intermediate pretest likelihood for coronary artery disease. Eur Heart J. 2007;28(19):2354-60. Full-text exclusion reason(s): No women with symptomatic chest pain, or results are not reported separately for symptomatic subgroup; Data for women not reported as a subgroup. [pmid: 17644815].
Leber AW, Knez A, Becker A, et al. Accuracy of multidetector spiral computed tomography in identifying and differentiating the composition of coronary atherosclerotic plaques: a comparative study with intracoronary ultrasound. J Am Coll Cardiol. 2004;43(7):1241-7. Full-text exclusion reason(s): Data for women not reported as a subgroup; No outcomes of interest. [pmid: 15063437].
Leber AW, Knez A, Becker C, et al. Non-invasive intravenous coronary angiography using electron beam tomography and multislice computed tomography. Heart. 2003;89(6):633-9. Full-text exclusion reason(s): All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 12748218].
Leber AW, Knez A, Mukherjee R, et al. Usefulness of calcium scoring using electron beam computed tomography and noninvasive coronary angiography in patients with suspected coronary artery disease. Am J Cardiol. 2001;88(3):219-23. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 11472697].
Leber AW, Knez A, von Ziegler F, et al. Quantification of obstructive and nonobstructive coronary lesions by 64-slice computed tomography: a comparative study with quantitative coronary angiography and intravascular ultrasound. J Am Coll Cardiol. 2005;46(1):147-54. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 15992649].
Lee DH, Youn HJ, Choi YS, et al. Coronary flow reserve is a comprehensive indicator of cardiovascular risk factors in subjects with chest pain and normal coronary angiogram. Circ J. 2010;74(7):1405-14. Full-text exclusion reason(s): Data for women not reported as a subgroup; No outcomes of interest. [pmid: 20484824].
Lee DS, Jang MJ, Cheon GJ, et al. Comparison of the cost-effectiveness of stress myocardial SPECT and stress echocardiography in suspected coronary artery disease considering the prognostic value of false-negative results. J Nucl Cardiol. 2002;9(5):515-22. Full-text exclusion reason(s): Not original peer-reviewed data or a secondary analysis of RCT, prospective or retrospective observational study, or registry. [pmid: 12360132].
Lee DS, Paeng JC, Lee MC. Implication of prognostically significant negative results on prone SPECT. J Nucl Med. 2003;44(10):1641-3. Full-text exclusion reason(s): Not original peer-reviewed data or a secondary analysis of RCT, prospective or retrospective observational study, or registry. [pmid: 14530479].
Lee HJ, Kim JS, Kim YJ, et al. Diagnostic accuracy of 64-slice multidetector computed tomography for selecting coronary artery bypass graft surgery candidates. J Thorac Cardiovasc Surg. 2010. Full-text exclusion reason(s): No women with symptomatic chest pain, or results are not reported separately for symptomatic subgroup; All women in the study are known to have CAD; Data for women not reported as a subgroup; No outcomes of interest.
Lee JH, Crump R, Ellestad MH. Significance of precordial T-wave increase during treadmill stress testing. Am J Cardiol. 1995;76(17):1297-9. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 7503013].
Lee KH, Jang HJ, Lee SC, et al. Myocardial thallium defects in apical hypertrophic cardiomyopathy are associated with a benign prognosis. Thallium defects in apical hypertrophy. Int J Cardiovasc Imaging. 2003;19(5):381-8. Full-text exclusion reason(s): No women with symptomatic chest pain, or results are not reported separately for symptomatic subgroup; Data for women not reported as a subgroup; No outcomes of interest. [pmid: 14609187].
Lee TC, O’Malley PG, Feuerstein I, et al. The prevalence and severity of coronary artery calcification on coronary artery computed tomography in black and white subjects. J Am Coll Cardiol. 2003;41(1):39-44. Full-text exclusion reason(s): No women with symptomatic chest pain, or results are not reported separately for symptomatic subgroup; Data for women not reported as a subgroup; No outcomes of interest. [pmid: 12570942].
Legare JF, Haddad H, Barnes D, et al. Myocardial scintigraphy correlates poorly with coronary angiography in the screening of transplant arteriosclerosis. Can J Cardiol. 2001;17(8):866-72. Full-text exclusion reason(s): No women with symptomatic chest pain, or results are not reported separately for symptomatic subgroup; Data for women not reported as a subgroup; No outcomes of interest. [pmid: 11521129].
Lehman SJ, Abbara S, Cury RC, et al. Significance of cardiac computed tomography incidental findings in acute chest pain. Am J Med. 2009;122(6):543-9. Full-text exclusion reason(s): No women with symptomatic chest pain, or results are not reported separately for symptomatic subgroup; All women in the study are known to have CAD; Study does not compare one NIT to another or to diagnostic cardiac catheterization; Data for women not reported as a subgroup; No outcomes of interest. [pmid: 19486717].
Leipsic J, Labounty TM, Heilbron B, et al. Estimated radiation dose reduction using adaptive statistical iterative reconstruction in coronary CT angiography: the ERASIR study. AJR Am J Roentgenol. 2010;195(3):655-60. Full-text exclusion reason(s): No women with symptomatic chest pain, or results are not reported separately for symptomatic subgroup; Data for women not reported as a subgroup; No outcomes of interest. [pmid: 20729443].
Leipsic J, LaBounty TM, Mancini GB, et al. A prospective randomized controlled trial to assess the diagnostic performance of reduced tube voltage for coronary CT angiography. AJR Am J Roentgenol. 2011;196(4):801-6. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 21427328].
Leischik R, Dworrak B, Littwitz H, et al. Prognostic significance of exercise stress echocardiography in 3329 outpatients (5-year longitudinal study). Int J Cardiol. 2007;119(3):297-305. Full-text exclusion reason(s): No women with symptomatic chest pain, or results are not reported separately for symptomatic subgroup; Data for women not reported as a subgroup. [pmid: 17113169].
Leite WA, Gil MA, Lima VC, et al. Exercise testing early after myocardial infarction: comparison with echocardiography, electrocardiographic monitoring and coronary arteriography. Arq Bras Cardiol. 2008;90(3):176-81. Full-text exclusion reason(s): No women with symptomatic chest pain, or results are not reported separately for symptomatic subgroup; All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 18392397].
Lele RD, Luthra K, Sawant Y. Assessment of diastolic heart function—experience with 16-gated myocardial perfusion SPECT. J Assoc Physicians India. 2008;56:763-8. Full-text exclusion reason(s): No women with symptomatic chest pain, or results are not reported separately for symptomatic subgroup; All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 19263701].
Lerakis S, Janik M, McLean DS, et al. Adenosine stress magnetic resonance imaging in women with low risk chest pain: the Emory University experience. Am J Med Sci. 2010;339(3):216-20. Full-text exclusion reason(s): Study does not compare one NIT to another or to diagnostic cardiac catheterization. [pmid: 20051822].
Leschka S, Alkadhi H, Plass A, et al. Accuracy of MSCT coronary angiography with 64-slice technology: first experience. Eur Heart J. 2005;26(15):1482-7. Full-text exclusion reason(s): No women with symptomatic chest pain, or results are not reported separately for symptomatic subgroup; All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 15840624].
Leschka S, Scheffel H, Desbiolles L, et al. Combining dual-source computed tomography coronary angiography and calcium scoring: added value for the assessment of coronary artery disease. Heart. 2008;94(9):1154-61. Full-text exclusion reason(s): All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 18032458].
Leschka S, Scheffel H, Husmann L, et al. Effect of decrease in heart rate variability on the diagnostic accuracy of 64-MDCT coronary angiography. AJR Am J Roentgenol. 2008;190(6):1583-90. Full-text exclusion reason(s): All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 18492910].
Leschka S, Stolzmann P, Desbiolles L, et al. Diagnostic accuracy of high-pitch dual-source CT for the assessment of coronary stenoses: First experience. Euro Radiol. 2009;19(12):2896-2903. Full-text exclusion reason(s): Data for women not reported as a subgroup.
Lesser JR, Flygenring B, Knickelbine T, et al. Clinical utility of coronary CT angiography: coronary stenosis detection and prognosis in ambulatory patients. Catheter Cardiovasc Interv. 2007;69(1):64-72. Full-text exclusion reason(s): All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 17139675].
Lessick J, Ghersin E, Dragu R, et al. Diagnostic accuracy of myocardial hypoenhancement on multidetector computed tomography in identifying myocardial infarction in patients admitted with acute chest pain syndrome. J Comput Assist Tomogr. 2007;31(5):780-8. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 17895792].
Leta R, Carreras F, Alomar X, et al. Non-invasive coronary angiography with 16 multidetector-row spiral computed tomography: a comparative study with invasive coronary angiography. Rev Esp Cardiol. 2004;57(3):217-24. Full-text exclusion reason(s): Non-English. [pmid: 15056425].
Lethen H, HPT, Kersting S, et al. Validation of noninvasive assessment of coronary flow velocity reserve in the right coronary artery. A comparison of transthoracic echocardiographic results with intracoronary Doppler flow wire measurements. Eur Heart J. 2003;24(17):1567-75. Full-text exclusion reason(s): No data for NITs of interest (ECG, ECHO, SPECT, PET, CMR, CTA). [pmid: 12927192].
Leung DY, Lo ST, Liew CT, et al. Use of functional tests before angiography in patients with normal coronary arteries. Int J Cardiol. 2005;104(3):326-31. Full-text exclusion reason(s): Study does not compare one NIT to another or to diagnostic cardiac catheterization; Data for women not reported as a subgroup; No outcomes of interest. [pmid: 16186064].
Levine MG, McGill CC, Ahlberg AW, et al. Functional assessment with electrocardiographic gated single-photon emission computed tomography improves the ability of technetium-99m sestamibi myocardial perfusion imaging to predict myocardial viability in patients undergoing revascularization. Am J Cardiol. 1999;83(1):1-5. Full-text exclusion reason(s): All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 10073775].
Lewis JF, McGorray SP, Pepine CJ. Assessment of women with suspected myocardial ischemia: review of findings of the Women’s Ischemia Syndrome Evaluation (WISE) Study. Curr Womens Health Rep. 2002;2(2):110-4. Full-text exclusion reason(s): Not original peer-reviewed data or a secondary analysis of RCT, prospective or retrospective observational study, or registry. [pmid: 12116599].
Lewis WR, Ganim R, Sabapathy R. Utility of stress echocardiography in identifying significant coronary artery disease in patients with left bundle-branch block. Crit Pathw Cardiol. 2007;6(3):127-30. Full-text exclusion reason(s): All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 17804973].
Li J, Li X, Wei M, et al. Diagnostic accuracy of dual-source computed tomography in the detection of coronary chronic total occlusion:Comparison with invasive angiography. African Journal of Biotechnology. 2011;10(19):3854-3858. Full-text exclusion reason(s): All women in the study are known to have CAD; Data for women not reported as a subgroup.
Liao L, Smith WTt, Tuttle RH, et al. Prediction of death and nonfatal myocardial infarction in high-risk patients: a comparison between the Duke treadmill score, peak exercise radionuclide angiography, and SPECT perfusion imaging. J Nucl Med. 2005;46(1):5-11. Full-text exclusion reason(s): No women with symptomatic chest pain, or results are not reported separately for symptomatic subgroup; All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 15632026].
Lim MC, Wong TW, Yaneza LO, et al. Non-invasive detection of significant coronary artery disease with multi-section computed tomography angiography in patients with suspected coronary artery disease. Clin Radiol. 2006;61(2):174-80. Full-text exclusion reason(s): No women with symptomatic chest pain, or results are not reported separately for symptomatic subgroup; Data for women not reported as a subgroup. [pmid: 16439223].
Lim SJ, Choo KS, Park YH, et al. Assessment of left ventricular function and volume in patients undergoing 128-slice coronary CT angiography with ECG-based maximum tube current modulation: a comparison with echocardiography. Korean J Radiol. 2011;12(2):156-62. Full-text exclusion reason(s): Data for women not reported as a subgroup; No outcomes of interest. [pmid: 21430931].
Lima RS, De Lorenzo A, Pantoja MR, et al. Incremental prognostic value of myocardial perfusion 99m-technetium-sestamibi SPECT in the elderly. Int J Cardiol. 2004;93(2–3):137-43. Full-text exclusion reason(s): Study does not compare one NIT to another or to diagnostic cardiac catheterization. [pmid: 14975539].
Limacher MC, Quinones MA, Poliner LR, et al. Detection of coronary artery disease with exercise two-dimensional echocardiography. Description of a clinically applicable method and comparison with radionuclide ventriculography. Circulation. 1983;67(6):1211-8. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 6303623].
Lin CJ, Hsu JC, Lai YJ, et al. Diagnostic accuracy of dual-source CT coronary angiography in a population unselected for degree of coronary artery calcification and without heart rate modification. Clin Radiol. 2010;65(2):109-17. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 20103432].
Lin F, Shaw LJ, Berman DS, et al. Multidetector computed tomography coronary artery plaque predictors of stress-induced myocardial ischemia by SPECT. Atherosclerosis. 2008;197(2):700-9. Full-text exclusion reason(s): Data for women not reported as a subgroup; No outcomes of interest. [pmid: 17720167].
Lin FY, Saba S, Weinsaft JW, et al. Relation of plaque characteristics defined by coronary computed tomographic angiography to ST-segment depression and impaired functional capacity during exercise treadmill testing in patients suspected of having coronary heart disease. Am J Cardiol. 2009;103(1):50-8. Full-text exclusion reason(s): No women with symptomatic chest pain, or results are not reported separately for symptomatic subgroup; Data for women not reported as a subgroup. [pmid: 19101229].
Lin GA, Dudley RA, Lucas FL, et al. Frequency of stress testing to document ischemia prior to elective percutaneous coronary intervention. JAMA. 2008;300(15):1765-73. Full-text exclusion reason(s): All women in the study are known to have CAD; Study does not compare one NIT to another or to diagnostic cardiac catheterization; No outcomes of interest. [pmid: 18854538].
Lin SL, Chiou KR, Huang WC, et al. Detection of coronary artery disease using real-time myocardial contrast echocardiography: a comparison with dual-isotope resting thallium-201/stress technectium-99m sestamibi single-photon emission computed tomography. Heart Vessels. 2006;21(4):226-35. Full-text exclusion reason(s): No women with symptomatic chest pain, or results are not reported separately for symptomatic subgroup; All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 16865298].
Ling LH, Pellikka PA, Mahoney DW, et al. Atropine augmentation in dobutamine stress echocardiography: role and incremental value in a clinical practice setting. J Am Coll Cardiol. 1996;28(3):551-7. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 8772738].
Lipiec P, Wejner-Mik P, Krzeminska-Pakula M, et al. Gated 99mTc-MIBI single-photon emission computed tomography for the evaluation of left ventricular ejection fraction: comparison with three-dimensional echocardiography. Ann Nucl Med. 2008;22(8):723-6. Full-text exclusion reason(s): All women in the study are known to have CAD; Data for women not reported as a subgroup; No outcomes of interest. [pmid: 18982477].
Lipiec P, Wejner-Mik P, Krzeminska-Pakula M, et al. Detection of single-vessel coronary artery disease by dipyridamole stress echocardiography: no longer a problem?. Clin Physiol Funct Imaging. 2009;29(2):151-7. Full-text exclusion reason(s): No women with symptomatic chest pain, or results are not reported separately for symptomatic subgroup; All women in the study are known to have CAD. [pmid: 19222128].
Lipiec P, Wejner-Mik P, Krzeminska-Pakula M, et al. Accelerated stress real-time myocardial contrast echocardiography for the detection of coronary artery disease: comparison with 99mTc single photon emission computed tomography. J Am Soc Echocardiogr. 2008;21(8):941-7. Full-text exclusion reason(s): All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 18385014].
Lipinski M, Do D, Froelicher V, et al. Comparison of exercise test scores and physician estimation in determining disease probability. Arch Intern Med. 2001;161(18):2239-44. Full-text exclusion reason(s): Data for women not reported as a subgroup; No outcomes of interest. [pmid: 11575981].
Lipton JA, Nelwan SP, van Domburg RT, et al. Abnormal spatial QRS-T angle predicts mortality in patients undergoing dobutamine stress echocardiography for suspected coronary artery disease. Coron Artery Dis. 2010;21(1):26-32. Full-text exclusion reason(s): All women in the study are known to have CAD; Study does not compare one NIT to another or to diagnostic cardiac catheterization; Data for women not reported as a subgroup. [pmid: 19996961].
Liu X, Cai Z, Cai Y, et al. Comparison of 16 slice multi-detector computed tomography and breath hold 3D magnetic resonance angiography in the detection of coronary stenosis. Journal of Geriatric Cardiology. 2006;3(1):24-28. Full-text exclusion reason(s): Data for women not reported as a subgroup.
Liu X, Zhao X, Huang J, et al. Comparison of 3D free-breathing coronary MR angiography and 64-MDCT angiography for detection of coronary stenosis in patients with high calcium scores. AJR Am J Roentgenol. 2007;189(6):1326-32. Full-text exclusion reason(s): All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 18029867].
Lo KY, Leung KF, Chu CM, et al. Prognostic value of adenosine stress myocardial perfusion by cardiac magnetic resonance imaging in patients with known or suspected coronary artery disease. QJM. 2011;104(5):425-32. Full-text exclusion reason(s): Study does not compare one NIT to another or to diagnostic cardiac catheterization; Data for women not reported as a subgroup. [pmid: 21217114].
Lockie T, Ishida M, Perera D, et al. High-resolution magnetic resonance myocardial perfusion imaging at 3.0-Tesla to detect hemodynamically significant coronary stenoses as determined by fractional flow reserve. J Am Coll Cardiol. 2011;57(1):70-5. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 21185504].
Loimaala A, Groundstroem K, Pasanen M, et al. Comparison of bicycle, heavy isometric, dipyridamole-atropine and dobutamine stress echocardiography for diagnosis of myocardial ischemia. Am J Cardiol. 1999;84(12):1396-400. Full-text exclusion reason(s): All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 10606111].
Lokies J. Value of magnetocardiography for the non-invasive diagnosis of coronary artery disease. 30th Annual Congress of the International Society of Electrocardiology. Helsinki (Finland). 11–14 Jun 2003. (World Meeting Number 000 6973). 2003. Full-text exclusion reason(s): Data for women not reported as a subgroup.
Lonnebakken MT, Bleie O, Strand E, et al. Myocardial contrast echocardiography in assessment of stable coronary artery disease at intermediate dobutamine-induced stress level. Echocardiography. 2009;26(1):52-60. Full-text exclusion reason(s): All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 19125808].
Lorenzoni R, Cortigiani L, Magnani M, et al. Cost-effectiveness analysis of noninvasive strategies to evaluate patients with chest pain. J Am Soc Echocardiogr. 2003;16(12):1287-91. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 14652608].
Lu B, Lu JG, Sun ML, et al. Comparison of diagnostic accuracy and radiation dose between prospective triggering and retrospective gated coronary angiography by dual-source computed tomography. Am J Cardiol. 2011;107(9):1278-84. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 21497209].
Lu B, Shavelle DM, Mao S, et al. Improved accuracy of noninvasive electron beam coronary angiography. Invest Radiol. 2004;39(2):73-9. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 14734921].
Luotolahti M, Saraste M, Hartiala J. Exercise echocardiography in the diagnosis of coronary artery disease. Ann Med. 1996;28(1):73-7. Full-text exclusion reason(s): No women with symptomatic chest pain, or results are not reported separately for symptomatic subgroup; All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 8932510].
Ma Es, Yang Zg, Li Y, et al. Correlation of calcium measurement with low dose 64-slice CT and angiographic stenosis in patients with suspected coronary artery disease. Int J Cardiol. 2010;140(2):249-252. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 19097653].
Maas AHEM, Appelman YEA. Gender differences in coronary heart disease. Netherlands Heart Journal. 2010;18(12):598-603. Full-text exclusion reason(s): Not a clinical study report; Not original peer-reviewed data or a secondary analysis of RCT, prospective or retrospective observational study, or registry; Study does not compare one NIT to another or to diagnostic cardiac catheterization.
Macaciel RM, Mesquita ET, Vivacqua R, et al. Safety, feasibility, and results of exercise testing for stratifying patients with chest pain in the emergency room. Arq Bras Cardiol. 2003;81(2):174-81. 166. 73. Full-text exclusion reason(s): All women in the study are known to have CAD; Study does not compare one NIT to another or to diagnostic cardiac catheterization; Data for women not reported as a subgroup. [pmid: 14502386].
Machaalany J, Yam Y, Ruddy TD, et al. Potential clinical and economic consequences of noncardiac incidental findings on cardiac computed tomography. J Am Coll Cardiol. 2009;54(16):1533-41. Full-text exclusion reason(s): No women with symptomatic chest pain, or results are not reported separately for symptomatic subgroup; All women in the study are known to have CAD; Study does not compare one NIT to another or to diagnostic cardiac catheterization; Data for women not reported as a subgroup; No outcomes of interest. [pmid: 19815125].
Machecourt J, Denis B, Comet M, et al. Comparison between the predictive value of thallium 201 myocardial scintigraphy during effort, clinical findings and the effort electrocardiogram. Study in 112 patients undergoing coronary angiography, without previous myocardial infarction. Arch Mal Coeur Vaiss. 1981;74(1):11-20. Full-text exclusion reason(s): Non-English. [pmid: 6781432].
Machecourt J, Longere P, Fagret D, et al. Prognostic value of thallium-201 single-photon emission computed tomographic myocardial perfusion imaging according to extent of myocardial defect. Study in 1,926 patients with follow-up at 33 months. J Am Coll Cardiol. 1994;23(5):1096-106. Full-text exclusion reason(s): Study does not compare one NIT to another or to diagnostic cardiac catheterization. [pmid: 8144775].
Maciejewski M, Zielinska M, Bolinska H, et al. Dobutamine stress echocardiography in symptomatic patients with nondiagnostic or negative treadmill exercise test. Acta Cardiol. 2002;57(1):56-7. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 11918151].
Maddahi J, Abdulla A, Garcia EV, et al. Noninvasive identification of left main and triple vessel coronary artery disease: improved accuracy using quantitative analysis of regional myocardial stress distribution and washout of thallium-201. J Am Coll Cardiol. 1986;7(1):53-60. Full-text exclusion reason(s): All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 3941217].
Maddahi J, Garcia EV, Berman DS, et al. Improved noninvasive assessment of coronary artery disease by quantitative analysis of regional stress myocardial distribution and washout of thallium-201. Circulation. 1981;64(5):924-35. Full-text exclusion reason(s): All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 7285307].
Maddahi J, Van Train K, Prigent F, et al. Quantitative single photon emission computed thallium-201 tomography for detection and localization of coronary artery disease: optimization and prospective validation of a new technique. J Am Coll Cardiol. 1989;14(7):1689-99. Full-text exclusion reason(s): All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 2584558].
Madu EC. Transesophageal dobutamine stress echocardiography in the evaluation of myocardial ischemia in morbidly obese subjects. Chest. 2000;117(3):657-61. Full-text exclusion reason(s): No data for NITs of interest (ECG, ECHO, SPECT, PET, CMR, CTA). [pmid: 10712988].
Maffei E, Palumbo A, Martini C, et al. Stress-ECG vs. CT coronary angiography for the diagnosis of coronary artery disease: a “real-world” experience. Radiol Med. 2010;115(3):354-67. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 19902329].
Maffei E, Palumbo A, Martini C, et al. Diagnostic accuracy of 64-slice computed tomography coronary angiography in a large population of patients without revascularisation: registry data and review of multicentre trials. Radiol Med. 2010;115(3):368-84. Full-text exclusion reason(s): No women with symptomatic chest pain, or results are not reported separately for symptomatic subgroup; All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 20017001].
Maffei E, Palumbo A, Martini C, et al. Diagnostic accuracy of computed tomography coronary angiography in a high risk symptomatic population. Acta bio-medica: Atenei Parmensis. 2010:47-53. Full-text exclusion reason(s): All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 20860092].
Maffei E, Palumbo A, Martini C, et al. Diagnostic accuracy of computedtomography coronary angiography in a high risk symptomatic population. Acta Biomedica de l’ Ateneo Parmense. 2010;81(1):47-53. Full-text exclusion reason(s): All women in the study are known to have CAD; Data for women not reported as a subgroup.
Maffei E, Seitun S, Martini C, et al. Prognostic value of CT coronary angiography: focus on obstructive vs. nonobstructive disease and on the presence of left main disease. Radiol Med. 2011;116(1):15-31. Full-text exclusion reason(s): Study does not compare one NIT to another or to diagnostic cardiac catheterization; Data for women not reported as a subgroup. [pmid: 20927651].
Maffei E, Seitun S, Romano M, et al. Computed tomography coronary angiography plaque burden in patients with suspected coronary artery disease. J Cardiovasc Med (Hagerstown). 2009;10(12):913-20. Full-text exclusion reason(s): Study does not compare one NIT to another or to diagnostic cardiac catheterization. [pmid: 19550352].
Maffei S, Baroni M, Terrazzi M, et al. Preoperative assessment of coronary artery disease in aortic stenosis: a dipyridamole echocardiographic study. Ann Thorac Surg. 1998;65(2):397-402. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 9485235].
Mahajan N, Polavaram L, Vankayala H, et al. Diagnostic accuracy of myocardial perfusion imaging and stress echocardiography for the diagnosis of left main and triple vessel coronary artery disease: a comparative meta-analysis. Heart. 2010;96(12):956-66. Full-text exclusion reason(s): Not original peer-reviewed data or a secondary analysis of RCT, prospective or retrospective observational study, or registry. [pmid: 20538671].
Mahenthiran J, Bangalore S, Yao SS, et al. Comparison of prognostic value of stress echocardiography versus stress electrocardiography in patients with suspected coronary artery disease. Am J Cardiol. 2005;96(5):628-34. Full-text exclusion reason(s): No women with symptomatic chest pain, or results are not reported separately for symptomatic subgroup; All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 16125483].
Mahmarian JJ, Boyce TM, Goldberg RK, et al. Quantitative exercise thallium-201 single photon emission computed tomography for the enhanced diagnosis of ischemic heart disease. J Am Coll Cardiol. 1990;15(2):318-29. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 2405036].
Maintz D, Ozgun M, Hoffmeier A, et al. Whole-heart coronary magnetic resonance angiography: value for the detection of coronary artery stenoses in comparison to multislice computed tomography angiography. Acta Radiol. 2007;48(9):967-73. Full-text exclusion reason(s): No women with symptomatic chest pain, or results are not reported separately for symptomatic subgroup; All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 17957510].
Mairesse GH, Marwick TH, Arnese M, et al. Improved identification of coronary artery disease in patients with left bundle branch block by use of dobutamine stress echocardiography and comparison with myocardial perfusion tomography. Am J Cardiol. 1995;76(5):321-5. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 7639153].
Malm S, Frigstad S, Torp H, et al. Quantitative adenosine real-time myocardial contrast echocardiography for detection of angiographically significant coronary artery disease. J Am Soc Echocardiogr. 2006;19(4):365-72. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 16581474].
Maltagliati A, Berti M, Muratori M, et al. Exercise echocardiography versus exercise electrocardiography in the diagnosis of coronary artery disease in hypertension. Am J Hypertens. 2000;13(7):796-801. Full-text exclusion reason(s): No women with symptomatic chest pain, or results are not reported separately for symptomatic subgroup; Data for women not reported as a subgroup. [pmid: 10933572].
Mandysova E, Niederle P, Malkova A, et al. Usefulness of dipyridamole-handgrip echocardiography test for detecting coronary artery disease. Am J Cardiol. 1991;67(9):883-5. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 2011988].
Manka R, Jahnke C, Kozerke S, et al. Dynamic 3-dimensional stress cardiac magnetic resonance perfusion imaging: detection of coronary artery disease and volumetry of myocardial hypoenhancement before and after coronary stenting. J Am Coll Cardiol. 2011;57(4):437-44. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 21251584].
Manka R, Paetsch I, Schnackenburg B, et al. BOLD cardiovascular magnetic resonance at 3.0 tesla in myocardial ischemia. J Cardiovasc Magn Reson. 2010;12:54. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 20860792].
Manka R, Vitanis V, Boesiger P, et al. Clinical feasibility of accelerated, high spatial resolution myocardial perfusion imaging. JACC: Cardiovascular Imaging. 2010;3(7):710-717. Full-text exclusion reason(s): All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 20633848].
Manning WJ, Li W, Edelman RR. A preliminary report comparing magnetic resonance coronary angiography with conventional angiography. N Engl J Med. 1993;328(12):828-32. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 8285929].
Mansencal N, Pellerin D, Lamar A, et al. Diagnostic value of contrast echocardiography in Tako-Tsubo cardiomyopathy. Arch Cardiovasc Dis. 2010;103(8–9):447-53. Full-text exclusion reason(s): All women in the study are known to have CAD; No outcomes of interest. [pmid: 21074123].
Mant J, McManus RJ, Oakes RA, et al. Systematic review and modelling of the investigation of acute and chronic chest pain presenting in primary care. Health Technol Assess. 1. 2004;8(2):iii-158. Full-text exclusion reason(s): Not original peer-reviewed data or a secondary analysis of RCT, prospective or retrospective observational study, or registry.
Marangelli V, Iliceto S, Piccinni G, et al. Detection of coronary artery disease by digital stress echocardiography: comparison of exercise, transesophageal atrial pacing and dipyridamole echocardiography. J Am Coll Cardiol. 1994;24(1):117-24. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 8006254].
Marano R, De Cobelli F, Floriani I, et al. Italian multicenter, prospective study to evaluate the negative predictive value of 16- and 64-slice MDCT imaging in patients scheduled for coronary angiography (NIMISCAD-Non Invasive Multicenter Italian Study for Coronary Artery Disease). Eur Radiol. 2009;19(5):1114-23. Full-text exclusion reason(s): No women with symptomatic chest pain, or results are not reported separately for symptomatic subgroup; Data for women not reported as a subgroup. [pmid: 19089430].
Marcovitz PA, Armstrong WF. Accuracy of dobutamine stress echocardiography in detecting coronary artery disease. Am J Cardiol. 1992;69(16):1269-73. Full-text exclusion reason(s): No women with symptomatic chest pain, or results are not reported separately for symptomatic subgroup; All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 1585858].
Marie PY, Danchin N, Durand JF, et al. Long-term prediction of major ischemic events by exercise thallium-201 single-photon emission computed tomography. Incremental prognostic value compared with clinical, exercise testing, catheterization and radionuclide angiographic data. J Am Coll Cardiol. 1995;26(4):879-86. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 7560612].
Mark DB, Berman DS, Budoff MJ, et al. ACCF/ACR/AHA/NASCI/SAIP/SCAI/SCCT 2010 expert consensus document on coronary computed tomographic angiography: a report of the American College of Cardiology Foundation Task Force on Expert Consensus Documents. Circulation. 2010;121(22):2509-43. Full-text exclusion reason(s): Not a clinical study report. [pmid: 20479158].
Marshall AJ, Hutchings F, James AJ, et al. Prognostic value of a nine-minute treadmill test in patients undergoing myocardial perfusion scintigraphy. Am J Cardiol. 2010;106(10):1423-8. Full-text exclusion reason(s): Study does not compare one NIT to another or to diagnostic cardiac catheterization. [pmid: 21059431].
Martin CM, McConahay DR. Maximal treadmill exercise electrocardiography. Correlations with coronary arteriography and cardiac hemodynamics. Circulation. 1972;46(5):956-62. Full-text exclusion reason(s): All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 5081147].
Martinez-Selles M, Bueno H, Estevez A, et al. Positive non-invasive tests in the chest pain unit: importance of the clinical profile for estimating the probability of coronary artery disease. Acute Card Care. 2008;10(4):205-8. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 19031188].
Martuscelli E, Razzini C, D’Eliseo A, et al. Limitations of four-slice multirow detector computed tomography in the detection of coronary stenosis. Ital Heart J. 2004;5(2):127-31. Full-text exclusion reason(s): All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 15086142].
Martuscelli E, Romagnoli A, D’Eliseo A, et al. Accuracy of thin-slice computed tomography in the detection of coronary stenoses. Eur Heart J. 2004;25(12):1043-8. Full-text exclusion reason(s): All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 15191775].
Maruyama T, Takada M, Hasuike T, et al. Radiation dose reduction and coronary assessability of prospective electrocardiogram-gated computed tomography coronary angiography: comparison with retrospective electrocardiogram-gated helical scan. J Am Coll Cardiol. 2008;52(18):1450-5. Full-text exclusion reason(s): All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 19017511].
Maruyama T, Yoshizumi T, Tamura R, et al. Comparison of visibility and diagnostic capability of noninvasive coronary angiography by eight-slice multidetector-row computed tomography versus conventional coronary angiography. Am J Cardiol. 2004;93(5):537-42. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 14996575].
Marwick T, Willemart B, D’Hondt AM, et al. Selection of the optimal nonexercise stress for the evaluation of ischemic regional myocardial dysfunction and malperfusion. Comparison of dobutamine and adenosine using echocardiography and 99mTc-MIBI single photon emission computed tomography. Circulation. 1993;87(2):345-54. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 8425283].
Marwick TH, Case C, Sawada S, et al. Prediction of mortality using dobutamine echocardiography. J Am Coll Cardiol. 2001;37(3):754-60. Full-text exclusion reason(s): All women in the study are known to have CAD; Study does not compare one NIT to another or to diagnostic cardiac catheterization; Data for women not reported as a subgroup. [pmid: 11693748].
Marwick TH, Case C, Sawada S, et al. Use of stress echocardiography to predict mortality in patients with diabetes and known or suspected coronary artery disease. Diabetes Care. 2002;25(6):1042-8. Full-text exclusion reason(s): All women in the study are known to have CAD; Study does not compare one NIT to another or to diagnostic cardiac catheterization; Data for women not reported as a subgroup. [pmid: 12032112].
Marwick TH, Case C, Sawada S, et al. Prediction of outcomes in hypertensive patients with suspected coronary disease. Hypertension. 2002;39(6):1113-8. Full-text exclusion reason(s): Study does not compare one NIT to another or to diagnostic cardiac catheterization; Data for women not reported as a subgroup. [pmid: 12052851].
Marwick TH, Case C, Short L, et al. Prediction of mortality in patients without angina: use of an exercise score and exercise echocardiography. Eur Heart J. 2003;24(13):1223-30. Full-text exclusion reason(s): No women with symptomatic chest pain, or results are not reported separately for symptomatic subgroup; Study does not compare one NIT to another or to diagnostic cardiac catheterization; Data for women not reported as a subgroup. [pmid: 12831817].
Marwick TH, Case C, Vasey C, et al. Prediction of mortality by exercise echocardiography: a strategy for combination with the duke treadmill score. Circulation. 2001;103(21):2566-71. Full-text exclusion reason(s): Study does not compare one NIT to another or to diagnostic cardiac catheterization; Data for women not reported as a subgroup. [pmid: 11382725].
Marwick TH, D’Hondt AM, Mairesse GH, et al. Comparative ability of dobutamine and exercise stress in inducing myocardial ischaemia in active patients. Br Heart J. 1994;72(1):31-8. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 8068466].
Marwick TH, Nemec JJ, Pashkow FJ, et al. Accuracy and limitations of exercise echocardiography in a routine clinical setting. J Am Coll Cardiol. 1992;19(1):74-81. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 1729348].
Marwick TH, Nemec JJ, Stewart WJ, et al. Diagnosis of coronary artery disease using exercise echocardiography and positron emission tomography: comparison and analysis of discrepant results. J Am Soc Echocardiogr. 1992;5(3):231-8. Full-text exclusion reason(s): All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 1622613].
Marwick TH, Shaw L, Case C, et al. Clinical and economic impact of exercise electrocardiography and exercise echocardiography in clinical practice. Eur Heart J. 2003;24(12):1153-63. Full-text exclusion reason(s): Study does not compare one NIT to another or to diagnostic cardiac catheterization; Data for women not reported as a subgroup. [pmid: 12804930].
Marwick TH, Torelli J, Harjai K, et al. Influence of left ventricular hypertrophy on detection of coronary artery disease using exercise echocardiography. J Am Coll Cardiol. 1995;26(5):1180-6. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 7594030].
Mason JR, Palac RT, Freeman ML, et al. Thallium scintigraphy during dobutamine infusion: nonexercise-dependent screening test for coronary disease. Am Heart J. 1984;107(3):481-5. Full-text exclusion reason(s): Population does not include women ≥ age 18; No women with symptomatic chest pain, or results are not reported separately for symptomatic subgroup; Data for women not reported as a subgroup. [pmid: 6695691].
Masood Y, Liu YH, Depuey G, et al. Clinical validation of SPECT attenuation correction using x-ray computed tomography-derived attenuation maps: multicenter clinical trial with angiographic correlation. J Nucl Cardiol. 2005;12(6):676-86. Full-text exclusion reason(s): All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 16344230].
Matsumoto N, Sato Y, Suzuki Y, et al. Usefulness of rapid low-dose/high-dose 1-day 99mTc-sestamibi ECG-gated myocardial perfusion single-photon emission computed tomography. Circ J. 2006;70(12):1585-9. Full-text exclusion reason(s): All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 17127804].
Matsumura Y, Hozumi T, Arai K, et al. Non-invasive assessment of myocardial ischaemia using new real-time three-dimensional dobutamine stress echocardiography: comparison with conventional two-dimensional methods. Eur Heart J. 2005;26(16):1625-32. Full-text exclusion reason(s): All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 15817607].
Matsumura Y, Hozumi T, Watanabe H, et al. Cut-off value of coronary flow velocity reserve by transthoracic Doppler echocardiography for diagnosis of significant left anterior descending artery stenosis in patients with coronary risk factors. Am J Cardiol. 2003;92(12):1389-93. Full-text exclusion reason(s): All women in the study are known to have CAD; Study does not compare one NIT to another or to diagnostic cardiac catheterization; Data for women not reported as a subgroup. [pmid: 14675571].
Matsuo S, Nakajima K, Akhter N, et al. Clinical usefulness of novel cardiac MDCT/SPECT fusion image. Ann Nucl Med. 2009;23(6):579-86. Full-text exclusion reason(s): All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 19572098].
Matsuo S, Nakamura Y, Matsumoto T, et al. Visual assessment of coronary artery stenosis with electrocardiographically-gated multislice computed tomography. Int J Cardiovasc Imaging. 2004;20(1):61-6. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 15055822].
Matsushima Y, Takase B, Uehata A, et al. Comparative predictive and diagnostic value of flow-mediated vasodilation in the brachial artery and intima media thickness of the carotid artery for assessment of coronary artery disease severity. Int J Cardiol. 2007;117(2):165-72. Full-text exclusion reason(s): No data for NITs of interest (ECG, ECHO, SPECT, PET, CMR, CTA). [pmid: 17258333].
Mattera JA, De Leon CM, Wackers FJ, et al. Association of patients’ perception of health status and exercise electrocardiogram, myocardial perfusion imaging, and ventricular function measures. Am Heart J. 2000;140(3):409-18. Full-text exclusion reason(s): All women in the study are known to have CAD; Study does not compare one NIT to another or to diagnostic cardiac catheterization; Data for women not reported as a subgroup; No outcomes of interest. [pmid: 10966538].
Mazeika PK, Nadazdin A, Oakley CM. Dobutamine stress echocardiography for detection and assessment of coronary artery disease. J Am Coll Cardiol. 1992;19(6):1203-11. Full-text exclusion reason(s): All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 1564221].
Mazur W, Rivera JM, Khoury AF, et al. Prognostic value of exercise echocardiography: validation of a new risk index combining echocardiographic, treadmill, and exercise electrocardiographic parameters. J Am Soc Echocardiogr. 2003;16(4):318-25. Full-text exclusion reason(s): No women with symptomatic chest pain, or results are not reported separately for symptomatic subgroup; All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 12712013].
McCarthy RM, Deshpande VS, Beohar N, et al. Three-dimensional breathhold magnetization-prepared TrueFISP: a pilot study for magnetic resonance imaging of the coronary artery disease. Invest Radiol. 2007;42(10):665-70. Full-text exclusion reason(s): No women with symptomatic chest pain, or results are not reported separately for symptomatic subgroup; Data for women not reported as a subgroup. [pmid: 17984762].
McHenry PL, Phillips JF, Knoebel SB. Correlation of computer-quantitated treadmill exercise electrocardiogram with arteriographic location of coronary artery disease. Am J Cardiol. 1972;30(7):747-52. Full-text exclusion reason(s): All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 4563637].
McKeogh JR. The diagnostic role of stress echocardiography in women with coronary artery disease: evidence based review. Curr Opin Cardiol. 2007;22(5):429-33. Full-text exclusion reason(s): Not original peer-reviewed data or a secondary analysis of RCT, prospective or retrospective observational study, or registry. [pmid: 17762544].
McNeill AJ, Fioretti PM, el-Said SM, et al. Enhanced sensitivity for detection of coronary artery disease by addition of atropine to dobutamine stress echocardiography. Am J Cardiol. 1992;70(1):41-6. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 1615868].
Meijboom WB, Mollet NR, Van Mieghem CA, et al. 64-Slice CT coronary angiography in patients with non-ST elevation acute coronary syndrome. Heart. 2007;93(11):1386-92. Full-text exclusion reason(s): All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 17344332].
Meijboom WB, van Mieghem CA, Mollet NR, et al. 64-slice computed tomography coronary angiography in patients with high, intermediate, or low pretest probability of significant coronary artery disease. J Am Coll Cardiol. 2007;50(15):1469-75. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 17919567].
Meijboom WB, Van Mieghem CA, van Pelt N, et al. Comprehensive assessment of coronary artery stenoses: computed tomography coronary angiography versus conventional coronary angiography and correlation with fractional flow reserve in patients with stable angina. J Am Coll Cardiol. 2008;52(8):636-43. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 18702967].
Meijer AB, OYL, Geleijns J, et al. Meta-analysis of 40- and 64-MDCT angiography for assessing coronary artery stenosis. AJR Am J Roentgenol. 2008;191(6):1667-75. Full-text exclusion reason(s): No women with symptomatic chest pain, or results are not reported separately for symptomatic subgroup; All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 19020234].
Mendelson MA, Spies SM, Spies WG, et al. Usefulness of single-photon emission computed tomography of thallium-201 uptake after dipyridamole infusion for detection of coronary artery disease. Am J Cardiol. 1992;69(14):1150-5. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 1575183].
Meng L, Cui L, Cheng Y, et al. Effect of heart rate and coronary calcification on the diagnostic accuracy of the dual-source CT coronary angiography in patients with suspected coronary artery disease. Korean J Radiol. 2009;10(4):347-54. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 19568462].
Mennicke M, Giesler T, Ropers D, et al. Influence of heart rate on image quality and detection of coronary stenoses with multislice spiral CT. Biomed Tech (Berl). Suppl 1. 2002;47(Pt 2):782-5. Full-text exclusion reason(s): Non-English. [pmid: 12465302].
Menon M, Lesser JR, Hara H, et al. Multidetector CT coronary angiography for patient triage to invasive coronary angiography: Performance and cost in ambulatory patients with equivocal or suspected inaccurate noninvasive stress tests. Catheter Cardiovasc Interv. 2009;73(4):497-502. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 19229981].
Merhige ME, Breen WJ, Shelton V, et al. Impact of myocardial perfusion imaging with PET and (82)Rb on downstream invasive procedure utilization, costs, and outcomes in coronary disease management. J Nucl Med. 2007;48(7):1069-76. Full-text exclusion reason(s): No women with symptomatic chest pain, or results are not reported separately for symptomatic subgroup; Data for women not reported as a subgroup. [pmid: 17607038].
Merkle N, Wohrle J, Grebe O, et al. Assessment of myocardial perfusion for detection of coronary artery stenoses by steady-state, free-precession magnetic resonance first-pass imaging. Heart. 2007;93(11):1381-5. Full-text exclusion reason(s): No women with symptomatic chest pain, or results are not reported separately for symptomatic subgroup; Data for women not reported as a subgroup. [pmid: 17488772].
Merz NB, Johnson BD, Kelsey PSF, et al. Diagnostic, prognostic, and cost assessment of coronary artery disease in women. Am J Manag Care. 2001;7(10):959-65. Full-text exclusion reason(s): Not original peer-reviewed data or a secondary analysis of RCT, prospective or retrospective observational study, or registry. [pmid: 11669360].
Metz LD, Beattie M, Hom R, et al. The prognostic value of normal exercise myocardial perfusion imaging and exercise echocardiography: a meta-analysis. J Am Coll Cardiol. 2007;49(2):227-37. Full-text exclusion reason(s): Not original peer-reviewed data or a secondary analysis of RCT, prospective or retrospective observational study, or registry. [pmid: 17222734].
Meyer C, Strach K, Thomas D, et al. High-resolution myocardial stress perfusion at 3 T in patients with suspected coronary artery disease. Eur Radiol. 2008;18(2):226-33. Full-text exclusion reason(s): No women with symptomatic chest pain, or results are not reported separately for symptomatic subgroup; All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 17851665].
Michaelides AP, Andrikopoulos GK, Antoniades C, et al. Duration of treadmill exercise testing combined with QRS score predicts adverse cardiac outcome at long-term follow-up. Coron Artery Dis. 2009;20(5):337-42. Full-text exclusion reason(s): No women with symptomatic chest pain, or results are not reported separately for symptomatic subgroup; All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 19543085].
Michaelides AP, Fourlas CA, Andrikopoulos GK, et al. QRS score versus ST-segment changes in patients undergoing Tl-201 scintigraphy using dipyridamole infusion. J Nucl Cardiol. 2005;12(2):203-7. Full-text exclusion reason(s): No women with symptomatic chest pain, or results are not reported separately for symptomatic subgroup; Data for women not reported as a subgroup. [pmid: 15812375].
Michaelides AP, Fourlas CA, Giannopoulos N, et al. Significance of QRS duration changes in the evaluation of ST-segment depression presenting exclusively during the postexercise recovery period. Ann Noninvasive Electrocardiol. 2006;11(3):241-6. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 16846439].
Michaelides AP, Massias S, Antoniades C, et al. Novel methodology for the detection of exercise-induced myocardial wall motion abnormalities by surface electrocardiogram during exercise test. J Electrocardiol. 2011;44(3):377-382. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 21190701].
Michaelides AP, Psomadaki ZD, Aigyptiadou MN, et al. Significance of exercise-induced ST changes in leads aVR, V5, and V1. Discrimination of patients with single- or multivessel coronary artery disease. Clin Cardiol. 2003;26(5):226-30. Full-text exclusion reason(s): No women with symptomatic chest pain, or results are not reported separately for symptomatic subgroup; All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 12769250].
Michaelides AP, Tousoulis D, Fourlas CA, et al. Hypertensive patients with false-positive thallium-201 scintigraphic results in the infero-posterior wall are in high risk for coronary artery disease development. Int J Cardiol. 2007;117(2):178-83. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 16904776].
Mieres JH, Rosman DR, Shaw LJ. The clinical role of stress myocardial perfusion imaging in women with suspected coronary artery disease. Curr Cardiol Rep. 2004;6(1):27-31. Full-text exclusion reason(s): Not a clinical study report. [pmid: 14662095].
Mieres JH, Shaw LJ, Arai A, et al. Role of noninvasive testing in the clinical evaluation of women with suspected coronary artery disease: Consensus statement from the Cardiac Imaging Committee, Council on Clinical Cardiology, and the Cardiovascular Imaging and Intervention Committee, Council on Cardiovascular Radiology and Intervention, American Heart Association. Circulation. 2005;111(5):682-96. Full-text exclusion reason(s): Not original peer-reviewed data or a secondary analysis of RCT, prospective or retrospective observational study, or registry. [pmid: 15687114].
Milavetz JJ, Miller TD, Hodge DO, et al. Accuracy of single-photon emission computed tomography myocardial perfusion imaging in patients with stents in native coronary arteries. Am J Cardiol. 1998;82(7):857-61. Full-text exclusion reason(s): All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 9781967].
Miller CD, Hwang W, Hoekstra JW, et al. Stress cardiac magnetic resonance imaging with observation unit care reduces cost for patients with emergent chest pain: a randomized trial. Ann Emerg Med. 2010;56(3):209-219. e2. Full-text exclusion reason(s): Study does not compare one NIT to another or to diagnostic cardiac catheterization; Data for women not reported as a subgroup. [pmid: 20554078].
Miller DD, Younis LT, Chaitman BR, et al. Diagnostic accuracy of dipyridamole technetium 99m-labeled sestamibi myocardial tomography for detection of coronary artery disease. J Nucl Cardiol. 1997;4(1 Pt 1):18-24. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 9138835].
Miller JM, Rochitte CE, Dewey M, et al. Diagnostic performance of coronary angiography by 64-row CT. N Engl J Med. 2008;359(22):2324-36. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 19038879].
Miller TD, Chaliki HP, Christian TF, et al. Usefulness of worsening clinical status or exercise performance in predicting future events in patients with coronary artery disease. Am J Cardiol. 2001;88(11):1294-7. Full-text exclusion reason(s): All women in the study are known to have CAD; Study does not compare one NIT to another or to diagnostic cardiac catheterization; Data for women not reported as a subgroup. [pmid: 11728358].
Miller TD, Hodge DO, Milavetz JJ, et al. A normal stress SPECT scan is an effective gatekeeper for coronary angiography. J Nucl Cardiol. 2007;14(2):187-93. Full-text exclusion reason(s): No women with symptomatic chest pain, or results are not reported separately for symptomatic subgroup; Data for women not reported as a subgroup. [pmid: 17386380].
Miller TD, Roger VL, Hodge DO, et al. Gender differences and temporal trends in clinical characteristics, stress test results and use of invasive procedures in patients undergoing evaluation for coronary artery disease. J Am Coll Cardiol. 2001;38(3):690-7. Full-text exclusion reason(s): Study does not compare one NIT to another or to diagnostic cardiac catheterization. [pmid: 11527619].
Milosavljevic J, Ostojic M, Marinkovic J. Dipyridamole-dobutamine stress echocardiography for the detection of myocardial ischemia in patients with hypertension. Herz. 2005;30(3):215-222. Full-text exclusion reason(s): All women in the study are known to have CAD. [pmid: 15902372].
Min JK, Dunning A, Lin FY, et al. Age- and sex-related differences in all-cause mortality risk based on coronary computed tomography angiography findings results rrom the international multicenter CONFIRM (Coronary CT Angiography Evaluation for Clinical Outcomes: An International Multicenter Registry) of 23,854 patients without known coronary artery disease. J Am Coll Cardiol. 2011;58(8):849-60. Full-text exclusion reason(s): Study does not compare one NIT to another or to diagnostic cardiac catheterization. [pmid: 21835321].
Min JK, Dunning A, Lin FY, et al. Age- and sex-related differences in all-cause mortality risk based on coronary computed tomography angiography findings: Results from the international multicenter CONFIRM (Coronary CT Angiography Evaluation for Clinical Outcomes: An International Multicenter Registry) of 23,854 patients without known coronary artery disease. J Am Coll Cardiol. 2011;58(8):849-860. Full-text exclusion reason(s): Study does not compare one NIT to another or to diagnostic cardiac catheterization. [pmid: 21835321].
Min JK, Dunning A, Lin FY, et al. Rationale and design of the CONFIRM (COronary CT Angiography EvaluatioN For Clinical Outcomes: An InteRnational Multicenter) Registry. J Cardiovasc Comput Tomogr. 2011;5(2):84-92. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 21477786].
Min JK, Feignoux J, Treutenaere J, et al. The prognostic value of multidetector coronary CT angiography for the prediction of major adverse cardiovascular events: a multicenter observational cohort study. Int J Cardiovasc Imaging. 2010;26(6):721-8. Full-text exclusion reason(s): All women in the study are known to have CAD; Study does not compare one NIT to another or to diagnostic cardiac catheterization; Data for women not reported as a subgroup. [pmid: 20349139].
Min JK, Robinson M, Shaw LJ, et al. Differences in episode-based care costs for multidetector computed tomographic coronary angiography versus myocardial perfusion imaging for the diagnosis of coronary artery disease. J Med Econ. 2008;11(2):327-40. Full-text exclusion reason(s): Study does not compare one NIT to another or to diagnostic cardiac catheterization; Data for women not reported as a subgroup; No outcomes of interest. [pmid: 19450089].
Min JK, Shaw LJ, Berman DS, et al. Costs and clinical outcomes in individuals without known coronary artery disease undergoing coronary computed tomographic angiography from an analysis of Medicare category III transaction codes. Am J Cardiol. 2008;102(6):672-8. Full-text exclusion reason(s): No women with symptomatic chest pain, or results are not reported separately for symptomatic subgroup; Data for women not reported as a subgroup; No outcomes of interest. [pmid: 18773986].
Minardi G, Di Segni M, Manzara CC, et al. Diagnostic and prognostic value of dipyridamole and dobutamine stress echocardiography in patients with Q-wave acute myocardial infarction. Am J Cardiol. 1997;80(7):847-51. Full-text exclusion reason(s): All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 9381996].
Minoves M, Garcia A, Magrina J, et al. Evaluation of myocardial perfusion defects by means of “bull’s eye” images. Clin Cardiol. 1993;16(1):16-22. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 8416754].
Mir-Akbari H, Ripsweden J, Jensen J, et al. Limitations of 64-detector-row computed tomography coronary angiography: calcium and motion but not short experience. Acta Radiol. 2009;50(2):174-80. Full-text exclusion reason(s): No women with symptomatic chest pain, or results are not reported separately for symptomatic subgroup; All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 19169918].
Mishra JP, Acio E, Heo J, et al. Impact of stress single-photon emission computed tomography perfusion imaging on downstream resource utilization. Am J Cardiol. 1999;83(9):1401-3. A8. Full-text exclusion reason(s): Study does not compare one NIT to another or to diagnostic cardiac catheterization; Data for women not reported as a subgroup; No outcomes of interest. [pmid: 10235101].
Miszalski-Jamka T, Kuntz-Hehner S, Schmidt H, et al. Myocardial contrast echocardiography enhances long-term prognostic value of supine bicycle stress two-dimensional echocardiography. J Am Soc Echocardiogr. 2009;22(11):1220-7. Full-text exclusion reason(s): No women with symptomatic chest pain, or results are not reported separately for symptomatic subgroup; All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 19883873].
Miyazono Y, Kisanuki A, Toyonaga K, et al. Usefulness of adenosine triphosphate-atropine stress echocardiography for detecting coronary artery stenosis. Am J Cardiol. 1998;82(3):290-4. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 9708655].
Modena MG. Sex differences in noninvasive diagnosis of multivessel coronary artery disease. 46th Annual Scientific Session of the American College of Cardiology. Anaheim, CA (USA). 16–19 Mar 1997. (World Meeting Number 971 0068). 1997. Full-text exclusion reason(s): Conference abstract or trial registry posting.
Modena MG, Rossi R, Muia N, et al. Female gender as a bias for non-invasive diagnosis of multivessel coronary artery disease. XIXth Congress of the European Society of Cardiology. Stockholm (Sweden). 24–28 August 1997. (World Meeting Number 973 0006). 1997. Full-text exclusion reason(s): Conference abstract or trial registry posting.
Moir S, Haluska BA, Jenkins C, et al. Incremental benefit of myocardial contrast to combined dipyridamole-exercise stress echocardiography for the assessment of coronary artery disease. Circulation. 2004;110(9):1108-13. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 15326066].
Moir S, Haluska BA, Jenkins C, et al. Myocardial blood volume and perfusion reserve responses to combined dipyridamole and exercise stress: a quantitative approach to contrast stress echocardiography. J Am Soc Echocardiogr. 2005;18(11):1187-93. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 16275528].
Moir S, Shaw L, Haluska B, et al. Left ventricular opacification for the diagnosis of coronary artery disease with stress echocardiography: an angiographic study of incremental benefit and cost-effectiveness. Am Heart J. 2007;154(3):510-8. Full-text exclusion reason(s): No women with symptomatic chest pain, or results are not reported separately for symptomatic subgroup; Data for women not reported as a subgroup. [pmid: 17719299].
Mollet NR, Cademartiri F, Krestin GP, et al. Improved diagnostic accuracy with 16-row multi-slice computed tomography coronary angiography. J Am Coll Cardiol. 2005;45(1):128-32. Full-text exclusion reason(s): All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 15629386].
Mollet NR, Cademartiri F, Nieman K, et al. Multislice spiral computed tomography coronary angiography in patients with stable angina pectoris. J Am Coll Cardiol. 2004;43(12):2265-70. Full-text exclusion reason(s): All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 15193691].
Mollet NR, Cademartiri F, Nieman K, et al. Noninvasive assessment of coronary plaque burden using multislice computed tomography. Am J Cardiol. 2005;95(10):1165-9. Full-text exclusion reason(s): All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 15877987].
Mollet NR, Cademartiri F, Van Mieghem C, et al. Adjunctive value of CT coronary angiography in the diagnostic work-up of patients with typical angina pectoris. Eur Heart J. 2007;28(15):1872-8. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 17350972].
Mollet NR, Cademartiri F, van Mieghem CA, et al. High-resolution spiral computed tomography coronary angiography in patients referred for diagnostic conventional coronary angiography. Circulation. 2005;112(15):2318-23. Full-text exclusion reason(s): No women with symptomatic chest pain, or results are not reported separately for symptomatic subgroup; All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 16203914].
Moon JH, Park EA, Lee W, et al. The diagnostic accuracy, image quality and radiation dose of 64-slice dual-source CT in daily practice: A single institution’s experience. Korean J Radiol. 2011;12(3):308-318. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 21603290].
Moon JY, Chung N, Choi BW, et al. The utility of multi-detector row spiral CT for detection of coronary artery stenoses. Yonsei Med J. 2005;46(1):86-94. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 15744810].
Morgan-Hughes GJ, Roobottom CA, Owens PE, et al. Highly accurate coronary angiography with submillimetre, 16 slice computed tomography. Heart. 2005;91(3):308-13. Full-text exclusion reason(s): All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 15710708].
Morganroth J, Chen CC, David D, et al. Exercise cross-sectional echocardiographic diagnosis of coronary artery disease. Am J Cardiol. 1981;47(1):20-6. Full-text exclusion reason(s): All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 7457403].
Morise AP, Beto R, Gupta N, et al. Exercise QT dispersion as an independent predictor of the presence of ischemia on myocardial perfusion imaging. Ann Noninvasive Electrocardiol. 2000;5(3):240-247. Full-text exclusion reason(s): No women with symptomatic chest pain, or results are not reported separately for symptomatic subgroup; Data for women not reported as a subgroup; No outcomes of interest.
Motoyama S, Anno H, Sarai M, et al. Noninvasive coronary angiography with a prototype 256-row area detector computed tomography system: comparison with conventional invasive coronary angiography. J Am Coll Cardiol. 2008;51(7):773-5. Full-text exclusion reason(s): Not a clinical study report. [pmid: 18279744].
Mowatt G, Brazzelli M, Gemmell H, et al. Systematic review of the prognostic effectiveness of SPECT myocardial perfusion scintigraphy in patients with suspected or known coronary artery disease and following myocardial infarction. Nucl Med Commun. 2005;26(3):217-29. Full-text exclusion reason(s): All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 15722902].
Mowatt G, Cook JA, Hillis GS, et al. 64-Slice computed tomography angiography in the diagnosis and assessment of coronary artery disease: systematic review and meta-analysis. Heart. 2008;94(11):1386-93. Full-text exclusion reason(s): All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 18669550].
Mowatt G, Cummins E, Waugh N, et al. Systematic review of the clinical effectiveness and cost-effectiveness of 64-slice or higher computed tomography angiography as an alternative to invasive coronary angiography in the investigation of coronary artery disease. Health Technol Assess. 2008;12(17):iii-iv. ix-143. Full-text exclusion reason(s): All women in the study are known to have CAD; Data for women not reported as a subgroup.
Muhlenbruch G, Seyfarth T, Soo CS, et al. Diagnostic value of 64-slice multi-detector row cardiac CTA in symptomatic patients. Eur Radiol. 2007;17(3):603-9. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 17008986].
Muller H, Lerch R. Tilt table exercise echocardiography assessment in the diagnosis of coronary artery disease. Arch Cardiovasc Dis. 2008;101(3):170-4. Full-text exclusion reason(s): No women with symptomatic chest pain, or results are not reported separately for symptomatic subgroup; All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 18477944].
Muller MF, Fleisch M, Kroeker R, et al. Proximal coronary artery stenosis: three-dimensional MRI with fat saturation and navigator echo. J Magn Reson Imaging. 1997;7(4):644-51. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 9243382].
Müller-Suur R, Eriksson SV, Strandberg LE, et al. Comparison of adenosine and exercise stress test for quantitative perfusion imaging in patients on beta-blocker therapy. Cardiology. 2001;(2):112-8. Full-text exclusion reason(s): All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 11423717].
Mulvagh SL, DeMaria AN, Feinstein SB, et al. Contrast echocardiography: current and future applications. J Am Soc Echocardiogr. 2000;13(4):331-42. Full-text exclusion reason(s): Not original peer-reviewed data or a secondary analysis of RCT, prospective or retrospective observational study, or registry. [pmid: 10756254].
Mulvagh SL, Rakowski H, Vannan MA, et al. American Society of Echocardiography Consensus Statement on the Clinical Applications of Ultrasonic Contrast Agents in Echocardiography. J Am Soc Echocardiogr. 2008;21(11):1179-201. quiz 1281. Full-text exclusion reason(s): Not original peer-reviewed data or a secondary analysis of RCT, prospective or retrospective observational study, or registry. [pmid: 18992671].
Mumma BE, Baumann BM, Diercks DB, et al. Sex bias in cardiovascular testing: the contribution of patient preference. Ann Emerg Med. 2011;57(6):551-560. e4. Full-text exclusion reason(s): No outcomes of interest. [pmid: 21146255].
Murata E, Hozumi T, Matsumura Y, et al. Coronary flow velocity reserve measurement in three major coronary arteries using transthoracic Doppler echocardiography. Echocardiography. 2006;23(4):279-86. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 16640704].
Muro T, Hozumi T, Watanabe H, et al. Assessment of myocardial perfusion abnormalities by intravenous myocardial contrast echocardiography with harmonic power Doppler imaging: comparison with positron emission tomography. Heart. 2003;89(2):145-9. Full-text exclusion reason(s): All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 12527662].
Murphy JC, Scott PJ, Shannon HJ, et al. ST elevation on the exercise ECG in patients presenting with chest pain and no prior history of myocardial infarction. Heart. 2009;95(21):1792-7. Full-text exclusion reason(s): No women with symptomatic chest pain, or results are not reported separately for symptomatic subgroup; Data for women not reported as a subgroup. [pmid: 19570758].
Murray CJ, Lopez AD. Evidence-based health policy—lessons from the Global Burden of Disease Study. Science. 1996;274(5288):740-3. Full-text exclusion reason(s): No data for NITs of interest (ECG, ECHO, SPECT, PET, CMR, CTA). [pmid: 8966556].
Muscholl MW, Oswald M, Mayer C, et al. Prognostic value of 2D echocardiography in patients presenting with acute chest pain and non-diagnostic ECG for ST-elevation myocardial infarction. Int J Cardiol. 2002;84(2–3):217-25. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 12127375].
Musto C, Simon P, Nicol E, et al. 64-multislice computed tomography in consecutive patients with suspected or proven coronary artery disease: initial single center experience. Int J Cardiol. 2007;114(1):90-7. Full-text exclusion reason(s): No women with symptomatic chest pain, or results are not reported separately for symptomatic subgroup; All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 16904768].
Nagata M, Kato S, Kitagawa K, et al. Diagnostic accuracy of 1.5-T unenhanced whole-heart coronary MR angiography performed with 32-channel cardiac coils: initial single-center experience. Radiology. 2011;259(2):384-92. Full-text exclusion reason(s): All women in the study are known to have CAD; Study does not compare one NIT to another or to diagnostic cardiac catheterization; Data for women not reported as a subgroup; No outcomes of interest. [pmid: 21406635].
Nagel E, Klein C, Paetsch I, et al. Magnetic resonance perfusion measurements for the noninvasive detection of coronary artery disease. Circulation. 2003;108(4):432-7. Full-text exclusion reason(s): No women with symptomatic chest pain, or results are not reported separately for symptomatic subgroup; Data for women not reported as a subgroup. [pmid: 12860910].
Nagel E, Lehmkuhl HB, Bocksch W, et al. Noninvasive diagnosis of ischemia-induced wall motion abnormalities with the use of high-dose dobutamine stress MRI: comparison with dobutamine stress echocardiography. Circulation. 1999;99(6):763-70. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 9989961].
Nagurney JT, Bamberg F, Nichols JH, et al. The Disposition Decision on Emergency Department Patients with Chest Pain is Affected by the Results of Multi-Detector Computed Axial Tomography Scan of the Coronary Arteries. J Emerg Med. 2010;39(1):57-64. Full-text exclusion reason(s): All women in the study are known to have CAD; Data for women not reported as a subgroup; No outcomes of interest. [pmid: 19500937].
Nakamura M, Takeda K, Ichihara T, et al. Feasibility of simultaneous stress 99mTc-sestamibi/rest 201Tl dual-isotope myocardial perfusion SPECT in the detection of coronary artery disease. J Nucl Med. 1999;40(6):895-903. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 10452303].
Nakazato R, Tamarappoo BK, Kang X, et al. Quantitative upright-supine high-speed SPECT myocardial perfusion imaging for detection of coronary artery disease: correlation with invasive coronary angiography. J Nucl Med. 2010;51(11):1724-31. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 20956478].
Nallamothu BK, Saint S, Bielak LF, et al. Electron-beam computed tomography in the diagnosis of coronary artery disease: a meta-analysis. Arch Intern Med. 2001;161(6):833-8. Full-text exclusion reason(s): Not original peer-reviewed data or a secondary analysis of RCT, prospective or retrospective observational study, or registry. [pmid: 11268225].
Nallamothu N, Pancholy SB, Lee KR, et al. Impact on exercise single-photon emission computed tomographic thallium imaging on patient management and outcome. J Nucl Cardiol. 1995;2(4):334-8. Full-text exclusion reason(s): Study does not compare one NIT to another or to diagnostic cardiac catheterization; Data for women not reported as a subgroup. [pmid: 9420808].
Nanasato M, Hirayama H, Ando A, et al. Incremental predictive value of myocardial scintigraphy with 123I-BMIPP in patients with acute myocardial infarction treated with primary percutaneous coronary intervention. European journal of nuclear medicine and molecular imaging. 2004;(11):1512-21. Full-text exclusion reason(s): All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 15232655].
Nance JW Jr, Bamberg F, Schoepf UJ, et al. Coronary atherosclerosis in African American and white patients with acute chest pain: Characterization with coronary CT angiography. Radiology. 2011;260(2):373-380. Full-text exclusion reason(s): Study does not compare one NIT to another or to diagnostic cardiac catheterization; Data for women not reported as a subgroup. [pmid: 21712470].
Nance JW Jr, Bastarrika G, Kang DK, et al. High-temporal resolution dual-energy computed tomography of the heart using a novel hybrid image reconstruction algorithm: initial experience. J Comput Assist Tomogr. 2011;35(1):119-25. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 21245697].
Nandalur KR, Dwamena BA, Choudhri AF, et al. Diagnostic performance of stress cardiac magnetic resonance imaging in the detection of coronary artery disease: a meta-analysis. J Am Coll Cardiol. 2007;50(14):1343-53. Full-text exclusion reason(s): Not original peer-reviewed data or a secondary analysis of RCT, prospective or retrospective observational study, or registry. [pmid: 17903634].
Napel S, Rubin GD, Jeffrey RB Jr. STS-MIP: a new reconstruction technique for CT of the chest. J Comput Assist Tomogr. 1993;17(5):832-8. Full-text exclusion reason(s): Study does not compare one NIT to another or to diagnostic cardiac catheterization; Data for women not reported as a subgroup; No outcomes of interest. [pmid: 8370848].
Naser N, Buksa M, Sokolovic S, et al. The role of dobutamine stress echocardiography in detecting coronary artery disease compared with coronary angiography. Med Arh. 2011;65(3):140-4. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 21776873].
Nasis A, Leung MC, Antonis PR, et al. Diagnostic accuracy of noninvasive coronary angiography with 320-detector row computed tomography. Am J Cardiol. 2010;106(10):1429-35. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 21059432].
Nemes A, Balazs E, Pinter S, et al. Long-term prognostic significance of coronary flow velocity reserve in patients with significant coronary artery disease not involving the left anterior descending coronary artery (results from the SZEGED study). Echocardiography. 2010;27(3):306-10. Full-text exclusion reason(s): All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 20486959].
Newman RJ, Darrow M, Cummings DM, et al. Predictive value of exercise stress testing in a family medicine population. J Am Board Fam Med. 2008;21(6):531-8. Full-text exclusion reason(s): Study does not compare one NIT to another or to diagnostic cardiac catheterization; Data for women not reported as a subgroup. [pmid: 18988720].
Nguyen T, Heo J, Ogilby JD, et al. Single photon emission computed tomography with thallium-201 during adenosine-induced coronary hyperemia: correlation with coronary arteriography, exercise thallium imaging and two-dimensional echocardiography. J Am Coll Cardiol. 1990;16(6):1375-83. Full-text exclusion reason(s): All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 2229789].
Nicol ED, Stirrup J, Reyes E, et al. Comparison of 64-slice cardiac computed tomography with myocardial perfusion scintigraphy for assessment of global and regional myocardial function and infarction in patients with low to intermediate likelihood of coronary artery disease. J Nucl Cardiol. 2008;15(4):497-502. Full-text exclusion reason(s): No women with symptomatic chest pain, or results are not reported separately for symptomatic subgroup; Data for women not reported as a subgroup. [pmid: 18674716].
Nicol ED, Stirrup J, Reyes E, et al. Sixty-four-slice computed tomography coronary angiography compared with myocardial perfusion scintigraphy for the diagnosis of functionally significant coronary stenoses in patients with a low to intermediate likelihood of coronary artery disease. J Nucl Cardiol. 2008;15(3):311-8. Full-text exclusion reason(s): No women with symptomatic chest pain, or results are not reported separately for symptomatic subgroup; Data for women not reported as a subgroup. [pmid: 18513637].
Nieman K, Cademartiri F, Lemos PA, et al. Reliable noninvasive coronary angiography with fast submillimeter multislice spiral computed tomography. Circulation. 2002;106(16):2051-4. Full-text exclusion reason(s): All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 12379572].
Nieman K, Galema T, Weustink A, et al. Computed tomography versus exercise electrocardiography in patients with stable chest complaints: real-world experiences from a fast-track chest pain clinic. Heart. 2009;95(20):1669-75. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 19622516].
Nieman K, Galema TW, Neefjes LA, et al. Comparison of the value of coronary calcium detection to computed tomographic angiography and exercise testing in patients with chest pain. Am J Cardiol. 2009;104(11):1499-504. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 19932782].
Nieman K, Rensing BJ, van Geuns RJ, et al. Usefulness of multislice computed tomography for detecting obstructive coronary artery disease. Am J Cardiol. 2002;89(8):913-8. Full-text exclusion reason(s): All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 11950427].
Nieman K, Rensing BJ, van Geuns RJ, et al. Non-invasive coronary angiography with multislice spiral computed tomography: impact of heart rate. Heart. 2002;88(5):470-4. Full-text exclusion reason(s): All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 12381635].
Nikolaou K, Knez A, Rist C, et al. Accuracy of 64-MDCT in the diagnosis of ischemic heart disease. AJR Am J Roentgenol. 2006;187(1):111-7. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 16794164].
Nikolaou K, Rist C, Wintersperger BJ, et al. Clinical value of MDCT in the diagnosis of coronary artery disease in patients with a low pretest likelihood of significant disease. AJR Am J Roentgenol. 2006;186(6):1659-68. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 16714656].
Nishimura S, Mahmarian JJ, Boyce TM, et al. Quantitative thallium-201 single-photon emission computed tomography during maximal pharmacologic coronary vasodilation with adenosine for assessing coronary artery disease. J Am Coll Cardiol. 1991;18(3):736-45. Full-text exclusion reason(s): No women with symptomatic chest pain, or results are not reported separately for symptomatic subgroup; All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 1869737].
Nixdorff U, Kufner C, Achenbach S, et al. Head-to-head comparison of dobutamine stress echocardiography and cardiac computed tomography for the detection of significant coronary artery disease. Cardiology. 2008;110(2):81-6. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 17971656].
Nkoulou R, Pazhenkottil AP, Kuest SM, et al. Semiconductor detectors allow low-dose - Low-dose 1-day SPECT myocardial perfusion imaging. J Nucl Med. 2011;52(8):1204-1209. Full-text exclusion reason(s): Study does not compare one NIT to another or to diagnostic cardiac catheterization; Data for women not reported as a subgroup. [pmid: 21810589].
Nucifora G, Badano LP, Sarraf-Zadegan N, et al. Comparison of early dobutamine stress echocardiography and exercise electrocardiographic testing for management of patients presenting to the emergency department with chest pain. Am J Cardiol. 2007;100(7):1068-73. Full-text exclusion reason(s): All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 17884363].
Nucifora G, Schuijf JD, van Werkhoven JM, et al. Relation between Framingham risk categories and the presence of functionally relevant coronary lesions as determined on multislice computed tomography and stress testing. Am J Cardiol. 2009;104(6):758-63. Full-text exclusion reason(s): No women with symptomatic chest pain, or results are not reported separately for symptomatic subgroup; All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 19733707].
Nygaard TW, Gibson RS, Ryan JM, et al. Prevalence of high-risk thallium-201 scintigraphic findings in left main coronary artery stenosis: comparison with patients with multiple- and single-vessel coronary artery disease. Am J Cardiol. 1984;53(4):462-9. Full-text exclusion reason(s): All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 6695774].
Odagiri K, Uehara A, Kurata C. Vasodilator stress impairs the left ventricular function obtained with gated single-photon emission computed tomography in patients with known or suspected coronary artery disease. Circ J. 2010;74(12):2666-73. Full-text exclusion reason(s): All women in the study are known to have CAD; Data for women not reported as a subgroup; No outcomes of interest. [pmid: 20966594].
Odawara H, Hamashige N, Doi Y, et al. Noninvasive detection of significant coronary artery disease in patients with vasospastic angina. Society of Nuclear Medicine 35th Annual Meeting. San Francisco, CA (USA). 14–17 Jun 1988. (World Meeting Number 882 0432). Full-text exclusion reason(s): Conference abstract or trial registry posting.
Ogilby JD, Kegel JG, Heo J, et al. Correlation between hemodynamic changes and tomographic sestamibi imaging during dipyridamole-induced coronary hyperemia. J Am Coll Cardiol. 1998;31(1):75-82. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 9426021].
Oguzhan A, Kisacik HL, Ozdemir K, et al. Comparison of exercise stress testing with dobutamine stress echocardiography and exercise technetium-99m isonitrile single photon emission computerized tomography for diagnosis of coronary artery disease. Jpn Heart J. 1997;38(3):333-44. Full-text exclusion reason(s): All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 9290568].
Ohara T, Hashimoto Y, Suzuki M, et al. Early diastolic flow propagation velocity detects induced diastolic dysfunction during dobutamine stress echocardiography. Echocardiography. 2011;28(3):335-41. Full-text exclusion reason(s): Study does not compare one NIT to another or to diagnostic cardiac catheterization; Data for women not reported as a subgroup; No outcomes of interest. [pmid: 21323985].
Ohkita Y, Terasawa M, Toshima H, et al. Exercise electrocardiography—the accuracy of Master two step test correlated with coronary arteriographic findings in angina suspected patients (author’s transl). Rinsho Byori. 1980;28(1):19-25. Full-text exclusion reason(s): Non-English. [pmid: 7373870].
O’Keefe JC, Edwards AC, Wiseman J, et al. Comparison of exercise electrocardiography, thallium-201 myocardial imaging and exercise gated blood pool scan in patients with suspected coronary artery disease. Aust N Z J Med. 1983;13(1):45-50. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 6576744].
O’Keefe JH Jr, Barnhart CS, Bateman TM. Comparison of stress echocardiography and stress myocardial perfusion scintigraphy for diagnosing coronary artery disease and assessing its severity. Am J Cardiol. 1995;75(11):25D-34D. Full-text exclusion reason(s): Not original peer-reviewed data or a secondary analysis of RCT, prospective or retrospective observational study, or registry.
O’Keefe JH Jr, Bateman TM, Silvestri R, et al. Safety and diagnostic accuracy of adenosine thallium-201 scintigraphy in patients unable to exercise and those with left bundle branch block. Am Heart J. 1992;124(3):614-21. Full-text exclusion reason(s): All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 1514488].
Olivetti L, Mazza G, Volpi D, et al. Multislice CT in emergency room management of patients with chest pain and medium-low probability of acute coronary syndrome. Radiol Med. 2006;111(8):1054-63. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 17171528].
Olmos LI, Dakik H, Gordon R, et al. Long-term prognostic value of exercise echocardiography compared with exercise 201Tl, ECG, and clinical variables in patients evaluated for coronary artery disease. Circulation. 1998;98(24):2679-86. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 9851953].
Olson MB, Kelsey SF, Matthews K, et al. Symptoms, myocardial ischaemia and quality of life in women: results from the NHLBI-sponsored WISE Study. Eur Heart J. 2003;24(16):1506-14. Full-text exclusion reason(s): Study does not compare one NIT to another or to diagnostic cardiac catheterization. [pmid: 12919775].
Olszowska M, Kostkiewicz M, Tracz W, et al. Assessment of myocardial perfusion in patients with coronary artery disease. Comparison of myocardial contrast echocardiography and 99mTc MIBI single photon emission computed tomography. Int J Cardiol. 2003;90(1):49-55. Full-text exclusion reason(s): All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 12821219].
Oncel D, Oncel G, Tastan A, et al. Detection of significant coronary artery stenosis with 64-section MDCT angiography. Eur J Radiol. 2007;62(3):394-405. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 17306490].
Oncel D, Oncel G, Turkoglu I. Accuracy of MR coronary angiography in the evaluation of coronary artery stenosis. Diagn Interv Radiol. 2008;14(3):153-8. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 18814138].
Ong K, Chin SP, Chan WL, et al. Feasibility and accuracy of 64-row MDCT coronary imaging from a centre with early experience: a review and comparison with established centres. Med J Malaysia. 2005;60(5):629-36. Full-text exclusion reason(s): No women with symptomatic chest pain, or results are not reported separately for symptomatic subgroup; All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 16515115].
Ong TK, Chin SP, Liew CK, et al. Accuracy of 64-row multidetector computed tomography in detecting coronary artery disease in 134 symptomatic patients: influence of calcification. Am Heart J. 2006;151(6):1323 e1-6. Full-text exclusion reason(s): All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 16781246].
Ontario Health Technology Assessment. Medical Advisory Secretariat, Stress echocardiography for the diagnosis of coronary artery disease: an evidence-based analysis. Ont Health Technol Assess Ser. [Internet]. June. 2010;10(9):1-61. http://www.health.gov.on.ca/english/providers/program/mas/tech/reviews/pdf/cardiac_stress_echo_20100528.pdf. 2010. Full-text exclusion reason(s): Not a clinical study report.
Ostojic M, Picano E, Beleslin B, et al. Dipyridamole-dobutamine echocardiography: a novel test for the detection of milder forms of coronary artery disease. J Am Coll Cardiol. 1994;23(5):1115-22. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 8144777].
Ovrehus KA, Botker HE, Jensen JM, et al. Influence of coronary computed tomographic angiography on patient treatment and prognosis in patients with suspected stable angina pectoris. Am J Cardiol. 2011;107(10):1473-9. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 21420047].
Ovrehus KA, Jensen JK, Mickley HF, et al. Comparison of usefulness of exercise testing versus coronary computed tomographic angiography for evaluation of patients suspected of having coronary artery disease. Am J Cardiol. 2010;105(6):773-9. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 20211318].
Ovrehus KA, Munkholm H, Bottcher M, et al. Coronary computed tomographic angiography in patients suspected of coronary artery disease: impact of observer experience on diagnostic performance and interobserver reproducibility. J Cardiovasc Comput Tomogr. 2010;4(3):186-94. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 20451487].
Ozdemir K, Kisacik HL, Oguzhan A, et al. Comparison of exercise stress testing with dobutamine stress echocardiography and radionuclide ventriculography for diagnosis of coronary artery disease. Jpn Heart J. 1999;40(6):715-27. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 10737555].
Ozmen N, Yiginer O, Uz O, et al. ST elevation in the lead aVR during exercise treadmill testing may indicate left main coronary artery disease. Kardiol Pol. 2010;68(10):1107-11. Full-text exclusion reason(s): Data for women not reported as a subgroup; No outcomes of interest. [pmid: 20967704].
Paetsch I, Jahnke C, Barkhausen J, et al. Detection of coronary stenoses with contrast enhanced, three-dimensional free breathing coronary MR angiography using the gadolinium-based intravascular contrast agent gadocoletic acid (B-22956). J Cardiovasc Magn Reson. 2006;8(3):509-16. Full-text exclusion reason(s): All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 16755840].
Paetsch I, Jahnke C, Wahl A, et al. Comparison of dobutamine stress magnetic resonance, adenosine stress magnetic resonance, and adenosine stress magnetic resonance perfusion. Circulation. 2004;110(7):835-42. Full-text exclusion reason(s): All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 15289384].
Pagali SR, Madaj P, Gupta M, et al. Interobserver variations of plaque severity score and segment stenosis score in coronary arteries using 64 slice multidetector computed tomography: a substudy of the ACCURACY trial. J Cardiovasc Comput Tomogr. 2010;4(5):312-8. Full-text exclusion reason(s): Study does not compare one NIT to another or to diagnostic cardiac catheterization; Data for women not reported as a subgroup. [pmid: 20630819].
Paijitprapaporn P, Jongjirasiri S, Tangpagasit L, et al. Accuracy of sixteen-slice CT scanners in detected coronary artery disease. J Med Assoc Thai. 2006;89(1):72-80. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 16583585].
Paladugu N, Shaqra H, Blum S, et al. Positive vasodilator stress ECG with normal myocardial perfusion imaging and its correlation with coronary angiographic findings in African Americans and Hispanics. Clin Cardiol. 2010;33(10):638-42. Full-text exclusion reason(s): Study does not compare one NIT to another or to diagnostic cardiac catheterization; Data for women not reported as a subgroup; No outcomes of interest. [pmid: 20960539].
Palinkas A, Toth E, Amyot R, et al. The value of ECG and echocardiography during stress testing for identifying systemic endothelial dysfunction and epicardial artery stenosis. Eur Heart J. 2002;23(20):1587-95. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 12323158].
Palmas W, Friedman JD, Diamond GA, et al. Incremental value of simultaneous assessment of myocardial function and perfusion with technetium-99m sestamibi for prediction of extent of coronary artery disease. J Am Coll Cardiol. 1995;25(5):1024-31. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 7897112].
Panmethis M, Wangsuphachart S, Rerkpattanapipat P, et al. Detection of coronary stenoses in chronic stable angina by multi-detector CT coronary angiography. J Med Assoc Thai. 2007;90(8):1573-80. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 17926987].
Park JW, Leithauser B, Jung F. Magnetocardiography predicts coronary artery disease in bundle-branch block patients with acute chest pain. J Electrocardiol. 2007;40(1 SUPPL):S53. Full-text exclusion reason(s): Conference abstract or trial registry posting.
Park JW, Leithauser B, Vrsansky M, et al. Dobutamine stress magnetocardiography for the detection of significant coronary artery stenoses - a prospective study in comparison with simultaneous 12-lead electrocardiography. Clin Hemorheol Microcirc. 2008;39(1–4):21-32. Full-text exclusion reason(s): Study does not compare one NIT to another or to diagnostic cardiac catheterization; Data for women not reported as a subgroup. [pmid: 18503107].
Park MY, Choi SJ, Kim JK, et al. Use of multidetector computed tomography for evaluating coronary artery disease in patients undergoing dialysis. Nephrology (Carlton). 2011;16(3):285-9. Full-text exclusion reason(s): No women with symptomatic chest pain, or results are not reported separately for symptomatic subgroup; Data for women not reported as a subgroup. [pmid: 21342322].
Park TH, Tayan N, Takeda K, et al. Supine bicycle echocardiography improved diagnostic accuracy and physiologic assessment of coronary artery disease with the incorporation of intermediate stages of exercise. J Am Coll Cardiol. 2007;50(19):1857-63. Full-text exclusion reason(s): No women with symptomatic chest pain, or results are not reported separately for symptomatic subgroup; Data for women not reported as a subgroup. [pmid: 17980252].
Parodi G, Picano E, Marcassa C, et al. High dose dipyridamole myocardial imaging: simultaneous sestamibi scintigraphy and two-dimensional echocardiography in the detection and evaluation of coronary artery disease. Italian Group of Nuclear Cardiology. Coron Artery Dis. 1999;10(3):177-84. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 10352895].
Parthenakis FI, Karidis KS, Zuridakis G, et al. Left ventricular diastolic filling changes during dipyridamole-induced ischaemia. An echo-Doppler study. Coron Artery Dis. 1997;8(7):449-54. Full-text exclusion reason(s): All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 9383606].
Patel MR, Albert TS, Kandzari DE, et al. Acute myocardial infarction: safety of cardiac MR imaging after percutaneous revascularization with stents. Radiology. 2006;240(3):674-80. Full-text exclusion reason(s): All women in the study are known to have CAD; Study does not compare one NIT to another or to diagnostic cardiac catheterization; Data for women not reported as a subgroup. [pmid: 16926324].
Patel MR, Peterson ED, Dai D, et al. Low diagnostic yield of elective coronary angiography. N Engl J Med. 2010;362(10):886-95. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 20220183].
Patterson RE, Horowitz SF, Eng C, et al. Can exercise electrocardiography and thallium-201 myocardial imaging exclude the diagnosis of coronary artery disease? Bayesian analysis of the clinical limits of exclusion and indications for coronary angiography. Am J Cardiol. 1982;49(5):1127-35. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 6801953].
Pattillo RW, Fuchs S, Johnson J, et al. Predictors of prognosis by quantitative assessment of coronary angiography, single photon emission computed tomography thallium imaging, and treadmill exercise testing. Am Heart J. 1996;131(3):582-90. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 8604641].
Paul JF, Ohanessian A, Caussin C, et al. Visualization of coronary tree and detection of coronary artery stenosis using 16-slice, sub-millimeter computed tomography: preliminary experience. Arch Mal Coeur Vaiss. 2004;97(1):31-6. Full-text exclusion reason(s): Non-English. [pmid: 15002708].
Pazhenkottil AP, Ghadri JR, Nkoulou RN, et al. Improved outcome prediction by SPECT myocardial perfusion imaging after CT attenuation correction. J Nucl Med. 2011;52(2):196-200. Full-text exclusion reason(s): Study does not compare one NIT to another or to diagnostic cardiac catheterization; Data for women not reported as a subgroup. [pmid: 21270455].
Pedrazzini GB, D’Angeli I, Vassalli G, et al. Assessment of coronary stenosis, plaque burden and remodeling by multidetector computed tomography in patients referred for suspected coronary artery disease. J Cardiovasc Med (Hagerstown). 2011;12(2):122-30. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 21045721].
Peix A, Garcia EJ, Valiente J, et al. Ischemia in women with angina and normal coronary angiograms. Coron Artery Dis. 2007;18(5):361-6. Full-text exclusion reason(s): Study does not compare one NIT to another or to diagnostic cardiac catheterization; Data for women not reported as a subgroup; No outcomes of interest. [pmid: 17627185].
Penfornis A, Zimmermann C, Boumal D, et al. Use of dobutamine stress echocardiography in detecting silent myocardial ischaemia in asymptomatic diabetic patients: a comparison with thallium scintigraphy and exercise testing. Diabet Med. 2001;18(11):900-5. Full-text exclusion reason(s): No women with symptomatic chest pain, or results are not reported separately for symptomatic subgroup; Data for women not reported as a subgroup. [pmid: 11703435].
Peng NJ, Mar GY, Liu CP, et al. Does inadequate exercise lower the accuracy of myocardial perfusion scintigraphy?. Nucl Med Commun. 2001;22(6):625-9. Full-text exclusion reason(s): All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 11403172].
Pennell DJ, Mavrogeni S, Anagnostopoulos C, et al. Thallium myocardial perfusion tomography using intravenous dipyridamole combined with maximal dynamic exercise. Nucl Med Commun. 1993;14(11):939-45. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 8290165].
Pennell DJ, Underwood SR, Ell PJ, et al. Dipyridamole magnetic resonance imaging: a comparison with thallium-201 emission tomography. Br Heart J. 1990;64(6):362-9. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 2271342].
Pennell DJ, Underwood SR, Swanton RH, et al. Dobutamine thallium myocardial perfusion tomography. J Am Coll Cardiol. 1991;18(6):1471-9. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 1939948].
Perrier A, Roy PM, Sanchez O, et al. Multidetector-row computed tomography in suspected pulmonary embolism. N Engl J Med. 2005;352(17):1760-8. Full-text exclusion reason(s): No data for NITs of interest (ECG, ECHO, SPECT, PET, CMR, CTA). [pmid: 15858185].
Peteiro J, Bouzas-Mosquera A, Broullon F, et al. Treadmill exercise echocardiography as a predictor of events in patients with left ventricular hypertrophy. Am J Hypertens. 2010;23(7):794-801. Full-text exclusion reason(s): All women in the study are known to have CAD; Study does not compare one NIT to another or to diagnostic cardiac catheterization; Data for women not reported as a subgroup. [pmid: 20379141].
Peteiro J, Fabregas R, Montserrat L, et al. Comparison of treadmill exercise echocardiography before and after exercise in the evaluation of patients with known or suspected coronary artery disease. J Am Soc Echocardiogr. 1999;12(12):1073-9. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 10588783].
Peteiro J, Monserrat L, Perez R, et al. Accuracy of peak treadmill exercise echocardiography to detect multivessel coronary artery disease: comparison with post-exercise echocardiography. Eur J Echocardiogr. 2003;4(3):182-90. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 12928021].
Peters RM, Shanies SA, Peters JC. Predicting extent of coronary disease: Fuzzy cluster analysis vs. Duke treadmill score. Journal of Clinical and Basic Cardiology. 2000;3(1):39-41. Full-text exclusion reason(s): No data for NITs of interest (ECG, ECHO, SPECT, PET, CMR, CTA).
Pflederer T, Marwan M, Schepis T, et al. Characterization of culprit lesions in acute coronary syndromes using coronary dual-source CT angiography. Atherosclerosis. 2010;211(2):437-444. Full-text exclusion reason(s): All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 20189568].
Pfleger S, Scherhag A, Latsch A, et al. Safety of dobutamine echocardiography: No signs of myocardial cell damage or activation of the coagulation system. Disease Management and Clinical Outcomes. 2001;3(1):15-19. Full-text exclusion reason(s): All women in the study are known to have CAD; Data for women not reported as a subgroup.
Philippe L, Merino B, Blaire T, et al. Tetrofosmin early time gated post-stress single-photon emission computed tomography imaging: feasibility and potential benefits. J Nucl Cardiol. 2011;18(1):62-72. Full-text exclusion reason(s): All women in the study are known to have CAD; Study does not compare one NIT to another or to diagnostic cardiac catheterization; Data for women not reported as a subgroup; No outcomes of interest. [pmid: 21063927].
Phillips LM, Mieres JH. Noninvasive assessment of coronary artery disease in women: What’s next?. Curr Cardiol Rep. 2010;12(2):147-154. Full-text exclusion reason(s): Not original peer-reviewed data or a secondary analysis of RCT, prospective or retrospective observational study, or registry. [pmid: 20425170].
Pianou N, Georgakopoulos A, Anagnostopoulos CD. Positron emission tomography for risk assessment of women investigated for coronary artery disease. Cardiology. 2011;118(3):164-167. Full-text exclusion reason(s): Not a clinical study report. [pmid: 21646781].
Picano E, Alaimo A, Chubuchny V, et al. Noninvasive pacemaker stress echocardiography for diagnosis of coronary artery disease: a multicenter study. J Am Coll Cardiol. 2002;40(7):1305-10. Full-text exclusion reason(s): No women with symptomatic chest pain, or results are not reported separately for symptomatic subgroup; All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 12383579].
Picano E, Bedetti G, Varga A, et al. The comparable diagnostic accuracies of dobutamine-stress and dipyridamole-stress echocardiographies: a meta-analysis. Coron Artery Dis. 2000;11(2):151-9. Full-text exclusion reason(s): All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 10758817].
Picano E, Lattanzi F, Masini M, et al. Comparison of the high-dose dipyridamole-echocardiography test and exercise two-dimensional echocardiography for diagnosis of coronary artery disease. Am J Cardiol. 1987;59(6):539-42. Full-text exclusion reason(s): All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 3825891].
Picano E, Molinaro S, Pasanisi E. The diagnostic accuracy of pharmacological stress echocardiography for the assessment of coronary artery disease: a meta-analysis. Cardiovasc Ultrasound. 2008;6:30. Full-text exclusion reason(s): All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 18565214].
Picano E, Morales MA, Distante A, et al. Dipyridamole-echocardiography test in angina at rest: noninvasive assessment of coronary stenosis underlying spasm. Am Heart J. 1986;111(4):688-91. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 3953391].
Picano E, Parodi O, Lattanzi F, et al. Assessment of anatomic and physiological severity of single-vessel coronary artery lesions by dipyridamole echocardiography. Comparison with positron emission tomography and quantitative arteriography. Circulation. 1994;89(2):753-61. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 8313564].
Pilz G, Eierle S, Heer T, et al. Negative predictive value of normal adenosine-stress cardiac MRI in the assessment of coronary artery disease and correlation with semiquantitative perfusion analysis. J Magn Reson Imaging. 2010;32(3):615-621. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 20815059].
Pilz G, Heer T, Graw M, et al. Influence of small caliber coronary arteries on the diagnostic accuracy of adenosine stress cardiac magnetic resonance imaging. Clin Res Cardiol. 2011;100(3):201-8. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 20862587].
Pilz G, Jeske A, Klos M, et al. Prognostic value of normal adenosine-stress cardiac magnetic resonance imaging. Am J Cardiol. 2008;101(10):1408-12. Full-text exclusion reason(s): Study does not compare one NIT to another or to diagnostic cardiac catheterization; Data for women not reported as a subgroup. [pmid: 18471450].
Pingitore A, Picano E, Colosso MQ, et al. The atropine factor in pharmacologic stress echocardiography. Echo Persantine (EPIC) and Echo Dobutamine International Cooperative (EDIC) Study Groups. J Am Coll Cardiol. 1996;27(5):1164-70. Full-text exclusion reason(s): No women with symptomatic chest pain, or results are not reported separately for symptomatic subgroup; Data for women not reported as a subgroup. [pmid: 8609337].
Pizzuto F, Voci P, Bartolomucci F, et al. Usefulness of coronary flow reserve measured by echocardiography to improve the identification of significant left anterior descending coronary artery stenosis assessed by multidetector computed tomography. Am J Cardiol. 2009;104(5):657-64. Full-text exclusion reason(s): All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 19699341].
Plana JC, Mikati IA, Dokainish H, et al. A randomized cross-over study for evaluation of the effect of image optimization with contrast on the diagnostic accuracy of dobutamine echocardiography in coronary artery disease The OPTIMIZE Trial. JACC Cardiovasc Imaging. 2008;1(2):145-52. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 19356420].
Plass A, Azemaj N, Scheffel H, et al. Accuracy of dual-source computed tomography coronary angiography: evaluation with a standardised protocol for cardiac surgeons. Eur J Cardiothorac Surg. 2009;36(6):1011-7. Full-text exclusion reason(s): All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 19646889].
Plass A, Grunenfelder J, Leschka S, et al. Coronary artery imaging with 64-slice computed tomography from cardiac surgical perspective. Eur J Cardiothorac Surg. 2006;30(1):109-16. Full-text exclusion reason(s): All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 16725341].
Plein S, Greenwood JP, Ridgway JP, et al. Assessment of non-ST-segment elevation acute coronary syndromes with cardiac magnetic resonance imaging. J Am Coll Cardiol. 2004;44(11):2173-81. Full-text exclusion reason(s): All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 15582315].
Plein S, Kozerke S, Suerder D, et al. High spatial resolution myocardial perfusion cardiac magnetic resonance for the detection of coronary artery disease. Euro Heart J. 2008;29(17):2148-2155. Full-text exclusion reason(s): All women in the study are known to have CAD; Data for women not reported as a subgroup.
Plein S, Radjenovic A, Ridgway JP, et al. Coronary artery disease: myocardial perfusion MR imaging with sensitivity encoding versus conventional angiography. Radiology. 2005;235(2):423-30. Full-text exclusion reason(s): All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 15858084].
Pontone G, Andreini D, Ballerini G, et al. Diagnostic work-up of unselected patients with suspected coronary artery disease: complementary role of multidetector computed tomography, symptoms and electrocardiogram stress test. Coron Artery Dis. 2007;18(4):265-74. Full-text exclusion reason(s): All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 17496490].
Pontone G, Andreini D, Quaglia C, et al. Accuracy of multidetector spiral computed tomography in detecting significant coronary stenosis in patient populations with differing pre-test probabilities of disease. Clin Radiol. 2007;62(10):978-85. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 17765463].
Poprawski K, Wierzchowiecki M, Michalski M, et al. Usefulness of transoesophageal dipyridamole Doppler echocardiography evaluation of coronary flow reserve for detection of left anterior descending coronary artery stenosis. Comparison with dobutamine stress echocardiography and electrocardiographic exercise test. Kardiologia Polska. 2000;52(7):21-25. Full-text exclusion reason(s): Data for women not reported as a subgroup.
Postel T, Frick M, Feuchtner G, et al. Role of 16-multidetector computed tomography in the assessment of coronary artery stenoses: A prospective study of consecutive patients. Experimental and Clinical Cardiology. 2007;12(3):149-152. Full-text exclusion reason(s): All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 18650996].
Pouleur AC, le Polain de Waroux JB, Kefer J, et al. Direct comparison of whole-heart navigator-gated magnetic resonance coronary angiography and 40- and 64-slice multidetector row computed tomography to detect the coronary artery stenosis in patients scheduled for conventional coronary angiography. Circ Cardiovasc Imaging. 2008;1(2):114-21. Full-text exclusion reason(s): No women with symptomatic chest pain, or results are not reported separately for symptomatic subgroup; Data for women not reported as a subgroup. [pmid: 19808528].
Pozzoli MM, Fioretti PM, Salustri A, et al. Exercise echocardiography and technetium-99m MIBI single-photon emission computed tomography in the detection of coronary artery disease. Am J Cardiol. 1991;67(5):350-5. Full-text exclusion reason(s): All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 1994657].
Pracon R, Kruk M, Kepka C, et al. Epicardial adipose tissue radiodensity is independently related to coronary atherosclerosis. A multidetector computed tomography study. Circ J. 2011;75(2):391-7. Full-text exclusion reason(s): Study does not compare one NIT to another or to diagnostic cardiac catheterization; No outcomes of interest. [pmid: 21178296].
Pratt CM, Francis MJ, Divine GW, et al. Exercise testing in women with chest pain. Are there additional exercise characteristics that predict true positive test results?. Chest. 1989;95(1):139-44. Full-text exclusion reason(s): No women with symptomatic chest pain, or results are not reported separately for symptomatic subgroup; No outcomes of interest. [pmid: 2909329].
Previtali M, Lanzarini L, Fetiveau R, et al. Comparison of dobutamine stress echocardiography, dipyridamole stress echocardiography and exercise stress testing for diagnosis of coronary artery disease. Am J Cardiol. 1993;72(12):865-70. Full-text exclusion reason(s): All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 8213540].
Probst C, Kovacs A, Schmitz C, et al. Quantification of coronary artery stenosis with 16-slice MSCT in patients before CABG surgery: comparison to standard invasive coronary angiography. Heart Surg Forum. 2005;8(1):E42-6. Full-text exclusion reason(s): All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 15769714].
Pugliese F, Mollet NR, Hunink MG, et al. Diagnostic performance of coronary CT angiography by using different generations of multisection scanners: single-center experience. Radiology. 2008;246(2):384-93. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 18180337].
Pugliese F, Mollet NR, Runza G, et al. Diagnostic accuracy of non-invasive 64-slice CT coronary angiography in patients with stable angina pectoris. Eur Radiol. 2006;16(3):575-82. Full-text exclusion reason(s): All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 16292649].
Pundziute G, Schuijf JD, Jukema JW, et al. Head-to-head comparison of coronary plaque evaluation between multislice computed tomography and intravascular ultrasound radiofrequency data analysis. JACC Cardiovasc Interv. 2008;1(2):176-82. Full-text exclusion reason(s): All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 19463297].
Pundziute G, Schuijf JD, van Werkhoven JM, et al. Head-to-head comparison between bicycle exercise testing and coronary calcium score and coronary stenoses on multislice computed tomography. Coron Artery Dis. 2009;20(4):281-7. Full-text exclusion reason(s): All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 19384193].
Qian Z, Anderson H, Marvasty I, et al. Lesion- and vessel-specific coronary artery calcium scores are superior to whole-heart Agatston and volume scores in the diagnosis of obstructive coronary artery disease. J Cardiovasc Comput Tomogr. 2010;4(6):391-9. Full-text exclusion reason(s): Data for women not reported as a subgroup; No outcomes of interest. [pmid: 21035423].
Quinones MA, Verani MS, Haichin RM, et al. Exercise echocardiography versus 201Tl single-photon emission computed tomography in evaluation of coronary artery disease. Analysis of 292 patients. Circulation. 1992;85(3):1026-31. Full-text exclusion reason(s): No women with symptomatic chest pain, or results are not reported separately for symptomatic subgroup; All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 1537100].
Quyyumi AA, Raphael MJ, Wright C, et al. Inability of the ST segment/heart rate slope to predict accurately the severity of coronary artery disease. Br Heart J. 1984;51(4):395-8. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 6704260].
Raff GL, Chinnaiyan KM, Share DA, et al. Radiation dose from cardiac computed tomography before and after implementation of radiation dose-reduction techniques. JAMA. 2009;301(22):2340-8. Full-text exclusion reason(s): No women with symptomatic chest pain, or results are not reported separately for symptomatic subgroup; All women in the study are known to have CAD; Study does not compare one NIT to another or to diagnostic cardiac catheterization; Data for women not reported as a subgroup. [pmid: 19509381].
Raff GL, Gallagher MJ, O’Neill WW, et al. Diagnostic accuracy of noninvasive coronary angiography using 64-slice spiral computed tomography. J Am Coll Cardiol. 2005;46(3):552-7. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 16053973].
Raiker K, Sinusas AJ, Wackers FJ, et al. One-year prognosis of patients with normal planar or single-photon emission computed tomographic technetium 99m-labeled sestamibi exercise imaging. J Nucl Cardiol. 1994;1(5 Pt 1):449-56. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 9420729].
Ramakrishna G, Breen JF, Mulvagh SL, et al. Relationship between coronary artery calcification detected by electron-beam computed tomography and abnormal stress echocardiography: association and prognostic implications. J Am Coll Cardiol. 2006;48(10):2125-31. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 17113002].
Ramakrishna G, Milavetz JJ, Zinsmeister AR, et al. Effect of exercise treadmill testing and stress imaging on the triage of patients with chest pain: CHEER substudy. Mayo Clinic Proceedings. 2005;(3):322-9. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 15757012].
Ramakrishna G, Miller TD, Breen JF, et al. Relationship and prognostic value of coronary artery calcification by electron beam computed tomography to stress-induced ischemia by single photon emission computed tomography. Am Heart J. 2007;153(5):807-14. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 17452158].
Rambihar S, Abramson B. Cardiovascular imaging and noninvasive diagnosis for older adults. Geriatrics and Aging. 2007;10(1):14-22. Full-text exclusion reason(s): Not original peer-reviewed data or a secondary analysis of RCT, prospective or retrospective observational study, or registry.
Ravipati G, Aronow WS, Lai H, et al. Comparison of sensitivity, specificity, positive predictive value, and negative predictive value of stress testing versus 64-multislice coronary computed tomography angiography in predicting obstructive coronary artery disease diagnosed by coronary angiography. Am J Cardiol. 2008;101(6):774-5. Full-text exclusion reason(s): All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 18328838].
Regenfus M, Ropers D, Achenbach S, et al. Noninvasive detection of coronary artery stenosis using contrast-enhanced three-dimensional breath-hold magnetic resonance coronary angiography. J Am Coll Cardiol. 2000;36(1):44-50. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 10898411].
Rehn T, Griffith LS, Achuff SC, et al. Exercise thallium-201 myocardial imaging in left main coronary artery disease: sensitive but not specific. Am J Cardiol. 1981;48(2):217-23. Full-text exclusion reason(s): All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 7270431].
Reis G, Marcovitz PA, Leichtman AB, et al. Usefulness of dobutamine stress echocardiography in detecting coronary artery disease in end-stage renal disease. Am J Cardiol. 1995;75(10):707-10. Full-text exclusion reason(s): No women with symptomatic chest pain, or results are not reported separately for symptomatic subgroup; Data for women not reported as a subgroup. [pmid: 7900665].
Reis SE, Holubkov R, Conrad Smith AJ, et al. Coronary microvascular dysfunction is highly prevalent in women with chest pain in the absence of coronary artery disease: results from the NHLBI WISE study. Am Heart J. 2001;141(5):735-41. Full-text exclusion reason(s): No outcomes of interest. [pmid: 11320360].
Rensing BJ, Surruys PW, de Feyter PJ. CT-Based coronary angiography. J Invasive Cardiol. 2000;12(1):23-4. Full-text exclusion reason(s): Not a clinical study report. [pmid: 10731259].
Rerkpattanapipat P, Gandhi SK, Darty SN, et al. Feasibility to detect severe coronary artery stenoses with upright treadmill exercise magnetic resonance imaging. Am J Cardiol. 2003;92(5):603-6. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 12943887].
Reynolds HR, Srichai MB, Iqbal SN, et al. Mechanisms of myocardial infarction in women without angiographically obstructive coronary artery disease. Circulation. 2011;124(13):1414-25. Full-text exclusion reason(s): All women in the study are known to have CAD. [pmid: 21900087].
Rieber J, Huber A, Erhard I, et al. Cardiac magnetic resonance perfusion imaging for the functional assessment of coronary artery disease: a comparison with coronary angiography and fractional flow reserve. Eur Heart J. 2006;27(12):1465-71. Full-text exclusion reason(s): All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 16720685].
Rijneke RD, Ascoop CA, Talmon JL. Clinical significance of upsloping ST segments in exercise electrocardiography. Circulation. 1980;61(4):671-8. Full-text exclusion reason(s): All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 7357708].
Ripsweden J, Brismar TB, Holm J, et al. Impact on image quality and radiation exposure in coronary CT angiography: 100 kVp versus 120 kVp. Acta Radiol. 2010;51(8):903-9. Full-text exclusion reason(s): No women with symptomatic chest pain, or results are not reported separately for symptomatic subgroup; All women in the study are known to have CAD; Study does not compare one NIT to another or to diagnostic cardiac catheterization; Data for women not reported as a subgroup; No outcomes of interest. [pmid: 20735275].
Rixe J, Rolf A, Conradi G, et al. Detection of relevant coronary artery disease using dual-source computed tomography in a high probability patient series: comparison with invasive angiography. Circ J. 2009;73(2):316-22. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 19122307].
Rizzello V, Poldermans D, Schinkel AF, et al. Long term prognostic value of myocardial viability and ischaemia during dobutamine stress echocardiography in patients with ischaemic cardiomyopathy undergoing coronary revascularisation. Heart. 2006;92(2):239-44. Full-text exclusion reason(s): All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 15814593].
Robertson WS, Feigenbaum H, Armstrong WF, et al. Exercise echocardiography: a clinically practical addition in the evaluation of coronary artery disease. J Am Coll Cardiol. 1983;2(6):1085-91. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 6630781].
Rocchi G, Fallani F, Bracchetti G, et al. Non-invasive detection of coronary artery stenosis: a comparison among power-Doppler contrast echo, 99Tc-Sestamibi SPECT and echo wall-motion analysis. Coron Artery Dis. 2003;14(3):239-45. Full-text exclusion reason(s): All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 12702928].
Rocha-Filho JA, Blankstein R, Shturman LD, et al. Incremental value of adenosine-induced stress myocardial perfusion imaging with dual-source CT at cardiac CT angiography. Radiology. 2010;254(2):410-9. Full-text exclusion reason(s): All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 20093513].
Rodevand O, Hogalmen G, Gudim LP, et al. Limited usefulness of non-invasive coronary angiography with 16-detector multislice computer tomography at a community hospital. Scand Cardiovasc J. 2006;40(2):76-82. Full-text exclusion reason(s): No women with symptomatic chest pain, or results are not reported separately for symptomatic subgroup; All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 16608776].
Rodriguez O, Picano E, Fedele S, et al. Noninvasive prediction of coronary artery disease progression by comparison of serial exercise electrocardiography and dipyridamole stress echocardiography. Int J Cardiovasc Imaging. 2002;18(2):93-9. Full-text exclusion reason(s): No women with symptomatic chest pain, or results are not reported separately for symptomatic subgroup; All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 12108913].
Rodriguez O, Picano E, Fedele S, et al. Non-invasive prediction of angiographic progression of coronary artery disease by dipyridamole-stress echocardiography. Coron Artery Dis. 2001;12(3):197-204. Full-text exclusion reason(s): All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 11352076].
Roger VL, Jacobsen SJ, Weston SA, et al. Sex differences in evaluation and outcome after stress testing. Mayo Clin Proc. 2002;77(7):638-45. Full-text exclusion reason(s): No women with symptomatic chest pain, or results are not reported separately for symptomatic subgroup; Study does not compare one NIT to another or to diagnostic cardiac catheterization. [pmid: 12108601].
Roger VL, Pellikka PA, Oh JK, et al. Identification of multivessel coronary artery disease by exercise echocardiography. J Am Coll Cardiol. 1994;24(1):109-14. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 8006251].
Roger VL, Pellikka PA, Oh JK, et al. Stress echocardiography. Part I. Exercise echocardiography: techniques, implementation, clinical applications, and correlations. Mayo Clin Proc. 1995;70(1):5-15. Full-text exclusion reason(s): Not original peer-reviewed data or a secondary analysis of RCT, prospective or retrospective observational study, or registry. [pmid: 7808051].
Roger VL, Seward JB, Bailey KR, et al. Aortic valve resistance in aortic stenosis: Doppler echocardiographic study and surgical correlation. Am Heart J. 1997;134(5 Pt 1):924-9. Full-text exclusion reason(s): No data for NITs of interest (ECG, ECHO, SPECT, PET, CMR, CTA). [pmid: 9398105].
Romagnoli A, Martuscelli E, Sperandio M, et al. Role of 64-slice cardiac computed tomography in the evaluation of patients with non-ST-elevation acute coronary syndrome. Radiol Med. 2010;115(3):341-53. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 20017003].
Romanens M, Gradel C, Saner H, et al. Comparison of (99m)Tc-sestamibi lung/heart ratio, transient ischaemic dilation and perfusion defect size for the identification of severe and extensive coronary artery disease. European Journal of Nuclear Medicine. 2001;28(7):907-910. Full-text exclusion reason(s): All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 11504088].
Romeo F, Leo R, Clementi F, et al. Multislice computed tomography in an asymptomatic high-risk population. Am J Cardiol. 2007;99(3):325-8. Full-text exclusion reason(s): No women with symptomatic chest pain, or results are not reported separately for symptomatic subgroup; Data for women not reported as a subgroup. [pmid: 17261391].
Ropers D, Baum U, Pohle K, et al. Detection of coronary artery stenoses with thin-slice multi-detector row spiral computed tomography and multiplanar reconstruction. Circulation. 2003;107(5):664-6. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 12578863].
Ropers D, Pohle FK, Kuettner A, et al. Diagnostic accuracy of noninvasive coronary angiography in patients after bypass surgery using 64-slice spiral computed tomography with 330-ms gantry rotation. Circulation. 2006;114(22):2334-41. quiz 2334. Full-text exclusion reason(s): All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 17088461].
Ropers D, Rixe J, Anders K, et al. Usefulness of multidetector row spiral computed tomography with 64- x 0.6-mm collimation and 330-ms rotation for the noninvasive detection of significant coronary artery stenoses. Am J Cardiol. 2006;97(3):343-8. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 16442393].
Rosas EA, Slomka PJ, Garcia-Rojas L, et al. Functional impact of coronary stenosis observed on coronary computed tomography angiography: Comparison with (1)(3)N-ammonia PET. Arch Med Res. 2010;41(8):642-8. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 21199734].
Rozanski A, Gransar H, Hayes SW, et al. Comparison of long-term mortality risk following normal exercise vs adenosine myocardial perfusion SPECT. J Nucl Cardiol. 2010;17(6):999-1008. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 21076898].
Rozanski A, Gransar H, Wong ND, et al. Use of coronary calcium scanning for predicting inducible myocardial ischemia: Influence of patients’ clinical presentation. J Nucl Cardiol. 2007;14(5):669-79. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 17826320].
Rozanski A, Gransar H, Wong ND, et al. Clinical outcomes after both coronary calcium scanning and exercise myocardial perfusion scintigraphy. J Am Coll Cardiol. 2007;49(12):1352-61. Full-text exclusion reason(s): All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 17394969].
Rubello D, Zanco P, Candelpergher G, et al. Usefulness of 99mTc-MIBI stress myocardial SPECT bull’s-eye quantification in coronary artery disease. Q J Nucl Med. 1995;39(2):111-5. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 8574803].
Rubinshtein R, Gaspar T, Halon DA, et al. Prevalence and extent of obstructive coronary artery disease in patients with zero or low calcium score undergoing 64-slice cardiac multidetector computed tomography for evaluation of a chest pain syndrome. Am J Cardiol. 2007;99(4):472-5. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 17293187].
Rubinshtein R, Halon DA, Gaspar T, et al. Impact of 64-slice cardiac computed tomographic angiography on clinical decision-making in emergency department patients with chest pain of possible myocardial ischemic origin. Am J Cardiol. 2007;100(10):1522-6. Full-text exclusion reason(s): All women in the study are known to have CAD; Study does not compare one NIT to another or to diagnostic cardiac catheterization; Data for women not reported as a subgroup. [pmid: 17996512].
Rubinshtein R, Halon DA, Gaspar T, et al. Usefulness of 64-slice cardiac computed tomographic angiography for diagnosing acute coronary syndromes and predicting clinical outcome in emergency department patients with chest pain of uncertain origin. Circulation. 2007;115(13):1762-8. Full-text exclusion reason(s): All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 17372178].
Rubinshtein R, Halon DA, Gaspar T, et al. Cardiac computed tomographic angiography for risk stratification and prediction of late cardiovascular outcome events in patients with a chest pain syndrome. Int J Cardiol. 2009;137(2):108-15. Full-text exclusion reason(s): Study does not compare one NIT to another or to diagnostic cardiac catheterization; Data for women not reported as a subgroup. [pmid: 18718681].
Rubinshtein R, Halon DA, Gaspar T, et al. Usefulness of 64-slice multidetector computed tomography in diagnostic triage of patients with chest pain and negative or nondiagnostic exercise treadmill test result. Am J Cardiol. 2007;99(7):925-9. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 17398185].
Rubinshtein R, Miller TD, Williamson EE, et al. Detection of myocardial infarction by dual-source coronary computed tomography angiography using quantitated myocardial scintigraphy as the reference standard. Heart. 2009;95(17):1419-22. Full-text exclusion reason(s): No women with symptomatic chest pain, or results are not reported separately for symptomatic subgroup; All women in the study are known to have CAD; Data for women not reported as a subgroup; No outcomes of interest. [pmid: 19196731].
Rumberger JA, Behrenbeck T, Breen JF, et al. Coronary calcification by electron beam computed tomography and obstructive coronary artery disease: a model for costs and effectiveness of diagnosis as compared with conventional cardiac testing methods. J Am Coll Cardiol. 1999;33(2):453-62. Full-text exclusion reason(s): Not original peer-reviewed data or a secondary analysis of RCT, prospective or retrospective observational study, or registry. [pmid: 9973026].
Rumberger JA, Sheedy PF 3rd, Breen JF, et al. Coronary calcium, as determined by electron beam computed tomography, and coronary disease on arteriogram. Effect of patient’s sex on diagnosis. Circulation. 1995;91(5):1363-7. Full-text exclusion reason(s): All women in the study are known to have CAD; No outcomes of interest. [pmid: 7867174].
Russo V, Gostoli V, Lovato L, et al. Clinical value of multidetector CT coronary angiography as a preoperative screening test before non-coronary cardiac surgery. Heart. 2007;93(12):1591-8. Full-text exclusion reason(s): No women with symptomatic chest pain, or results are not reported separately for symptomatic subgroup; Data for women not reported as a subgroup. [pmid: 17164488].
Russo V, Zavalloni A, Bacchi Reggiani ML, et al. Incremental prognostic value of coronary CT angiography in patients with suspected coronary artery disease. Circ Cardiovasc Imaging. 2010;3(4):351-9. Full-text exclusion reason(s): No women with symptomatic chest pain, or results are not reported separately for symptomatic subgroup; Study does not compare one NIT to another or to diagnostic cardiac catheterization; Data for women not reported as a subgroup. [pmid: 20460497].
Ruzsics B, Lee H, Zwerner PL, et al. Dual-energy CT of the heart for diagnosing coronary artery stenosis and myocardial ischemia-initial experience. Eur Radiol. 2008;18(11):2414-24. Full-text exclusion reason(s): All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 18523782].
Ruzsics B, Schwarz F, Schoepf UJ, et al. Comparison of dual-energy computed tomography of the heart with single photon emission computed tomography for assessment of coronary artery stenosis and of the myocardial blood supply. Am J Cardiol. 2009;104(3):318-26. Full-text exclusion reason(s): All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 19616661].
Ryan T, Segar DS, Sawada SG, et al. Detection of coronary artery disease with upright bicycle exercise echocardiography. J Am Soc Echocardiogr. 1993;6(2):186-97. Full-text exclusion reason(s): No women with symptomatic chest pain, or results are not reported separately for symptomatic subgroup; All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 8481247].
Ryan T, Vasey CG, Presti CF, et al. Exercise echocardiography: detection of coronary artery disease in patients with normal left ventricular wall motion at rest. J Am Coll Cardiol. 1988;11(5):993-9. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 3356843].
Sa MI, Nicol ED, Stirrup J, et al. Implications for single phase prospective CT coronary angiography for the diagnosis of significant coronary stenoses in clinical practice. Int J Cardiol. 2011;147(3):393-397. Full-text exclusion reason(s): All women in the study are known to have CAD; Data for women not reported as a subgroup; No outcomes of interest. [pmid: 19896730].
Saad MAM, Azer HY. Dual-source CT coronary angiography: Diagnostic accuracy without the use of B blockers. Egyptian Journal of Radiology and Nuclear Medicine. 2011. Full-text exclusion reason(s): Data for women not reported as a subgroup.
Sabharwal NK, Lahiri A. Role of myocardial perfusion imaging for risk stratification in suspected or known coronary artery disease. Heart. 2003;89(11):1291-7. Full-text exclusion reason(s): Not original peer-reviewed data or a secondary analysis of RCT, prospective or retrospective observational study, or registry. [pmid: 14594881].
Sabharwal NK, Stoykova B, Taneja AK, et al. A randomized trial of exercise treadmill ECG versus stress SPECT myocardial perfusion imaging as an initial diagnostic strategy in stable patients with chest pain and suspected CAD: cost analysis. J Nucl Cardiol. 2007;14(2):174-86. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 17386379].
Sahin M, Karakelleoglu S, Alp N, et al. Diagnostic value of dobutamine stress echocardiography in coronary artery disease. Thorac Cardiovasc Surg. 1994;42(5):285-9. Full-text exclusion reason(s): No women with symptomatic chest pain, or results are not reported separately for symptomatic subgroup; All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 7863491].
Sakakura K, Yasu T, Kobayashi Y, et al. Noninvasive tissue characterization of coronary arterial plaque by 16-slice computed tomography in acute coronary syndrome. Angiology. 2006;57(2):155-60. Full-text exclusion reason(s): All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 16518522].
Sakuma H, Ichikawa Y, Chino S, et al. Detection of coronary artery stenosis with whole-heart coronary magnetic resonance angiography. J Am Coll Cardiol. 2006;48(10):1946-50. Full-text exclusion reason(s): All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 17112982].
Sakuma H, Ichikawa Y, Suzawa N, et al. Assessment of coronary arteries with total study time of less than 30 minutes by using whole-heart coronary MR angiography. Radiology. 2005;237(1):316-21. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 16126921].
Sakuma H, Suzawa N, Ichikawa Y, et al. Diagnostic accuracy of stress first-pass contrast-enhanced myocardial perfusion MRI compared with stress myocardial perfusion scintigraphy. AJR Am J Roentgenol. 2005;185(1):95-102. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 15972407].
Salm LP, Schuijf JD, de Roos A, et al. Global and regional left ventricular function assessment with 16-detector row CT: comparison with echocardiography and cardiovascular magnetic resonance. Eur J Echocardiogr. 2006;7(4):308-14. Full-text exclusion reason(s): No women with symptomatic chest pain, or results are not reported separately for symptomatic subgroup; All women in the study are known to have CAD; Data for women not reported as a subgroup; No outcomes of interest. [pmid: 16098814].
Salustri A, Fioretti PM, McNeill AJ, et al. Pharmacological stress echocardiography in the diagnosis of coronary artery disease and myocardial ischaemia: a comparison between dobutamine and dipyridamole. Eur Heart J. 1992;13(10):1356-62. Full-text exclusion reason(s): All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 1396808].
Salustri A, Pozzoli MM, Hermans W, et al. Relationship between exercise echocardiography and perfusion single-photon emission computed tomography in patients with single-vessel coronary artery disease. Am Heart J. 1992;124(1):75-83. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 1615830].
Samady H, Wackers FJ, Joska TM, et al. Pharmacologic stress perfusion imaging with adenosine: role of simultaneous low-level treadmill exercise. J Nucl Cardiol. 2002;9(2):188-96. Full-text exclusion reason(s): No women with symptomatic chest pain, or results are not reported separately for symptomatic subgroup; All women in the study are known to have CAD; Study does not compare one NIT to another or to diagnostic cardiac catheterization; Data for women not reported as a subgroup; No outcomes of interest. [pmid: 11986564].
Sampson UK, Dorbala S, Limaye A, et al. Diagnostic accuracy of rubidium-82 myocardial perfusion imaging with hybrid positron emission tomography/computed tomography in the detection of coronary artery disease. J Am Coll Cardiol. 2007;49(10):1052-8. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 17349884].
San Roman JA, Sanz-Ruiz R, Ortega JR, et al. Safety and predictors of complications with a new accelerated dobutamine stress echocardiography protocol. J Am Soc Echocardiogr. 2008;21(1):53-7. Full-text exclusion reason(s): All women in the study are known to have CAD; Study does not compare one NIT to another or to diagnostic cardiac catheterization; Data for women not reported as a subgroup. [pmid: 17628422].
San Roman JA, Vilacosta I, Castillo JA, et al. Dipyridamole and dobutamine-atropine stress echocardiography in the diagnosis of coronary artery disease. Comparison with exercise stress test, analysis of agreement, and impact of antianginal treatment. Chest. 1996;110(5):1248-54. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 8915229].
Sandstede JJ, Pabst T, Wacker C, et al. Breath-hold 3D MR coronary angiography with a new intravascular contrast agent (feruglose)—first clinical experiences. Magn Reson Imaging. 2001;19(2):201-5. Full-text exclusion reason(s): No women with symptomatic chest pain, or results are not reported separately for symptomatic subgroup; All women in the study are known to have CAD; Study does not compare one NIT to another or to diagnostic cardiac catheterization; Data for women not reported as a subgroup. [pmid: 11358658].
Santana CA, Folks RD, Garcia EV, et al. Quantitative (82)Rb PET/CT: development and validation of myocardial perfusion database. J Nucl Med. 2007;48(7):1122-8. Full-text exclusion reason(s): No women with symptomatic chest pain, or results are not reported separately for symptomatic subgroup; All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 17574973].
Santana CA, Garcia EV, Faber TL, et al. Diagnostic performance of fusion of myocardial perfusion imaging (MPI) and computed tomography coronary angiography. J Nucl Cardiol. 2009;16(2):201-11. Full-text exclusion reason(s): No women with symptomatic chest pain, or results are not reported separately for symptomatic subgroup; All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 19156478].
Santana CA, Garcia EV, Vansant JP, et al. Gated stress-only 99mTc myocardial perfusion SPECT imaging accurately assesses coronary artery disease. Nucl Med Commun. 2003;24(3):241-9. Full-text exclusion reason(s): No women with symptomatic chest pain, or results are not reported separately for symptomatic subgroup; All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 12612464].
Santoro GM, Sciagra R, Buonamici P, et al. Head-to-head comparison of exercise stress testing, pharmacologic stress echocardiography, and perfusion tomography as first-line examination for chest pain in patients without history of coronary artery disease. J Nucl Cardiol. 1998;5(1):19-27. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 9504869].
Sarasso G, Airoldi L, Piccinino C, et al. Detection of coronary artery disease in hypertensive patients with chest pain: Diagnostic accuracy of noninvasive techniques. Cardiovascular Imaging. 1999;11(3):133-136. Full-text exclusion reason(s): Full-text unobtainable.
Saraste M, Vesalainen RK, Ylitalo A, et al. Transthoracic Doppler echocardiography as a noninvasive tool to assess coronary artery stenoses—a comparison with quantitative coronary angiography. J Am Soc Echocardiogr. 2005;18(6):679-85. Full-text exclusion reason(s): No data for NITs of interest (ECG, ECHO, SPECT, PET, CMR, CTA). [pmid: 15947773].
Sardanelli F, Molinari G, Zandrino F, et al. Three-dimensional, navigator-echo MR coronary angiography in detecting stenoses of the major epicardial vessels, with conventional coronary angiography as the standard of reference. Radiology. 2000;214(3):808-14. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 10715050].
Sarno G, Decraemer I, Vanhoenacker PK, et al. On the inappropriateness of noninvasive multidetector computed tomography coronary angiography to trigger coronary revascularization: a comparison with invasive angiography. JACC Cardiovasc Interv. 2009;2(6):550-7. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 19539260].
Sarullo FM, Di Pasquale P, Orlando G, et al. Utility and safety of immediate exercise testing of low-risk patients admitted to the hospital with acute chest pain. Int J Cardiol. 2000;75(2–3):239-43. Full-text exclusion reason(s): Study does not compare one NIT to another or to diagnostic cardiac catheterization; Data for women not reported as a subgroup. [pmid: 11077140].
Sato A, Hiroe M, Tamura M, et al. Quantitative measures of coronary stenosis severity by 64-Slice CT angiography and relation to physiologic significance of perfusion in nonobese patients: comparison with stress myocardial perfusion imaging. J Nucl Med. 2008;49(4):564-72. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 18344444].
Sato A, Nozato T, Hikita H, et al. Incremental value of combining 64-slice computed tomography angiography with stress nuclear myocardial perfusion imaging to improve noninvasive detection of coronary artery disease. J Nucl Cardiol. 2010;17(1):19-26. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 19777317].
Sato Y, Matsumoto N, Ichikawa M, et al. Efficacy of multislice computed tomography for the detection of acute coronary syndrome in the emergency department. Circ J. 2005;69(9):1047-51. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 16127184].
Sato Y, Matsumoto N, Kato M, et al. Noninvasive assessment of coronary artery disease by multislice spiral computed tomography using a new retrospectively ECG-gated image reconstruction technique. Circ J. 2003;67(5):401-5. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 12736477].
Sawada SG, Ryan T, Conley MJ, et al. Prognostic value of a normal exercise echocardiogram. Am Heart J. 1990;120(1):49-55. Full-text exclusion reason(s): Study does not compare one NIT to another or to diagnostic cardiac catheterization. [pmid: 2360517].
Sawada SG, Sayyed S, Raiesdana A, et al. Clinical assessment and rest and stress echocardiography for prediction of long-term prognosis in African Americans with known or suspected coronary artery disease. Echocardiography. 2009;26(5):558-66. Full-text exclusion reason(s): No women with symptomatic chest pain, or results are not reported separately for symptomatic subgroup; All women in the study are known to have CAD; Study does not compare one NIT to another or to diagnostic cardiac catheterization; Data for women not reported as a subgroup. [pmid: 19452609].
Sawada SG, Segar DS, Ryan T, et al. Echocardiographic detection of coronary artery disease during dobutamine infusion. Circulation. 1991;83(5):1605-14. Full-text exclusion reason(s): No women with symptomatic chest pain, or results are not reported separately for symptomatic subgroup; All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 1673646].
Scalise F, Bertella M, Manfredi M, et al. Stress-induced QTc-interval shortening as an ancillary marker of ischemia in patients with complete left bundle branch block. J Cardiovasc Med (Hagerstown). 2009;10(5):376-82. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 19449454].
Scandrett RM, Mukherjee SK. Frontiers in women’s cardiovascular health prevention: What have we learned so far?. World Heart Journal. 2008;1(2):141-159. Full-text exclusion reason(s): Not original peer-reviewed data or a secondary analysis of RCT, prospective or retrospective observational study, or registry.
Scanlon PJ, Faxon DP, Audet AM, et al. ACC/AHA guidelines for coronary angiography A report of the American College of Cardiology/American Heart Association. Task Force on practice guidelines (Committee on Coronary Angiography). Developed in collaboration with the Society for Cardiac Angiography and Interventions. J Am Coll Cardiol. 1999;33(6):1756-824. Full-text exclusion reason(s): Not original peer-reviewed data or a secondary analysis of RCT, prospective or retrospective observational study, or registry. [pmid: 10334456].
Schannwell CM. Echocardiographic diastolic function: A sensitive noninvasive approach for the detection of coronary artery disease in women. 46th Annual Scientific Session of the American College of Cardiology. Anaheim, CA (USA). 16–19 Mar 1997. (World Meeting Number 971 0068). 1997. Full-text exclusion reason(s): No outcomes of interest.
Schartl M, Beckmann S, Bocksch W, et al. Stress echocardiography in special groups: In women, in left bundle branch block, in hypertension and after heart transplantation. Euro Heart J. 1997;18. Full-text exclusion reason(s): Not original peer-reviewed data or a secondary analysis of RCT, prospective or retrospective observational study, or registry.
Scheffel H, Alkadhi H, Leschka S, et al. Low-dose CT coronary angiography in the step-and-shoot mode: diagnostic performance. Heart. 2008;94(9):1132-7. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 18519548].
Scheffel H, Alkadhi H, Plass A, et al. Accuracy of dual-source CT coronary angiography: First experience in a high pre-test probability population without heart rate control. Eur Radiol. 2006;16(12):2739-47. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 17031451].
Scheffel H, Stolzmann P, Alkadhi H, et al. Low-dose CT and cardiac MR for the diagnosis of coronary artery disease: accuracy of single and combined approaches. Int J Cardiovasc Imaging. 2010;26(5):579-90. Full-text exclusion reason(s): All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 20146002].
Scheike M, Nilsson S, Nylander E. Exercise testing and myocardial perfusion scintigraphy in primary care patients with chest pain of new onset. Scand J Prim Health Care. 2007;25(2):117-22. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 17497490].
Schenker MP, Dorbala S, Hong EC, et al. Interrelation of coronary calcification, myocardial ischemia, and outcomes in patients with intermediate likelihood of coronary artery disease: a combined positron emission tomography/computed tomography study. Circulation. 2008;117(13):1693-700. Full-text exclusion reason(s): Study does not compare one NIT to another or to diagnostic cardiac catheterization; Data for women not reported as a subgroup. [pmid: 18362235].
Schepis T, Gaemperli O, Koepfli P, et al. Added value of coronary artery calcium score as an adjunct to gated SPECT for the evaluation of coronary artery disease in an intermediate-risk population. J Nucl Med. 2007;48(9):1424-30. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 17785727].
Scherhag AW, Pfleger S, Schreckenberger AB, et al. Detection of patients with restenosis after PTCA by dipyridamole-atropine-stress-echocardiography. Int J Card Imaging. 1997;13(2):115-23. Full-text exclusion reason(s): All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 9110191].
Schicha H, Rentrop P, Facorro L, et al. Results of quantitative myocardial scintigraphy with thallium-201 at rest and after maximum exercise—critical analysis of predictive value and clinical application (author’s transl). Z Kardiol. 1980;69(1):31-42. Full-text exclusion reason(s): Non-English. [pmid: 7415378].
Schillaci O, Moroni C, Scopinaro F, et al. Technetium-99m sestamibi myocardial tomography based on dipyridamole echocardiography testing in hypertensive patients with chest pain. Eur J Nucl Med. 1997;24(7):774-8. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 9211764].
Schinkel AF, Elhendy A, Biagini E, et al. Prognostic stratification using dobutamine stress 99mTc-tetrofosmin myocardial perfusion SPECT in elderly patients unable to perform exercise testing. J Nucl Med. 2005;46(1):12-8. Full-text exclusion reason(s): Study does not compare one NIT to another or to diagnostic cardiac catheterization; Data for women not reported as a subgroup. [pmid: 15632027].
Schinkel AF, Elhendy A, van Domburg RT, et al. Prognostic value of dobutamine-atropine stress (99m)Tc-tetrofosmin myocardial perfusion SPECT in patients with known or suspected coronary artery disease. J Nucl Med. 2002;43(6):767-72. Full-text exclusion reason(s): Study does not compare one NIT to another or to diagnostic cardiac catheterization; Data for women not reported as a subgroup. [pmid: 12050321].
Schinkel AF, Elhendy A, Van Domburg RT, et al. Long-term prognostic value of dobutamine stress 99mTc-sestamibi SPECT: single-center experience with 8-year follow-up. Radiology. 2002;225(3):701-6. Full-text exclusion reason(s): Study does not compare one NIT to another or to diagnostic cardiac catheterization; Data for women not reported as a subgroup. [pmid: 12461248].
Schinkel AF, Elhendy A, van Domburg RT, et al. Incremental value of exercise technetium-99m tetrofosmin myocardial perfusion single-photon emission computed tomography for the prediction of cardiac events. Am J Cardiol. 2003;91(4):408-11. Full-text exclusion reason(s): Study does not compare one NIT to another or to diagnostic cardiac catheterization; Data for women not reported as a subgroup. [pmid: 12586253].
Schlegel TT, Kulecz WB, Feiveson AH, et al. Accuracy of advanced versus strictly conventional 12-lead ECG for detection and screening of coronary artery disease, left ventricular hypertrophy and left ventricular systolic dysfunction. BMC Cardiovascular Disorders. 2010;10(28). Full-text exclusion reason(s): No data for NITs of interest (ECG, ECHO, SPECT, PET, CMR, CTA).
Schlett CL, Banerji D, Siegel E, et al. Prognostic value of CT angiography for major adverse cardiac events in patients with acute chest pain from the emergency department: 2-Year outcomes of the ROMICAT trial. JACC: Cardiovascular Imaging. 2011;4(5):481-491. Full-text exclusion reason(s): Data for women not reported as a subgroup; No outcomes of interest. [pmid: 21565735].
Schlosser T, Mohrs OK, Magedanz A, et al. Noninvasive coronary angiography using 64-detector-row computed tomography in patients with a low to moderate pretest probability of significant coronary artery disease. Acta Radiol. 2007;48(3):300-7. Full-text exclusion reason(s): Study does not compare one NIT to another or to diagnostic cardiac catheterization; Data for women not reported as a subgroup. [pmid: 17453500].
Schmermund A, Baumgart D, Sack S, et al. Assessment of coronary calcification by electron-beam computed tomography in symptomatic patients with normal, abnormal or equivocal exercise stress test. Eur Heart J. 2000;21(20):1674-82. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 11032694].
Schmermund A, Elsasser A, Behl M, et al. Comparison of prognostic usefulness (three years) of computed tomographic angiography versus 64-slice computed tomographic calcium scanner in subjects without significant coronary artery disease. Am J Cardiol. 2010;106(11):1574-9. Full-text exclusion reason(s): Study does not compare one NIT to another or to diagnostic cardiac catheterization; Data for women not reported as a subgroup. [pmid: 21094357].
Schmermund A, Stang A, Mohlenkamp S, et al. Prognostic value of electron-beam computed tomography-derived coronary calcium scores compared with clinical parameters in patients evaluated for coronary artery disease. Prognostic value of EBCT in symptomatic patients. Z Kardiol. 2004;93(9):696-705. Full-text exclusion reason(s): Study does not compare one NIT to another or to diagnostic cardiac catheterization; Data for women not reported as a subgroup. [pmid: 15365737].
Schmidt A, Stefenelli T, Schuster E, et al. Informational contribution of noninvasive screening tests for coronary artery disease in patients on chronic renal replacement therapy. Am J Kidney Dis. 2001;37(1):56-63. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 11136168].
Schnapauff D, Dubel HP, Scholze J, et al. Multislice computed tomography: angiographic emulation versus standard assessment for detection of coronary stenoses. Eur Radiol. 2007;17(7):1858-64. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 17206423].
Schoenhagen P, Tuzcu EM, Stillman AE, et al. Non-invasive assessment of plaque morphology and remodeling in mildly stenotic coronary segments: comparison of 16-slice computed tomography and intravascular ultrasound. Coron Artery Dis. 2003;14(6):459-62. Full-text exclusion reason(s): No women with symptomatic chest pain, or results are not reported separately for symptomatic subgroup; All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 12966267].
Schonenberger E, Schnapauff D, Teige F, et al. Patient acceptance of noninvasive and invasive coronary angiography. PLoS One. 2007;2(2):e246. Full-text exclusion reason(s): No women with symptomatic chest pain, or results are not reported separately for symptomatic subgroup; Data for women not reported as a subgroup; No outcomes of interest. [pmid: 17327910].
Schroder K, Voller H, Dingerkus H, et al. Comparison of the diagnostic potential of four echocardiographic stress tests shortly after acute myocardial infarction: submaximal exercise, transesophageal atrial pacing, dipyridamole, and dobutamine-atropine. Am J Cardiol. 1996;77(11):909-14. Full-text exclusion reason(s): All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 8644637].
Schroder K, Wieckhorst A, Voller H. Comparison of the prognostic value of dipyridamole and dobutamine stress echocardiography in patients with known or suspected coronary artery disease. Am J Cardiol. 1997;79(11):1516-8. Full-text exclusion reason(s): All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 9185644].
Schroeder S, Kuettner A, Beck T, et al. Usefulness of noninvasive MSCT coronary angiography as first-line imaging technique in patients with chest pain: initial clinical experience. Int J Cardiol. 2005;102(3):469-75. Full-text exclusion reason(s): All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 16004893].
Schuijf JD, Bax JJ. Noninvasive coronary angiography with multislice computed tomography and myocardial perfusion imaging. Cardiol Rev. 2007;24(6):38-41. Full-text exclusion reason(s): Data for women not reported as a subgroup.
Schuijf JD, Bax JJ, Jukema JW, et al. Assessment of left ventricular volumes and ejection fraction with 16-slice multi-slice computed tomography; comparison with 2D-echocardiography. Int J Cardiol. 2007;116(2):201-5. Full-text exclusion reason(s): All women in the study are known to have CAD; Data for women not reported as a subgroup; No outcomes of interest. [pmid: 16828899].
Schuijf JD, Bax JJ, Jukema JW, et al. Noninvasive angiography and assessment of left ventricular function using multislice computed tomography in patients with type 2 diabetes. Diabetes Care. 2004;27(12):2905-10. Full-text exclusion reason(s): All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 15562205].
Schuijf JD, Bax JJ, Salm LP, et al. Noninvasive coronary imaging and assessment of left ventricular function using 16-slice computed tomography. Am J Cardiol. 2005;95(5):571-4. Full-text exclusion reason(s): All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 15721093].
Schuijf JD, Mollet NR, Cademartiri F, et al. Do risk factors influence the diagnostic accuracy of noninvasive coronary angiography with multislice computed tomography?. J Nucl Cardiol. 2006;13(5):635-41. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 16945743].
Schuijf JD, Pundziute G, Bax JJ. Prognostic value of multislice computed tomography coronary angiography. Cardiol Rev. 2007;24(12):39-42. Full-text exclusion reason(s): No women with symptomatic chest pain, or results are not reported separately for symptomatic subgroup; All women in the study are known to have CAD; Study does not compare one NIT to another or to diagnostic cardiac catheterization; Data for women not reported as a subgroup.
Schuijf JD, Pundziute G, Jukema JW, et al. Diagnostic accuracy of 64-slice multislice computed tomography in the noninvasive evaluation of significant coronary artery disease. Am J Cardiol. 2006;98(2):145-8. Full-text exclusion reason(s): No women with symptomatic chest pain, or results are not reported separately for symptomatic subgroup; All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 16828582].
Schuijf JD, van Werkhoven JM, Pundziute G, et al. Invasive versus noninvasive evaluation of coronary artery disease. JACC Cardiovasc Imaging. 2008;1(2):190-9. Full-text exclusion reason(s): All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 19356428].
Schuijf JD, Wijns W, Jukema JW, et al. Relationship between noninvasive coronary angiography with multi-slice computed tomography and myocardial perfusion imaging. J Am Coll Cardiol. 2006;48(12):2508-14. Full-text exclusion reason(s): No women with symptomatic chest pain, or results are not reported separately for symptomatic subgroup; Data for women not reported as a subgroup. [pmid: 17174190].
Schuijf JD, Wijns W, Jukema JW, et al. A comparative regional analysis of coronary atherosclerosis and calcium score on multislice CT versus myocardial perfusion on SPECT. J Nucl Med. 2006;47(11):1749-55. Full-text exclusion reason(s): All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 17079806].
Schutzenberger W, Leisch F, Herbinger W. R amplitude changes and ST segment lowering in the exercise ECG compared with angiographic findings (author’s transl). Dtsch Med Wochenschr. 1980;105(37):1285-9. Full-text exclusion reason(s): Non-English. [pmid: 7418627].
Schwartz JG, Johnson RB, Aepfelbacher FC, et al. Sensitivity, specificity and accuracy of stress SPECT myocardial perfusion imaging for detection of coronary artery disease in the distribution of first-order branch vessels, using an anatomical matching of angiographic and perfusion data. Nucl Med Commun. 2003;24(5):543-9. Full-text exclusion reason(s): No women with symptomatic chest pain, or results are not reported separately for symptomatic subgroup; All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 12717072].
Schwartz L, Overgaard CB. The accuracy of noninvasive stress myocardial imaging for detecting coronary artery disease in clinical practice. Hosp Pract (Minneap). 2010;38(2):14-8. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 20469609].
Schwitter J, Nanz D, Kneifel S, et al. Assessment of myocardial perfusion in coronary artery disease by magnetic resonance: a comparison with positron emission tomography and coronary angiography. Circulation. 2001;103(18):2230-5. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 11342469].
Schwitter J, Wacker CM, van Rossum AC, et al. MR-IMPACT: comparison of perfusion-cardiac magnetic resonance with single-photon emission computed tomography for the detection of coronary artery disease in a multicentre, multivendor, randomized trial. Eur Heart J. 2008;29(4):480-9. Full-text exclusion reason(s): All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 18208849].
Sciagra R, Zoccarato O, Bisi G, et al. Decreased [99mTc]Sestamibi uptake with dobutamine versus dipyridamole stress. Q J Nucl Med Mol Imaging. 2009;53(6):671-7. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 20016457].
Sciammarella MG, Fragasso G, Gerundini P, et al. 99Tcm-MIBI single photon emission tomography (SPET) for detecting myocardial ischaemia and necrosis in patients with significant coronary artery disease. Nucl Med Commun. 1992;13(12):871-8. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 1465270].
Seeck A, Garde A, Schuepbach M, et al. Diagnosis of ischemic heart disease with cardiogoniometry - Linear discriminant analysis versus support vector machines. IFMBE Proceedings. 2008;22:389-392. Full-text exclusion reason(s): Conference abstract or trial registry posting.
Seeger A, Doesch C, Klumpp B, et al. MR stress perfusion for the detection of flow-limiting stenoses in symptomatic patients with known coronary artery disease and history of stent implantation. Rofo. 2007;179(10):1068-73. Full-text exclusion reason(s): Non-English. [pmid: 17879175].
Seese B, Moshage W, Achenbach S, et al. Diagnostic value of coronary calcifications for non-invasive detection of coronary artery disease: A comparison of electron beam tomography, thoracic fluoroscopy and coronary angiography. XVIIth Congress of the European Society of Cardiology. Amsterdam (The Netherlands). 20–24 Aug 1995. (World Meeting Number 953 0126). 1995. Full-text exclusion reason(s): Conference abstract or trial registry posting.
Segar DS, Brown SE, Sawada SG, et al. Dobutamine stress echocardiography: correlation with coronary lesion severity as determined by quantitative angiography. J Am Coll Cardiol. 1992;19(6):1197-202. Full-text exclusion reason(s): No women with symptomatic chest pain, or results are not reported separately for symptomatic subgroup; All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 1564220].
Selcoki Y, Yilmaz OC, Kankilic MN, et al. Diagnostic accuracy of 64-slice computed tomography in patients with suspected or proven coronary artery disease. Turk Kardiyol Dern Ars. 2010;38(2):95-100. Full-text exclusion reason(s): All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 20473010].
Senior R, Basu S, Handler C, et al. Diagnostic accuracy of dobutamine stress echocardiography for detection of coronary heart disease in hypertensive patients. Eur Heart J. 1996;17(2):289-95. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 8732384].
Senior R, Becher H, Monaghan M, et al. Contrast echocardiography: evidence-based recommendations by European Association of Echocardiography. Eur J Echocardiogr. 2009;10(2):194-212. Full-text exclusion reason(s): Not original peer-reviewed data or a secondary analysis of RCT, prospective or retrospective observational study, or registry. [pmid: 19270054].
Senior R, Janardhanan R, Jeetley P, et al. Myocardial contrast echocardiography for distinguishing ischemic from nonischemic first-onset acute heart failure: insights into the mechanism of acute heart failure. Circulation. 2005;112(11):1587-93. Full-text exclusion reason(s): No women with symptomatic chest pain, or results are not reported separately for symptomatic subgroup; Data for women not reported as a subgroup. [pmid: 16144997].
Senior R, Khattar R, Lahiri A. Value of dobutamine stress echocardiography for the detection of multivessel coronary artery disease. Am J Cardiol. 1998;81(3):298-301. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 9468071].
Senior R, Lepper W, Pasquet A, et al. Myocardial perfusion assessment in patients with medium probability of coronary artery disease and no prior myocardial infarction: comparison of myocardial contrast echocardiography with 99mTc single-photon emission computed tomography. Am Heart J. 2004;147(6):1100-5. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 15199362].
Senior R, Monaghan M, Main ML, et al. Detection of coronary artery disease with perfusion stress echocardiography using a novel ultrasound imaging agent: two Phase 3 international trials in comparison with radionuclide perfusion imaging. Eur J Echocardiogr. 2009;10(1):26-35. Full-text exclusion reason(s): No women with symptomatic chest pain, or results are not reported separately for symptomatic subgroup; Data for women not reported as a subgroup. [pmid: 19131498].
Senior R, Sridhara BS, Anagnostou E, et al. Synergistic value of simultaneous stress dobutamine sestamibi single-photon-emission computerized tomography and echocardiography in the detection of coronary artery disease. Am Heart J. 1994;128(4):713-8. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 7942442].
Sensky PR, Jivan A, Hudson NM, et al. Coronary artery disease: combined stress MR imaging protocol-one-stop evaluation of myocardial perfusion and function. Radiology. 2000;215(2):608-14. Full-text exclusion reason(s): No women with symptomatic chest pain, or results are not reported separately for symptomatic subgroup; All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 10796946].
Sensky PR, Samani NJ, Reek C, et al. Magnetic resonance perfusion imaging in patients with coronary artery disease: a qualitative approach. Int J Cardiovasc Imaging. 2002;18(5):373-83. discussion 385–6. Full-text exclusion reason(s): No women with symptomatic chest pain, or results are not reported separately for symptomatic subgroup; All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 12194678].
Seo WW, Chang HJ, Cho I, et al. The value of brachial-ankle pulse wave velocity as a predictor of coronary artery disease in high-risk patients. Korean Circulation Journal. 2010;40(5):224-229. Full-text exclusion reason(s): No data for NITs of interest (ECG, ECHO, SPECT, PET, CMR, CTA). [pmid: 20514332].
Shabestari AA, Abdi S, Akhlaghpoor S, et al. Diagnostic performance of 64-channel multislice computed tomography in assessment of significant coronary artery disease in symptomatic subjects. Am J Cardiol. 2007;99(12):1656-61. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 17560870].
Shah DJ, Judd RM, Kim RJ. Technology insight: MRI of the myocardium. Nat Clin Pract Cardiovasc Med. 2005;2(11):597-605. quiz 606. Full-text exclusion reason(s): Not original peer-reviewed data or a secondary analysis of RCT, prospective or retrospective observational study, or registry. [pmid: 16258572].
Shaheen J, Luria D, Klutstein MW, et al. Diagnostic value of 12-lead electrocardiogram during dobutamine echocardiographic studies. Am Heart J. 1998;136(6):1061-4. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 9842020].
Shapiro MD, Butler J, Rieber J, et al. Analytic approaches to establish the diagnostic accuracy of coronary computed tomography angiography as a tool for clinical decision making. Am J Cardiol. 2007;99(8):1122-7. Full-text exclusion reason(s): All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 17437740].
Sharir T, Bacher-Stier C, Dhar S, et al. Identification of severe and extensive coronary artery disease by postexercise regional wall motion abnormalities in Tc-99m sestamibi gated single-photon emission computed tomography. Am J Cardiol. 2000;86(11):1171-5. Full-text exclusion reason(s): All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 11090786].
Sharir T, Kang X, Germano G, et al. Prognostic value of poststress left ventricular volume and ejection fraction by gated myocardial perfusion SPECT in women and men: gender-related differences in normal limits and outcomes. J Nucl Cardiol. 2006;13(4):495-506. Full-text exclusion reason(s): Study does not compare one NIT to another or to diagnostic cardiac catheterization. [pmid: 16919573].
Sharp SM, Sawada SG, Segar DS, et al. Dobutamine stress echocardiography: detection of coronary artery disease in patients with dilated cardiomyopathy. J Am Coll Cardiol. 1994;24(4):934-9. Full-text exclusion reason(s): All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 7930227].
Sharples L, Hughes V, Crean A, et al. Cost-effectiveness of functional cardiac testing in the diagnosis and management of coronary artery disease: a randomised controlled trial. The CECaT trial. Health Technol Assess. 2007;11(49):iii-iv. ix-115. Full-text exclusion reason(s): All women in the study are known to have CAD; Data for women not reported as a subgroup.
Shavelle DM, Budoff MJ, LaMont DH, et al. Exercise testing and electron beam computed tomography in the evaluation of coronary artery disease. J Am Coll Cardiol. 2000;36(1):32-8. Full-text exclusion reason(s): All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 10898409].
Shaw LJ, Bairey Merz CN, Pepine CJ, et al. Insights from the NHLBI-Sponsored Women’s Ischemia Syndrome Evaluation (WISE) Study: Part I: gender differences in traditional and novel risk factors, symptom evaluation, and gender-optimized diagnostic strategies. J Am Coll Cardiol. 2006;47(3 Suppl):S4-S20. Full-text exclusion reason(s): Not a clinical study report. [pmid: 16458170].
Shaw LJ, Berman DS, Hendel RC, et al. Prognosis by coronary computed tomographic angiography: matched comparison with myocardial perfusion single-photon emission computed tomography. J Cardiovasc Comput Tomogr. 2008;2(2):93-101. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 19083928].
Shaw LJ, Gillam L, Feinstein S, et al. Use of an intravenous contrast agent (Optison) to enhance echocardiography: efficacy and cost implications. Optison Multicenter Study Group. Am J Manag Care. 1998;4. Spec No:SP169-76. Full-text exclusion reason(s): No women with symptomatic chest pain, or results are not reported separately for symptomatic subgroup; All women in the study are known to have CAD; Data for women not reported as a subgroup.
Shaw LJ, Hachamovitch R, Berman DS, et al. The economic consequences of available diagnostic and prognostic strategies for the evaluation of stable angina patients: an observational assessment of the value of precatheterization ischemia. Economics of Noninvasive Diagnosis (END) Multicenter Study Group. J Am Coll Cardiol. 1999;33(3):661-9. Full-text exclusion reason(s): Study does not compare one NIT to another or to diagnostic cardiac catheterization; No outcomes of interest. [pmid: 10080466].
Shaw LJ, Hachamovitch R, Redberg RF. Current evidence on diagnostic testing in women with suspected coronary artery disease: choosing the appropriate test. Cardiol Rev. 2000;8(1):65-74. Full-text exclusion reason(s): Not original peer-reviewed data or a secondary analysis of RCT, prospective or retrospective observational study, or registry. [pmid: 11174875].
Shaw LJ, Hendel R, Borges-Neto S, et al. Prognostic value of normal exercise and adenosine (99m)Tc-tetrofosmin SPECT imaging: results from the multicenter registry of 4,728 patients. J Nucl Med. 2003;44(2):134-9. Full-text exclusion reason(s): All women in the study are known to have CAD; Study does not compare one NIT to another or to diagnostic cardiac catheterization. [pmid: 12571200].
Shaw LJ, Hendel RC, Cerquiera M, et al. Ethnic differences in the prognostic value of stress technetium-99m tetrofosmin gated single-photon emission computed tomography myocardial perfusion imaging. J Am Coll Cardiol. 2005;45(9):1494-504. Full-text exclusion reason(s): All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 15862425].
Shaw LJ, Marwick TH, Berman DS, et al. Incremental cost-effectiveness of exercise echocardiography vs. SPECT imaging for the evaluation of stable chest pain. Eur Heart J. 2006;27(20):2448-58. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 17003046].
Shaw LJ, Mieres JH. The role of noninvasive testing in the diagnosis and prognosis of women with suspected CAD. J Fam Pract. Suppl. 2005:4-5. 7. Full-text exclusion reason(s): Not original peer-reviewed data or a secondary analysis of RCT, prospective or retrospective observational study, or registry. [pmid: 16134556].
Shaw LJ, Min JK, Narula J, et al. Sex differences in mortality associated with computed tomographic angiographic measurements of obstructive and nonobstructive coronary artery disease: an exploratory analysis. Circ Cardiovasc Imaging. 2010;3(4):473-81. Full-text exclusion reason(s): No women with symptomatic chest pain, or results are not reported separately for symptomatic subgroup; All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 20484543].
Shaw LJ, Vasey C, Sawada S, et al. Impact of gender on risk stratification by exercise and dobutamine stress echocardiography: long-term mortality in 4234 women and 6898 men. Eur Heart J. 2005;26(5):447-56. Full-text exclusion reason(s): No women with symptomatic chest pain, or results are not reported separately for symptomatic subgroup; All women in the study are known to have CAD; Study does not compare one NIT to another or to diagnostic cardiac catheterization. [pmid: 15687253].
Shaw LJ, Wilson PW, Hachamovitch R, et al. Improved near-term coronary artery disease risk classification with gated stress myocardial perfusion SPECT. JACC Cardiovasc Imaging. 2010;3(11):1139-48. Full-text exclusion reason(s): Study does not compare one NIT to another or to diagnostic cardiac catheterization; Data for women not reported as a subgroup. [pmid: 21071002].
Sheikh M, Ben-Nakhi A, Shukkur AM, et al. Accuracy of 64-multidetector-row computed tomography in the diagnosis of coronary artery disease. Med Princ Pract. 2009;18(4):323-8. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 19494542].
Sheldon SH, Askew JW 3rd, Klarich KW, et al. Occurrence of atrial fibrillation during dobutamine stress echocardiography: incidence, risk factors, and outcomes. J Am Soc Echocardiogr. 2011;24(1):86-90. Full-text exclusion reason(s): No women with symptomatic chest pain, or results are not reported separately for symptomatic subgroup; Study does not compare one NIT to another or to diagnostic cardiac catheterization; Data for women not reported as a subgroup; No outcomes of interest. [pmid: 21172598].
Shelley S, Sathyamurthy I, Madhavan, et al. Adenosine myocardial SPECT—its efficacy and safety and correlation with coronary angiogram. J Assoc Physicians India. 2003;51:557-60. Full-text exclusion reason(s): All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 15266920].
Shen Y, Qian JY, Wang MH, et al. Quantitative and qualitative assessment of non-obstructive left main coronary artery plaques using 64-multislice computed tomography compared with intravascular ultrasound. Chin Med J (Engl). 2010;123(7):827-33. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 20497672].
Shenoy MM, Sengupta R, Khanna A. Atrial pacing stress echocardiography: an alternative diagnostic test for chest pain in the elderly. Am J Geriatr Cardiol. 2002;11(6):404-9. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 12417847].
Sheth T, Amlani S, Ellins ML, et al. Computed tomographic coronary angiographic assessment of high-risk coronary anatomy in patients with suspected coronary artery disease and intermediate pretest probability. Am Heart J. 2008;155(5):918-23. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 18440342].
Sheth TN, Rieber J, Mooyaart EA, et al. Usefulness of coronary computed tomographic angiography to assess suitability for revascularization in patients with significant coronary artery disease and angina pectoris. Am J Cardiol. 2006;98(9):1198-201. Full-text exclusion reason(s): All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 17056327].
Shi H, Aschoff AJ, Brambs HJ, et al. Multislice CT imaging of anomalous coronary arteries. Eur Radiol. 2004;14(12):2172-81. Full-text exclusion reason(s): All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 15490179].
Shi H, Han P, Kong X, et al. Noninvasive detection of coronary artery stenosis using 16-slice spiral CT: a comparison with selective X-ray coronary angiography. J Huazhong Univ Sci Technolog Med Sci. 2006;26(3):338-40. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 16961287].
Shiba C, Chikamori T, Hida S, et al. Important parameters in the detection of left main trunk disease using stress myocardial perfusion imaging. J Cardiol. 2009;53(1):43-52. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 19167637].
Shimoni S, Goland S, Livshitz S, et al. Accuracy and long-term prognostic value of pacing stress echocardiography compared with dipyridamole Tl emission computed tomography in patients with a permanent pacemaker and known or suspected coronary artery disease. Cardiology. 2010;116(3):229-236. Full-text exclusion reason(s): No women with symptomatic chest pain, or results are not reported separately for symptomatic subgroup; All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 20693801].
Shimoni S, Zoghbi WA, Xie F, et al. Real-time assessment of myocardial perfusion and wall motion during bicycle and treadmill exercise echocardiography: comparison with single photon emission computed tomography. J Am Coll Cardiol. 2001;37(3):741-7. Full-text exclusion reason(s): No women with symptomatic chest pain, or results are not reported separately for symptomatic subgroup; All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 11693746].
Shin JH, Pokharna HK, Williams KA, et al. SPECT myocardial perfusion imaging with prone-only acquisitions: correlation with coronary angiography. J Nucl Cardiol. 2009;16(4):590-6. Full-text exclusion reason(s): No women with symptomatic chest pain, or results are not reported separately for symptomatic subgroup; Data for women not reported as a subgroup. [pmid: 19466502].
Shirai N, Yamagishi H, Yoshiyama M, et al. Incremental value of assessment of regional wall motion for detection of multivessel coronary artery disease in exercise (201)Tl gated myocardial perfusion imaging. J Nucl Med. 2002;43(4):443-50. Full-text exclusion reason(s): All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 11937586].
Shiyovich A, Jafari J, Blaer Y, et al. Respiratory stress response: a novel diagnostic method for detection of significant coronary artery disease from finger pulse wave analysis during brief respiratory exercise. Am J Med Sci. 2010;339(5):440-7. Full-text exclusion reason(s): Article retracted. [pmid: 20234302].
Shry EA, Eckart RE, Furgerson JL, et al. Addition of right-sided and posterior precordial leads during stress testing. Am Heart J. 2003;146(6):1090-4. Full-text exclusion reason(s): No women with symptomatic chest pain, or results are not reported separately for symptomatic subgroup; All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 14661004].
Shuman WP, Branch KR, May JM, et al. Whole-chest 64-MDCT of emergency department patients with nonspecific chest pain: Radiation dose and coronary artery image quality with prospective ECG triggering versus retrospective ECG gating. AJR Am J Roentgenol. 2009;192(6):1662-7. Full-text exclusion reason(s): Study does not compare one NIT to another or to diagnostic cardiac catheterization; Data for women not reported as a subgroup. [pmid: 19457832].
Shuman WP, May JM, Branch KR, et al. Negative ECG-gated cardiac CT in patients with low-to-moderate risk chest pain in the emergency department: 1-year follow-up. AJR Am J Roentgenol. 2010;195(4):923-7. Full-text exclusion reason(s): Study does not compare one NIT to another or to diagnostic cardiac catheterization; Data for women not reported as a subgroup. [pmid: 20858819].
Sicari R, Pasanisi E, Venneri L, et al. Stress echo results predict mortality: a large-scale multicenter prospective international study. J Am Coll Cardiol. 2003;41(4):589-95. Full-text exclusion reason(s): Study does not compare one NIT to another or to diagnostic cardiac catheterization. [pmid: 12598070].
Sidhu M, Bhalla M, Chockalingam A, et al. Pertinence of myocardial perfusion imaging in octogenarians. Angiology. 2010;61(3):294-6. Full-text exclusion reason(s): All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 19689991].
Siebelink HM, Blanksma PK, Crijns HJ, et al. No difference in cardiac event-free survival between positron emission tomography-guided and single-photon emission computed tomography-guided patient management: a prospective, randomized comparison of patients with suspicion of jeopardized myocardium. J Am Coll Cardiol. 2001;37(1):81-8. Full-text exclusion reason(s): No women with symptomatic chest pain, or results are not reported separately for symptomatic subgroup; All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 11153777].
Siennicki J, Kusmierek J, Kovacevic-Kusmierek K, et al. The effect of image translation table on diagnostic efficacy of myocardial perfusion SPECT studies. Nucl Med Rev. 2010;13(2):64-69. Full-text exclusion reason(s): Data for women not reported as a subgroup.
Sikdar S, Beach KW, Goldberg SL, et al. Ultrasonic Doppler vibrometry: measurement of left ventricular wall vibrations associated with coronary artery disease. Conf Proc IEEE Eng Med Biol Soc. 2006;1:863-6. Full-text exclusion reason(s): No data for NITs of interest (ECG, ECHO, SPECT, PET, CMR, CTA). [pmid: 17946866].
Sikdar S, Lee JC, Remington J, et al. Ultrasonic Doppler vibrometry: novel method for detection of left ventricular wall vibrations caused by poststenotic coronary flow. J Am Soc Echocardiogr. 2007;20(12):1386-92. Full-text exclusion reason(s): No data for NITs of interest (ECG, ECHO, SPECT, PET, CMR, CTA). [pmid: 17764895].
Simone GL, Mullani NA, Page DA, et al. Utilization statistics and diagnostic accuracy of a nonhospital-based positron emission tomography center for the detection of coronary artery disease using rubidium-82. Am J Physiol Imaging. 1992;7(3–4):203-9. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 1343217].
Simonetti I, Rezai K, Rossen JD, et al. Physiological assessment of sensitivity of noninvasive testing for coronary artery disease. Circulation. 1991;83(5 SUPPL). Full-text exclusion reason(s): Not original peer-reviewed data or a secondary analysis of RCT, prospective or retrospective observational study, or registry.
Simova I, Katova T, Denchev S, et al. Flow-mediated dilatation has an additive value to stress ECG for the diagnosis of angiographically significant coronary atherosclerosis. J Am Soc Hypertens. 2010;4(4):203-8. Full-text exclusion reason(s): No women with symptomatic chest pain, or results are not reported separately for symptomatic subgroup; All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 20655504].
Sinha AM, Mahnken AH, Borghans A, et al. Multidetector-row computed tomography vs. angiography and intravascular ultrasound for the evaluation of the diameter of proximal coronary arteries. Int J Cardiol. 2006;110(1):40-5. Full-text exclusion reason(s): No women with symptomatic chest pain, or results are not reported separately for symptomatic subgroup; All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 16169611].
Sirol M, Sanz J, Henry P, et al. Evaluation of 64-slice MDCT in the real world of cardiology: a comparison with conventional coronary angiography. Arch Cardiovasc Dis. 2009;102(5):433-9. Full-text exclusion reason(s): No women with symptomatic chest pain, or results are not reported separately for symptomatic subgroup; All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 19520329].
Sitges M, Azqueta M, Pare C, et al. Dobutamine stress echocardiography and exercise electrocardiography for risk stratification in medically treated unstable angina. J Am Soc Echocardiogr. 2000;13(12):1084-90. Full-text exclusion reason(s): All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 11119276].
Slart RH, Zeebregts CJ, Hillege HL, et al. Myocardial perfusion reserve after a PET-driven revascularization procedure: a strong prognostic factor. J Nucl Med. 2011;52(6):873-9. Full-text exclusion reason(s): All women in the study are known to have CAD; Study does not compare one NIT to another or to diagnostic cardiac catheterization; Data for women not reported as a subgroup. [pmid: 21571798].
Smart SC, Bhatia A, Hellman R, et al. Dobutamine-atropine stress echocardiography and dipyridamole sestamibi scintigraphy for the detection of coronary artery disease: limitations and concordance. J Am Coll Cardiol. 2000;36(4):1265-73. Full-text exclusion reason(s): No women with symptomatic chest pain, or results are not reported separately for symptomatic subgroup; All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 11028482].
Smart SC, Knickelbine T, Malik F, et al. Dobutamine-atropine stress echocardiography for the detection of coronary artery disease in patients with left ventricular hypertrophy. Importance of chamber size and systolic wall stress. Circulation. 2000;101(3):258-63. Full-text exclusion reason(s): All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 10645921].
Smart SC, Knickelbine T, Stoiber TR, et al. Safety and accuracy of dobutamine-atropine stress echocardiography for the detection of residual stenosis of the infarct-related artery and multivessel disease during the first week after acute myocardial infarction. Circulation. 1997;95(6):1394-401. Full-text exclusion reason(s): All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 9118505].
Smit MD, Tio RA, Slart RH, et al. Myocardial perfusion imaging does not adequately assess the risk of coronary artery disease in patients with atrial fibrillation. Europace. 2010;12(5):643-8. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 20022875].
So NM, Lam WW, Li D, et al. Magnetic resonance angiography of coronary arteries with a 3-dimensional magnetization-prepared true fast imaging with steady-state precession sequence compared with conventional coronary angiography. Am Heart J. 2005;150(3):530-5. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 16169336].
Sochowski RA, Yvorchuk KJ, Yang Y, et al. Dobutamine and dipyridamole stress echocardiography in patients with a low incidence of severe coronary artery disease. J Am Soc Echocardiogr. 1995;8(4):482-7. Full-text exclusion reason(s): No women with symptomatic chest pain, or results are not reported separately for symptomatic subgroup; Data for women not reported as a subgroup. [pmid: 7546784].
Solot G, Hermans J, Merlo P, et al. Correlation of 99Tcm-sestamibi SPECT with coronary angiography in general hospital practice. Nucl Med Commun. 1993;14(1):23-9. Full-text exclusion reason(s): All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 8423930].
Soman P, Khattar R, Senior R, et al. Inotropic stress with arbutamine is superior to vasodilator stress with dipyridamole for the detection of reversible ischemia with Tc-99m sestamibi single-photon emission computed tomography. J Nucl Cardiol. 1997;4(5):364-71. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 9362012].
Soman P, Parsons A, Lahiri N, et al. The prognostic value of a normal Tc-99m sestamibi SPECT study in suspected coronary artery disease. J Nucl Cardiol. 1999;6(3):252-6. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 10385180].
Sommer T, Hackenbroch M, Hofer U, et al. Coronary MR angiography at 3.0 T versus that at 1.5 T: initial results in patients suspected of having coronary artery disease. Radiology. 2005;234(3):718-25. Full-text exclusion reason(s): No women with symptomatic chest pain, or results are not reported separately for symptomatic subgroup; Data for women not reported as a subgroup. [pmid: 15665221].
Soofi MA, Khan SA. Dobutamine stress echocardiography as a prognostic tool for future cardiac events. Ann Saudi Med. 2008;28(5):371-3. Full-text exclusion reason(s): No women with symptomatic chest pain, or results are not reported separately for symptomatic subgroup; All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 18779638].
Soon KH, Chaitowitz I, Cox N, et al. Diagnostic accuracy of 16-slice CT coronary angiography in the evaluation of coronary artery disease. Australas Radiol. 2007;51(4):365-9. Full-text exclusion reason(s): No women with symptomatic chest pain, or results are not reported separately for symptomatic subgroup; Data for women not reported as a subgroup. [pmid: 17635475].
Soon KH, Cox N, Chaitowitz I, et al. Determining the proportion of coronary segments assessable on 16-slice CT coronary angiography: a brief report. Australas Radiol. 2007;51(2):139-42. Full-text exclusion reason(s): All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 17419857].
Soon KH, Kelly AM, Cox N, et al. Practicality, safety and accuracy of computed tomography coronary angiography in the evaluation of low TIMI-risk score chest pain patients: a pilot study. Emerg Med Australas. 2007;19(2):129-35. Full-text exclusion reason(s): All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 17448098].
Sosnowski M, Pysz P, Gola A, et al. Coronary artery visualization using a 64-row multi-slice computed tomography in unselected patients with definite or suspected coronary artery disease: a comparison with invasive coronary angiography. Cardiol J. 2009;16(5):413-7. Full-text exclusion reason(s): All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 19753519].
Sosnowski M, Pysz P, Szymanski L, et al. Negative calcium score and the presence of obstructive coronary lesions in patients with intermediate CAD probability. Int J Cardiol. 2011;148(1):e16-e18. Full-text exclusion reason(s): Data for women not reported as a subgroup; No outcomes of interest. [pmid: 19324431].
Southard J, Baker L, Schaefer S. In search of the false-negative exercise treadmill testing evidence-based use of exercise echocardiography. Clin Cardiol. 2008;31(1):35-40. Full-text exclusion reason(s): All women in the study are known to have CAD. [pmid: 18203117].
Soylu O, Celik S, Karakus G, et al. Transthoracic Doppler echocardiographic coronary flow imaging in identification of left anterior descending coronary artery stenosis in patients with left bundle branch block. Echocardiography. 2008;25(10):1065-70. Full-text exclusion reason(s): All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 18771545].
Sozzi FB, Civaia F, Rossi P, et al. Long-term follow-up of patients with first-time chest pain having 64-slice computed tomography. Am J Cardiol. 2011;107(4):516-21. Full-text exclusion reason(s): Study does not compare one NIT to another or to diagnostic cardiac catheterization; Data for women not reported as a subgroup. [pmid: 21184991].
Sozzi FB, Elhendy A, Roelandt JR, et al. Prognostic value of dobutamine stress echocardiography in patients with diabetes. Diabetes Care. 2003;26(4):1074-8. Full-text exclusion reason(s): No women with symptomatic chest pain, or results are not reported separately for symptomatic subgroup; All women in the study are known to have CAD; Study does not compare one NIT to another or to diagnostic cardiac catheterization; Data for women not reported as a subgroup. [pmid: 12663576].
Sozzi FB, Poldermans D, Bax JJ, et al. Second harmonic imaging improves sensitivity of dobutamine stress echocardiography for the diagnosis of coronary artery disease. Am Heart J. 2001;142(1):153-9. Full-text exclusion reason(s): All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 11431672].
Srivastava AV, Ananthasubramaniam K, Patel SJ, et al. Prognostic implications of negative dobutamine stress echocardiography in African Americans compared to Caucasians. Cardiovasc Ultrasound. 2008;6:20. Full-text exclusion reason(s): All women in the study are known to have CAD; Study does not compare one NIT to another or to diagnostic cardiac catheterization; Data for women not reported as a subgroup. [pmid: 18492249].
Staniloff HM, Forrester JS, Berman DS, et al. Prediction of death, myocardial infarction, and worsening chest pain using thallium scintigraphy and exercise electrocardiography. J Nucl Med. 1986;27(12):1842-8. Full-text exclusion reason(s): Study does not compare one NIT to another or to diagnostic cardiac catheterization; Data for women not reported as a subgroup. [pmid: 3491191].
Starr H, Powers L, Safranek S. Clinical Inquiries: What is the best noninvasive diagnostic test for women with suspected CAD?. J Fam Pract. 2010;59(9):534-5. Full-text exclusion reason(s): Not a clinical study report. [pmid: 20824233].
Steel K, Broderick R, Gandla V, et al. Complementary prognostic values of stress myocardial perfusion and late gadolinium enhancement imaging by cardiac magnetic resonance in patients with known or suspected coronary artery disease. Circulation. 2009;120(14):1390-400. Full-text exclusion reason(s): All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 19770399].
Stegger L, Lipke CS, Kies P, et al. Quantification of left ventricular volumes and ejection fraction from gated 99mTc-MIBI SPECT: validation of an elastic surface model approach in comparison to cardiac magnetic resonance imaging, 4D-MSPECT and QGS. Eur J Nucl Med Mol Imaging. 2007;34(6):900-9. Full-text exclusion reason(s): All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 17216166].
Stein PD, Beemath A, Kayali F, et al. Multidetector computed tomography for the diagnosis of coronary artery disease: a systematic review. Am J Med. 2006;119(3):203-16. Full-text exclusion reason(s): Not original peer-reviewed data or a secondary analysis of RCT, prospective or retrospective observational study, or registry. [pmid: 16490463].
Stein PD, Yaekoub AY, Matta F, et al. 64-slice CT for diagnosis of coronary artery disease: a systematic review. Am J Med. 2008;121(8):715-25. Full-text exclusion reason(s): Not original peer-reviewed data or a secondary analysis of RCT, prospective or retrospective observational study, or registry. [pmid: 18691486].
Steingart RM, Hodnett P, Musso J, et al. Exercise myocardial perfusion imaging in elderly patients. J Nucl Cardiol. 2002;9(6):573-80. Full-text exclusion reason(s): All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 12466780].
Stewart RE, Schwaiger M, Molina E, et al. Comparison of rubidium-82 positron emission tomography and thallium-201 SPECT imaging for detection of coronary artery disease. Am J Cardiol. 1991;67(16):1303-10. Full-text exclusion reason(s): No women with symptomatic chest pain, or results are not reported separately for symptomatic subgroup; All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 2042560].
Stolzmann P, Alkadhi H, Scheffel H, et al. Combining cardiac magnetic resonance and computed tomography coronary calcium scoring: added value for the assessment of morphological coronary disease?. Int J Cardiovasc Imaging. 2010. Full-text exclusion reason(s): Data for women not reported as a subgroup.
Stolzmann P, Donati OF, Scheffel H, et al. Low-dose CT coronary angiography for the prediction of myocardial ischaemia. Eur Radiol. 2010;20(1):56-64. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 19657647].
Stolzmann P, Goetti R, Baumueller S, et al. Prospective and retrospective ECG-gating for CT coronary angiography perform similarly accurate at low heart rates. Euro J Radiol. 2011;79(1):85-91. Full-text exclusion reason(s): Data for women not reported as a subgroup.
Stolzmann P, Scheffel H, Leschka S, et al. Influence of calcifications on diagnostic accuracy of coronary CT angiography using prospective ECG triggering. AJR Am J Roentgenol. 2008;191(6):1684-9. Full-text exclusion reason(s): No women with symptomatic chest pain, or results are not reported separately for symptomatic subgroup; Data for women not reported as a subgroup. [pmid: 19020236].
Stratmann HG, Mark AL, Walter KE, et al. Prognostic value of atrial pacing and thallium-201 scintigraphy in patients with stable chest pain. Am J Cardiol. 1989;64(16):985-90. Full-text exclusion reason(s): Study does not compare one NIT to another or to diagnostic cardiac catheterization; Data for women not reported as a subgroup. [pmid: 2816758].
Stratmann HG, Williams GA, Wittry MD, et al. Exercise technetium-99m sestamibi tomography for cardiac risk stratification of patients with stable chest pain. Circulation. 1994;89(2):615-22. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 8313549].
Strobeck JE, Shen JT, Singh B, et al. Comparison of a two-lead, computerized, resting ECG signal analysis device, the MultiFunction-CardioGram or MCG (a.k.a. 3DMP), to quantitative coronary angiography for the detection of relevant coronary artery stenosis (>70%) - a meta-analysis of all published trials performed and analyzed in the US. Int J Med Sci. 2009;6(4):143-55. Full-text exclusion reason(s): Not original peer-reviewed data or a secondary analysis of RCT, prospective or retrospective observational study, or registry. [pmid: 19381351].
Sugihara H, Tamaki N, Mitsunami K, et al. Prognostic value of 1-day stress/rest electrocardiogram-gated single-photon emission computed tomography using Tc-99m-labeled methoxy-isobutyl isonitrile. Jpn Circ J. 1998;62(6):405-8. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 9652314].
Sumanen M, Jussila M, Mattila K. Exercise treadmill test may predict clinical outcome among working-aged patients suspected of coronary heart disease in general practice. Scand J Prim Health Care. 2005;23(1):47-51. Full-text exclusion reason(s): No women with symptomatic chest pain, or results are not reported separately for symptomatic subgroup; Study does not compare one NIT to another or to diagnostic cardiac catheterization; Data for women not reported as a subgroup. [pmid: 16025874].
Sumanen M, Mattila K. A negative finding in an exercise test is reliable among elderly people: a follow-up study. Gerontology. 2007;53(3):159-64. Full-text exclusion reason(s): Study does not compare one NIT to another or to diagnostic cardiac catheterization; Data for women not reported as a subgroup. [pmid: 17192713].
Sun Z, Cao Y. Multislice CT angiography assessment of left coronary artery: Correlation between bifurcation angle and dimensions and development of coronary artery disease. Euro J Radiol. 2011;79(2):e90-e95. Full-text exclusion reason(s): Study does not compare one NIT to another or to diagnostic cardiac catheterization; No outcomes of interest.
Sun Z, Dimpudus FJ, Nugroho J, et al. CT virtual intravascular endoscopy assessment of coronary artery plaques: a preliminary study. Eur J Radiol. 2010;75(1):e112-9. Full-text exclusion reason(s): Study does not compare one NIT to another or to diagnostic cardiac catheterization; Data for women not reported as a subgroup. [pmid: 19781885].
Sun Z, Lin C, Davidson R, et al. Diagnostic value of 64-slice CT angiography in coronary artery disease: a systematic review. Eur J Radiol. 2008;67(1):78-84. Full-text exclusion reason(s): Not original peer-reviewed data or a secondary analysis of RCT, prospective or retrospective observational study, or registry. [pmid: 17766073].
Sundram F, Notghi A, Smith NB. Pharmacological stress myocardial perfusion scintigraphy: use of a modified adenosine protocol in patients with asthma. Nucl Med Commun. 2009;30(3):217-25. Full-text exclusion reason(s): Study does not compare one NIT to another or to diagnostic cardiac catheterization; Data for women not reported as a subgroup. [pmid: 19262284].
Sunman H, Yorgun H, Canpolat U, et al. Association between family history of premature coronary artery disease and coronary atherosclerotic plaques shown by multidetector computed tomography coronary angiography. Int J Cardiol. 2011. Full-text exclusion reason(s): Study does not compare one NIT to another or to diagnostic cardiac catheterization; Data for women not reported as a subgroup.
Suratkal V, Shirke M, Lele RD. Treadmill ECG test combined with myocardial perfusion imaging for evaluation of coronary artery disease: analysis of 340 cases. J Assoc Physicians India. 2003;51:561-4. Full-text exclusion reason(s): No women with symptomatic chest pain, or results are not reported separately for symptomatic subgroup; All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 15266921].
Suzuki Y, Slomka PJ, Wolak A, et al. Motion-frozen myocardial perfusion SPECT improves detection of coronary artery disease in obese patients. J Nucl Med. 2008;49(7):1075-9. Full-text exclusion reason(s): No women with symptomatic chest pain, or results are not reported separately for symptomatic subgroup; Data for women not reported as a subgroup. [pmid: 18552133].
Svane B, Bone D, Holmgren A. Coronary angiography and thallium-201 single photon emission computed tomography in single vessel coronary artery disease. Acta Radiol. 1990;31(3):237-44. Full-text exclusion reason(s): All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 2386638].
Swailam S, Abdel-Salam Z, Emil S, et al. Multi-slice computed tomography: Can it adequately rule out left main coronary disease in patients with an intermediate probability of coronary artery disease?. Cardiol J. 2010;17(6):594-8. Full-text exclusion reason(s): No women with symptomatic chest pain, or results are not reported separately for symptomatic subgroup; Data for women not reported as a subgroup. [pmid: 21154262].
Sylven C, Hagerman I, Ylen M, et al. Variance ECG detection of coronary artery disease—a comparison with exercise stress test and myocardial scintigraphy. Clin Cardiol. 1994;17(3):132-40. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 8168281].
Taggu W, Cooper AF, Patel NR, et al. Clinical Symptoms and Non-Invasive Testing Fail to Predict the Presence of Significant Coronary Artery Disease in Men and Women Undergoing Coronary Angiography. 12th World Congress on Heart Disease - New Trends in Research, Diagnosis and Treatment. Hyatt Regency Vancouver, Vancouver (Canada). 16–19 Jul 2005. 2005.
Takagi T, Takagi A, Yoshikawa J. Detection of coronary artery disease using delayed strain imaging at 5 min after the termination of exercise stress: head to head comparison with conventional treadmill stress echocardiography. J Cardiol. 2010;55(1):41-8. Full-text exclusion reason(s): All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 20122547].
Takase B, Nagata M, Kihara T, et al. Whole-heart dipyridamole stress first-pass myocardial perfusion MRI for the detection of coronary artery disease. Jpn Heart J. 2004;45(3):475-86. Full-text exclusion reason(s): All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 15240967].
Takeishi Y, Chiba J, Abe S, et al. Noninvasive identification of left main and three-vessel coronary artery disease by thallium-201 single photon emission computed tomography during adenosine infusion. Ann Nucl Med. 1994;8(1):1-7. Full-text exclusion reason(s): All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 8204392].
Takeuchi M, Araki M, Nakashima Y, et al. Comparison of dobutamine stress echocardiography and stress thallium-201 single-photon emission computed tomography for detecting coronary artery disease. J Am Soc Echocardiogr. 1993;6(6):593-602. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 8311966].
Tamaki N, Yonekura Y, Mukai T, et al. Stress thallium-201 transaxial emission computed tomography: quantitative versus qualitative analysis for evaluation of coronary artery disease. J Am Coll Cardiol. 1984;4(6):1213-21. Full-text exclusion reason(s): Population does not include women ≥ age 18; All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 6334109].
Tamaki N, Yonekura Y, Senda M, et al. Value and limitation of stress thallium-201 single photon emission computed tomography: comparison with nitrogen-13 ammonia positron tomography. J Nucl Med. 1988;29(7):1181-8. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 3260624].
Tamarappoo B, Dey D, Shmilovich H, et al. Increased pericardial fat volume measured from noncontrast CT predicts myocardial ischemia by SPECT. JACC Cardiovasc Imaging. 2010;3(11):1104-12. Full-text exclusion reason(s): Study does not compare one NIT to another or to diagnostic cardiac catheterization; Data for women not reported as a subgroup. [pmid: 21070997].
Tamarappoo BK, Dey D, Nakazato R, et al. Comparison of the extent and severity of myocardial perfusion defects measured by CT coronary angiography and SPECT myocardial perfusion imaging. JACC Cardiovasc Imaging. 2010;3(10):1010-9. Full-text exclusion reason(s): No women with symptomatic chest pain, or results are not reported separately for symptomatic subgroup; All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 20947046].
Tardif JC, Dore A, Chan KL, et al. Economic impact of contrast stress echocardiography on the diagnosis and initial treatment of patients with suspected coronary artery disease. J Am Soc Echocardiogr. 2002;15(11):1335-45. Full-text exclusion reason(s): All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 12415226].
Tartagni F, Dondi M, Limonetti P, et al. Dipyridamole technetium-99m-2-methoxy isobutyl isonitrile tomoscintigraphic imaging for identifying diseased coronary vessels: comparison with thallium-201 stress-rest study. J Nucl Med. 1991;32(3):369-76. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 2005443].
Tashiro K, Tomiguchi S, Shiraishi S, et al. Clinical usefulness of a collimator distance dependent resolution recovery in myocardial perfusion SPECT: a clinical report from a single institute. Ann Nucl Med. 2011;25(2):133-7. Full-text exclusion reason(s): No women with symptomatic chest pain, or results are not reported separately for symptomatic subgroup; Data for women not reported as a subgroup; No outcomes of interest. [pmid: 21104346].
Tawa CB, Baker WB, Kleiman NS, et al. Comparison of adenosine echocardiography, with and without isometric handgrip, to exercise echocardiography in the detection of ischemia in patients with coronary artery disease. J Am Soc Echocardiogr. 1996;9(1):33-43. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 8679235].
Tejani FH, Thompson RC, Iskandrian AE, et al. Effect of caffeine on SPECT myocardial perfusion imaging during regadenoson pharmacologic stress: rationale and design of a prospective, randomized, multicenter study. J Nucl Cardiol. 2011;18(1):73-81. Full-text exclusion reason(s): All women in the study are known to have CAD; Study does not compare one NIT to another or to diagnostic cardiac catheterization; Data for women not reported as a subgroup; No outcomes of interest. [pmid: 21082298].
Tepe SM. Imaging of the heart and coronary arteries. Cardiovasc Intervent Radiol. 2003;26(SUPPL 1). Full-text exclusion reason(s): Conference abstract or trial registry posting.
Teresinska A, Wnuk J, Konieczna S, et al. Verification of the left ventricular ejection fraction from gated myocardial perfusion studies (GSPECT). Kardiol Pol. 2005;63(5):465-75. discussion 476–7. Full-text exclusion reason(s): Data for women not reported as a subgroup; No outcomes of interest. [pmid: 16362849].
Thanigaraj S, Nease RF Jr, Schechtman KB, et al. Use of contrast for image enhancement during stress echocardiography is cost-effective and reduces additional diagnostic testing. Am J Cardiol. 2001;87(12):1430-2. Full-text exclusion reason(s): All women in the study are known to have CAD; Study does not compare one NIT to another or to diagnostic cardiac catheterization; Data for women not reported as a subgroup. [pmid: 11397374].
Therre T, Ribal JP, Motreff P, et al. Assessment of cardiac risk before aortic reconstruction: noninvasive work-up using clinical examination, exercise testing, and dobutamine stress echocardiography versus routine coronary arteriography. Ann Vasc Surg. 1999;13(5):501-8. Full-text exclusion reason(s): Data for women not reported as a subgroup; No outcomes of interest. [pmid: 10466994].
Thiele H, Plein S, Breeuwer M, et al. Color-encoded semiautomatic analysis of multi-slice first-pass magnetic resonance perfusion: comparison to tetrofosmin single photon emission computed tomography perfusion and X-ray angiography. Int J Cardiovasc Imaging. 2004;20(5):371-84. discussion 385–7. Full-text exclusion reason(s): All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 15765860].
Thilo C, Schoepf UJ, Gordon L, et al. Integrated assessment of coronary anatomy and myocardial perfusion using a retractable SPECT camera combined with 64-slice CT: Initial experience. Euro Radiol. 2009;19(4):845-856. Full-text exclusion reason(s): All women in the study are known to have CAD; Data for women not reported as a subgroup.
Thomas C, Brodoefel H, Tsiflikas I, et al. Does clinical pretest probability influence image quality and diagnostic accuracy in dual-source coronary CT angiography?. Acad Radiol. 2010;17(2):212-8. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 19910219].
Thomas D, Meyer C, Strach K, et al. Dobutamine stress tagging and gradient-echo imaging for detection of coronary heart disease at 3 T. Br J Radiol. 2011;84(997):44-50. Full-text exclusion reason(s): All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 20959376].
Thomas D, Strach K, Meyer C, et al. Combined myocardial stress perfusion imaging and myocardial stress tagging for detection of coronary artery disease at 3 Tesla. J Cardiovasc Magn Reson. 2008;10:59. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 19094196].
Thomas GS, Miyamoto MI, Morello AP 3rd, et al. Technetium 99m sestamibi myocardial perfusion imaging predicts clinical outcome in the community outpatient setting. The Nuclear Utility in the Community (NUC) Study. J Am Coll Cardiol. 2004;43(2):213-23. Full-text exclusion reason(s): All women in the study are known to have CAD; Study does not compare one NIT to another or to diagnostic cardiac catheterization; Data for women not reported as a subgroup. [pmid: 14736440].
Thomas GS, Prill NV, Majmundar H, et al. Treadmill exercise during adenosine infusion is safe, results in fewer adverse reactions, and improves myocardial perfusion image quality. J Nucl Cardiol. 2000;7(5):439-46. Full-text exclusion reason(s): Study does not compare one NIT to another or to diagnostic cardiac catheterization. [pmid: 11083192].
Thompson RC, Heller GV, Johnson LL, et al. Value of attenuation correction on ECG-gated SPECT myocardial perfusion imaging related to body mass index. J Nucl Cardiol. 2005;12(2):195-202. Full-text exclusion reason(s): No women with symptomatic chest pain, or results are not reported separately for symptomatic subgroup; Data for women not reported as a subgroup. [pmid: 15812374].
Thomson HL, Basmadjian AJ, Rainbird AJ, et al. Contrast echocardiography improves the accuracy and reproducibility of left ventricular remodeling measurements: a prospective, randomly assigned, blinded study. J Am Coll Cardiol. 2001;38(3):867-75. Full-text exclusion reason(s): No women with symptomatic chest pain, or results are not reported separately for symptomatic subgroup; Data for women not reported as a subgroup; No outcomes of interest. [pmid: 11527647].
Tian J, Zhang G, Wang X, et al. Exercise echocardiography: feasibility and value for detection of coronary artery disease. Chin Med J (Engl). 1996;109(5):381-4. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 9208496].
Toledo E, Jacobs LD, Lodato JA, et al. Quantitative diagnosis of stress-induced myocardial ischemia using analysis of contrast echocardiographic parametric perfusion images. Eur J Echocardiogr. 2006;7(3):217-25. Full-text exclusion reason(s): No women with symptomatic chest pain, or results are not reported separately for symptomatic subgroup; Data for women not reported as a subgroup. [pmid: 16157510].
Tolstrup K, Madsen BE, Ruiz JA, et al. Non-invasive resting magnetocardiographic imaging for the rapid detection of ischemia in subjects presenting with chest pain. Cardiology. 2006;106(4):270-6. Full-text exclusion reason(s): All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 16733351].
Tomaszuk-Kazberuk A, Sobkowicz B, Malyszko J, et al. Perfusion defects on real-time myocardial contrast echocardiography predict higher mortality in patients with end-stage renal disease - a 3-year follow-up. Ren Fail. 2010;32(10):1160-6. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 20954975].
Toriyama T, Takase H, Goto T, et al. Coronary artery disease investigated using 99mTc-tetrofosmin myocardial SPECT. European journal of clinical investigation. 2007:478-82. [pmid: 17537155].
Toumanidis ST, Pantelia MI, Trika CO, et al. Detection of coronary artery disease in the presence of left ventricular atrophy. Int J Cardiol. 1996;57(3):245-55. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 9024913].
Trabold T, Buchgeister M, Kuttner A, et al. Estimation of radiation exposure in 16-detector row computed tomography of the heart with retrospective ECG-gating. Rofo. 2003;175(8):1051-5. Full-text exclusion reason(s): No women with symptomatic chest pain, or results are not reported separately for symptomatic subgroup; All women in the study are known to have CAD; Study does not compare one NIT to another or to diagnostic cardiac catheterization; Data for women not reported as a subgroup. [pmid: 12886472].
Travin MI, Dessouki A, Cameron T, et al. Use of exercise technetium-99m sestamibi SPECT imaging to detect residual ischemia and for risk stratification after acute myocardial infarction. Am J Cardiol. 1995;75(10):665-9. Full-text exclusion reason(s): All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 7900657].
Travin MI, Laraia PJ. The prognostic value of stress radionuclide myocardial perfusion imaging. Prim Cardiol. 1994;(20):44-52. Full-text exclusion reason(s): Not original peer-reviewed data or a secondary analysis of RCT, prospective or retrospective observational study, or registry.
Treuth MG, Reyes GA, He ZX, et al. Tolerance and diagnostic accuracy of an abbreviated adenosine infusion for myocardial scintigraphy: a randomized, prospective study. J Nucl Cardiol. 2001;8(5):548-54. Full-text exclusion reason(s): No women with symptomatic chest pain, or results are not reported separately for symptomatic subgroup; All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 11593218].
Tsai IC, Lee T, Lee WL, et al. Use of 40-detector row computed tomography before catheter coronary angiography to select early conservative versus early invasive treatment for patients with low-risk acute coronary syndrome. J Comput Assist Tomogr. 2007;31(2):258-64. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 17414764].
Tsai MF, Kao PF, Tzen KY. Improved diagnostic performance of thallium-201 myocardial perfusion scintigraphy in coronary artery disease: from planar to single photon emission computed tomography imaging. Chang Gung Med J. 2002;25(8):522-30. Full-text exclusion reason(s): No women with symptomatic chest pain, or results are not reported separately for symptomatic subgroup; All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 12392364].
Tsiflikas I, Brodoefel H, Reimann AJ, et al. Coronary CT angiography with dual source computed tomography in 170 patients. Eur J Radiol. 2010;74(1):161-5. Full-text exclusion reason(s): All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 19261419].
Tsiflikas I, Drosch T, Brodoefel H, et al. Diagnostic accuracy and image quality of cardiac dual-source computed tomography in patients with arrhythmia. Int J Cardiol. 2010;143(1):79-85. Full-text exclusion reason(s): All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 19246109].
Tsougos E, Panou F, Paraskevaidis I, et al. Exercise-induced changes in E/E′ ratio in patients with suspected coronary artery disease. Coron Artery Dis. 2008;19(6):405-11. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 18955834].
Tsutsui JM, Elhendy A, Anderson JR, et al. Prognostic value of dobutamine stress myocardial contrast perfusion echocardiography. Circulation. 2005;112(10):1444-50. Full-text exclusion reason(s): All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 16129798].
Tsutsui JM, Elhendy A, Xie F, et al. Safety of dobutamine stress real-time myocardial contrast echocardiography. J Am Coll Cardiol. 2005;45(8):1235-42. Full-text exclusion reason(s): All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 15837255].
Tsutsui JM, Osorio AF, Lario FA, et al. Comparison of safety and efficacy of the early injection of atropine during dobutamine stress echocardiography with the conventional protocol. Am J Cardiol. 2004;94(11):1367-72. Full-text exclusion reason(s): All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 15566905].
Tsutsui JM, Xie F, Cloutier D, et al. Real-time dobutamine stress myocardial perfusion echocardiography predicts outcome in the elderly. Eur Heart J. 2008;29(3):377-85. Full-text exclusion reason(s): All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 17989076].
Tsutsui JM, Xie F, McGrain AC, et al. Comparison of low-mechanical index pulse sequence schemes for detecting myocardial perfusion abnormalities during vasodilator stress echocardiography. Am J Cardiol. 2005;95(5):565-70. Full-text exclusion reason(s): All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 15721092].
Tsutsui JM, Xie F, O’Leary EL, et al. Diagnostic accuracy and prognostic value of dobutamine stress myocardial contrast echocardiography in patients with suspected acute coronary syndromes. Echocardiography. 2005;22(6):487-95. Full-text exclusion reason(s): All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 15966933].
Turgut B, Unlu M, Temiz NH, et al. Dobutamine Tc-99m furifosmin SPECT in detection of coronary artery disease: evaluation of same day, rest-stress protocol. Ann Nucl Med. 2003;17(7):531-9. Full-text exclusion reason(s): All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 14651351].
Turkvatan A, Biyikoglu SF, Buyukbayraktar F, et al. Clinical value of 16-slice multidetector computed tomography in symptomatic patients with suspected coronary artery disease. Acta Radiol. 2008;49(4):400-8. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 18415783].
Turner AS, Nathan MC, Watson OF, et al. The correlation of the computer quantitated treadmill exercise electrocardiogram with cinearteriographic assessment of coronary artery disease. N Z Med J. 1979;89(630):115-8. Full-text exclusion reason(s): Population does not include women ≥ age 18; All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 286892].
Turner DA, Battle WE, Deshmukh H, et al. The predictive value of myocardial perfusion scintigraphy after stress in patients without previous myocardial infarction. J Nucl Med. 1978;19(3):249-55. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 632901].
Ueno K, Anzai T, Jinzaki M, et al. Increased epicardial fat volume quantified by 64-multidetector computed tomography is associated with coronary atherosclerosis and totally occlusive lesions. Circ J. 2009;73(10):1927-33. Full-text exclusion reason(s): All women in the study are known to have CAD; Data for women not reported as a subgroup; No outcomes of interest. [pmid: 19690390].
Ueno K, Anzai T, Jinzaki M, et al. Diagnostic capacity of 64-slice multidetector computed tomography for acute coronary syndrome in patients presenting with acute chest pain. Cardiology. 2009;112(3):211-8. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 18682665].
Ugolini P, Pressacco J, Lesperance J, et al. Evaluation of coronary atheroma by 64-slice multidetector computed tomography: Comparison with intravascular ultrasound and angiography. Can J Cardiol. 2009;25(11):641-7. Full-text exclusion reason(s): No women with symptomatic chest pain, or results are not reported separately for symptomatic subgroup; All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 19898696].
Ulimoen GR, Gjonnaess E, Atar D, et al. Noninvasive coronary angiography with 64-channel multidetector computed tomography in patients with acute coronary syndrome. Acta Radiol. 2008;49(10):1140-4. Full-text exclusion reason(s): All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 18932101].
Underwood DA, Rincon G, Yiannikas J, et al. Clinical usefulness of thallium-201 scintigraphy in the study of coronary artery disease: a comparison of two exercise systems. Cleve Clin Q. 1982;49(2):73-8. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 7116630].
Underwood SR, Anagnostopoulos C, Cerqueira M, et al. Myocardial perfusion scintigraphy: the evidence. Eur J Nucl Med Mol Imaging. 2004;31(2):261-91. Full-text exclusion reason(s): Not original peer-reviewed data or a secondary analysis of RCT, prospective or retrospective observational study, or registry. [pmid: 15129710].
Underwood SR, Godman B, Salyani S, et al. Economics of myocardial perfusion imaging in Europe—the EMPIRE Study. Eur Heart J. 1999;20(2):157-66. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 10099913].
Uthamalingam S, Zheng H, Leavitt M, et al. Exercise-induced ST-segment elevation in ECG lead aVR is a useful indicator of significant left main or ostial LAD coronary artery stenosis. JACC Cardiovasc Imaging. 2011;4(2):176-86. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 21329903].
Vacanti LJ, Sposito AC, Sespedes L, et al. In comparison to the myocardial perfusion scintigraphy, a treadmill stress test is a viable, efficient and cost effective option to predict cardiovascular events in elderly patients. Arq Bras Cardiol. 2007;88(5):531-6. Full-text exclusion reason(s): No women with symptomatic chest pain, or results are not reported separately for symptomatic subgroup; All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 17589627].
Valdiviezo C, Motivala AA, Hachamovitch R, et al. The significance of transient ischemic dilation in the setting of otherwise normal SPECT radionuclide myocardial perfusion images. J Nucl Cardiol. 2011;18(2):220-9. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 21327596].
Valeti US, Miller TD, Hodge DO, et al. Exercise single-photon emission computed tomography provides effective risk stratification of elderly men and elderly women. Circulation. 2005;111(14):1771-6. Full-text exclusion reason(s): All women in the study are known to have CAD; Study does not compare one NIT to another or to diagnostic cardiac catheterization. [pmid: 15809375].
van der Bijl N, Joemai RM, Geleijns J, et al. Assessment of Agatston coronary artery calcium score using contrast-enhanced CT coronary angiography. AJR Am J Roentgenol. 2010;195(6):1299-305. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 21098187].
van Dijkman PR, Kuijpers DA, Blom BM, et al. Dobutamine stress magnetic resonance imaging: a valuable method in the noninvasive diagnosis of ischemic heart disease. J Electrocardiol. Suppl. 2002;35:57-9. Full-text exclusion reason(s): All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 12539099].
van Geuns RJ, Oudkerk M, Rensing BJ, et al. Comparison of coronary imaging between magnetic resonance imaging and electron beam computed tomography. Am J Cardiol. 2002;90(1):58-63. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 12088783].
van Geuns RJ, Wielopolski PA, de Bruin HG, et al. MR coronary angiography with breath-hold targeted volumes: preliminary clinical results. Radiology. 2000;217(1):270-7. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 11012456].
Van Lingen R, Kakani N, Veitch A, et al. Prognostic and accuracy data of multidetector CT coronary angiography in an established clinical service. Clin Radiol. 2009;64(6):601-7. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 19414082].
Van Train KF, Areeda J, Garcia EV, et al. Quantitative same-day rest-stress technetium-99m-sestamibi SPECT: definition and validation of stress normal limits and criteria for abnormality. J Nucl Med. 1993;34(9):1494-502. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 8355069].
Van Train KF, Maddahi J, Berman DS, et al. Quantitative analysis of tomographic stress thallium-201 myocardial scintigrams: a multicenter trial. J Nucl Med. 1990;31(7):1168-79. Full-text exclusion reason(s): No women with symptomatic chest pain, or results are not reported separately for symptomatic subgroup; Data for women not reported as a subgroup. [pmid: 2194003].
Van Velzen JE, Schuijf JD, De Graaf FR, et al. Diagnostic performance of non-invasive multidetector computed tomography coronary angiography to detect coronary artery disease using different endpoints: Detection of significant stenosis vs. detection of atherosclerosis. Euro Heart J. 2011;32(5):637-645. Full-text exclusion reason(s): Data for women not reported as a subgroup; No outcomes of interest.
Van Werkhoven JM, Cademartiri F, Seitun S, et al. Diabetes: prognostic value of CT coronary angiography—comparison with a nondiabetic population. Radiology. 2010;256(1):83-92. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 20574086].
van Werkhoven JM, de Boer SM, Schuijf JD, et al. Impact of clinical presentation and pretest likelihood on the relation between calcium score and computed tomographic coronary angiography. Am J Cardiol. 2010;106(12):1675-9. Full-text exclusion reason(s): Study does not compare one NIT to another or to diagnostic cardiac catheterization; Data for women not reported as a subgroup. [pmid: 21055714].
van Werkhoven JM, Gaemperli O, Schuijf JD, et al. Multislice computed tomography coronary angiography for risk stratification in patients with an intermediate pretest likelihood. Heart. 2009;95(19):1607-11. Full-text exclusion reason(s): Study does not compare one NIT to another or to diagnostic cardiac catheterization; Data for women not reported as a subgroup. [pmid: 19581272].
van Werkhoven JM, Heijenbrok MW, Schuijf JD, et al. Diagnostic accuracy of 64-slice multislice computed tomographic coronary angiography in patients with an intermediate pretest likelihood for coronary artery disease. Am J Cardiol. 2010;105(3):302-5. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 20102939].
van Werkhoven JM, Heijenbrok MW, Schuijf JD, et al. Combined non-invasive anatomical and functional assessment with MSCT and MRI for the detection of significant coronary artery disease in patients with an intermediate pre-test likelihood. Heart. 2010;96(6):425-31. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 19858134].
van Werkhoven JM, Schuijf JD, Gaemperli O, et al. Prognostic value of multislice computed tomography and gated single-photon emission computed tomography in patients with suspected coronary artery disease. J Am Coll Cardiol. 2009;53(7):623-32. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 19215839].
van Werkhoven JM, Schuijf JD, Gaemperli O, et al. Incremental prognostic value of multi-slice computed tomography coronary angiography over coronary artery calcium scoring in patients with suspected coronary artery disease. Eur Heart J. 2009;30(21):2622-9. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 19567382].
van Werkhoven JM, Schuijf JD, Jukema JW, et al. Anatomic correlates of a normal perfusion scan using 64-slice computed tomographic coronary angiography. Am J Cardiol. 2008;101(1):40-5. Full-text exclusion reason(s): All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 18157963].
Vanhoenacker PK, Decramer I, Bladt O, et al. Detection of non-ST-elevation myocardial infarction and unstable angina in the acute setting: meta-analysis of diagnostic performance of multi-detector computed tomographic angiography. BMC Cardiovasc Disord. 2007;7:39. Full-text exclusion reason(s): All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 18093295].
Vanhoenacker PK, Heijenbrok-Kal MH, Van Heste R, et al. Diagnostic performance of multidetector CT angiography for assessment of coronary artery disease: meta-analysis. Radiology. 2007;244(2):419-28. Full-text exclusion reason(s): Not original peer-reviewed data or a secondary analysis of RCT, prospective or retrospective observational study, or registry. [pmid: 17641365].
Vanzetto G, Ormezzano O, Fagret D, et al. Long-term additive prognostic value of thallium-201 myocardial perfusion imaging over clinical and exercise stress test in low to intermediate risk patients: study in 1137 patients with 6-year follow-up. Circulation. 1999;100(14):1521-7. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 10510055].
Vavere AL, Arbab-Zadeh A, Rochitte CE, et al. Coronary artery stenoses: accuracy of 64-detector row CT angiography in segments with mild, moderate, or severe calcification—A dubanalysis of the CORE-64 trial. Radiology. 2011. Full-text exclusion reason(s): Data for women not reported as a subgroup.
Vegsundvag J, Holte E, Wiseth R, et al. Coronary flow velocity reserve in the three main coronary arteries assessed with transthoracic doppler: A comparative study with quantitative coronary angiography. Journal of the American Society of Echocardiography. 2011;24(7):758-767. Full-text exclusion reason(s): No data for NITs of interest (ECG, ECHO, SPECT, PET, CMR, CTA); Data for women not reported as a subgroup. [pmid: 21524564].
Vegsundvag J, Holte E, Wiseth R, et al. Transthoracic echocardiography for imaging of the different coronary artery segments: a feasibility study. Cardiovasc Ultrasound. 2009;7:58. Full-text exclusion reason(s): No women with symptomatic chest pain, or results are not reported separately for symptomatic subgroup; All women in the study are known to have CAD; Data for women not reported as a subgroup; No outcomes of interest. [pmid: 20028530].
Venkatesh V, Ellins ML, Yang S, et al. Incremental detection of coronary artery disease by assessment of non-calcified plaque on coronary CT angiography. Clin Radiol. 2009;64(3):250-5. Full-text exclusion reason(s): No women with symptomatic chest pain, or results are not reported separately for symptomatic subgroup; Data for women not reported as a subgroup. [pmid: 19185654].
Verani MS, Mahmarian JJ, Hixson JB, et al. Diagnosis of coronary artery disease by controlled coronary vasodilation with adenosine and thallium-201 scintigraphy in patients unable to exercise. Circulation. 1990;82(1):80-7. Full-text exclusion reason(s): All women in the study are known to have CAD; Data for women not reported as a subgroup; No outcomes of interest. [pmid: 2364527].
Verani MS, Marcus ML, Razzak MA, et al. Sensitivity and specificity of thallium-201 perfusion scintigrams under exercise in the diagnosis of coronary artery disease. J Nucl Med. 1978;19(7):773-82. Full-text exclusion reason(s): All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 660279].
Verna E, Ceriani L, Giovanella L, et al. “False-positive” myocardial perfusion scintigraphy findings in patients with angiographically normal coronary arteries: insights from intravascular sonography studies. J Nucl Med. 2000;41(12):1935-40. Full-text exclusion reason(s): No women with symptomatic chest pain, or results are not reported separately for symptomatic subgroup; All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 11138675].
Vigna C, Stanislao M, De Rito V, et al. Dipyridamole stress echocardiography vs dipyridamole sestamibi scintigraphy for diagnosing coronary artery disease in left bundle-branch block. Chest. 2001;120(5):1534-9. Full-text exclusion reason(s): No women with symptomatic chest pain, or results are not reported separately for symptomatic subgroup; Data for women not reported as a subgroup. [pmid: 11713131].
Visser CA, van der Wieken RL, Kan G, et al. Comparison of two-dimensional echocardiography with radionuclide angiography during dynamic exercise for the detection of coronary artery disease. Am Heart J. 1983;106(3):528-34. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 6881027].
Vitarelli A, Conde Y, Luzzi MF, et al. Transesophageal dobutamine stress echocardiography with tissue Doppler imaging for detection and assessment of coronary artery disease. J Investig Med. 2001;49(6):534-43. Full-text exclusion reason(s): All women in the study are known to have CAD; Data for women not reported as a subgroup.
Vitarelli A, Luzzi MF, Penco M, et al. On-line quantitative assessment of left ventricular filling during dobutamine stress echocardiography: a useful addition to conventional wall motion scoring. Int J Cardiol. 1997;59(1):57-69. Full-text exclusion reason(s): All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 9080026].
Vivekananthan DP, Blackstone EH, Pothier CE, et al. Heart rate recovery after exercise is a predictor of mortality, independent of the angiographic severity of coronary disease. J Am Coll Cardiol. 2003;42(5):831-8. Full-text exclusion reason(s): No women with symptomatic chest pain, or results are not reported separately for symptomatic subgroup; All women in the study are known to have CAD; Data for women not reported as a subgroup; No outcomes of interest. [pmid: 12957428].
Vogel R, Indermuhle A, Meier P, et al. Quantitative stress echocardiography in coronary artery disease using contrast-based myocardial blood flow measurements: prospective comparison with coronary angiography. Heart. 2009;95(5):377-84. Full-text exclusion reason(s): No women with symptomatic chest pain, or results are not reported separately for symptomatic subgroup; Data for women not reported as a subgroup. [pmid: 18697806].
Vogel-Claussen J, Skrok J, Dombroski D, et al. Comprehensive adenosine stress perfusion MRI defines the etiology of chest pain in the emergency room: Comparison with nuclear stress test. J Magn Reson Imaging. 2009;30(4):753-62. Full-text exclusion reason(s): No outcomes of interest. [pmid: 19787721].
Voros S, Rinehart S, Qian Z, et al. Prospective validation of standardized, 3-dimensional, quantitative coronary computed tomographic plaque measurements using radiofrequency backscatter intravascular ultrasound as reference standard in intermediate coronary arterial lesions: results from the ATLANTA (assessment of tissue characteristics, lesion morphology, and hemodynamics by angiography with fractional flow reserve, intravascular ultrasound and virtual histology, and noninvasive computed tomography in atherosclerotic plaques) I study. JACC Cardiovasc Interv. 2011;4(2):198-208. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 21349459].
Vural M, Ucar O, Selvi NA, et al. Assessment of global left ventricular systolic function with multidetector. Diagn Interv Radiol. 2010;16(3):236-240. Full-text exclusion reason(s): Data for women not reported as a subgroup; No outcomes of interest. [pmid: 20635319].
Wagdi P, Alkadhi H. The impact of cardiac CT on the appropriate utilization of catheter coronary angiography. Int J Cardiovasc Imaging. 2010;26(3):333-44. Full-text exclusion reason(s): No women with symptomatic chest pain, or results are not reported separately for symptomatic subgroup; Data for women not reported as a subgroup; No outcomes of interest. [pmid: 19936961].
Wagdi P, Kaufmann U, Fluri M, et al. High dose dipyridamole as a pharmacological stress test during cardiac catheterisation in patients with coronary artery disease. Heart. 1996;75(3):247-51. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 8800986].
Wagner M, Rosler R, Lembcke A, et al. Whole-heart coronary magnetic resonance angiography at 1.5 Tesla: does a blood-pool contrast agent improve diagnostic accuracy?. Invest Radiol. 2011;46(3):152-9. Full-text exclusion reason(s): Study does not compare one NIT to another or to diagnostic cardiac catheterization; Data for women not reported as a subgroup. [pmid: 21150789].
Wagner S, Schuster S, Zahn R, et al. Postinfarction stress testing and one year outcome of stable patients after myocardial infarction treated with thrombolytics. Eur J Med Res. 1996;1(12):575-81. Full-text exclusion reason(s): All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 9438166].
Wahl A, Paetsch I, Gollesch A, et al. Safety and feasibility of high-dose dobutamine-atropine stress cardiovascular magnetic resonance for diagnosis of myocardial ischaemia: experience in 1000 consecutive cases. Eur Heart J. 2004;25(14):1230-6. Full-text exclusion reason(s): No women with symptomatic chest pain, or results are not reported separately for symptomatic subgroup; All women in the study are known to have CAD; Study does not compare one NIT to another or to diagnostic cardiac catheterization; Data for women not reported as a subgroup. [pmid: 15246641].
Wainwrwight RJ, Maisey MN, Sowton E. Segmental quantitative analysis of digital thallium-201 myocardial scintigrams in diagnosis of coronary artery disease. Comparison with rest and exercise electrocardiography and coronary arteriography. Br Heart J. 1981;46(5):478-85. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 7317214].
Wakasugi S, Shibata N, Kobayashi T, et al. Specific perfusion pattern in stress 201Tl myocardial scintigraphy of left main coronary artery disease. Eur J Nucl Med. 1986;12(8):369-74. Full-text exclusion reason(s): No women with symptomatic chest pain, or results are not reported separately for symptomatic subgroup; All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 3792371].
Walimbe V, Jaber WA, Garcia MJ, et al. Multimodality cardiac stress testing: combining real-time 3-dimensional echocardiography and myocardial perfusion SPECT. J Nucl Med. 2009;50(2):226-30. Full-text exclusion reason(s): No women with symptomatic chest pain, or results are not reported separately for symptomatic subgroup; All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 19164233].
Wallace EL, Morgan TM, Walsh TF, et al. Dobutamine cardiac magnetic resonance results predict cardiac prognosis in women with known or suspected ischemic heart disease. JACC Cardiovasc Imaging. 2009;2(3):299-307. Full-text exclusion reason(s): No women with symptomatic chest pain, or results are not reported separately for symptomatic subgroup; Study does not compare one NIT to another or to diagnostic cardiac catheterization. [pmid: 19356575].
Wallhaus TR, Lacy J, Stewart R, et al. Copper-62-pyruvaldehyde bis(N-methyl-thiosemicarbazone) PET imaging in the detection of coronary artery disease in humans. J Nucl Cardiol. 2001;8(1):67-74. Full-text exclusion reason(s): No women with symptomatic chest pain, or results are not reported separately for symptomatic subgroup; All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 11182711].
Walsh TF, Dall’Armellina E, Chughtai H, et al. Adverse effect of increased left ventricular wall thickness on five year outcomes of patients with negative dobutamine stress. J Cardiovasc Magn Reson. 2009;11:25. Full-text exclusion reason(s): No women with symptomatic chest pain, or results are not reported separately for symptomatic subgroup; All women in the study are known to have CAD; Study does not compare one NIT to another or to diagnostic cardiac catheterization; Data for women not reported as a subgroup. [pmid: 19650895].
Wang Q, Qin J, Gai LY, et al. A pilot study on diagnosis of coronary artery disease using computed tomography first-pass myocardial perfusion imaging at rest. Journal of Zhejiang University: Science B. 2011;12(6):485-491. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 21634042].
Warner MF, Pippin JJ, DiSciascio G, et al. Assessment of thallium scintigraphy and echocardiography during dobutamine infusion for the detection of coronary artery disease. Cathet Cardiovasc Diagn. 1993;29(2):122-7. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 8348596].
Watanabe H, Hozumi T, Hirata K, et al. Noninvasive coronary flow velocity reserve measurement in the posterior descending coronary artery for detecting coronary stenosis in the right coronary artery using contrast-enhanced transthoracic Doppler echocardiography. Echocardiography. 2004;21(3):225-33. Full-text exclusion reason(s): Study does not compare one NIT to another or to diagnostic cardiac catheterization; Data for women not reported as a subgroup. [pmid: 15053784].
Watanabe K, Sekiya M, Ikeda S, et al. Comparison of adenosine triphosphate and dipyridamole in diagnosis by thallium-201 myocardial scintigraphy. J Nucl Med. 1997;38(4):577-81. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 9098205].
Watkins MW, Hesse B, Green CE, et al. Detection of coronary artery stenosis using 40-channel computed tomography with multi-segment reconstruction. Am J Cardiol. 2007;99(2):175-81. Full-text exclusion reason(s): All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 17223414].
Watkins S, McGeoch R, Lyne J, et al. Validation of magnetic resonance myocardial perfusion imaging with fractional flow reserve for the detection of significant coronary heart disease. Circulation. 2009;120(22):2207-13. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 19917885].
Wehrschuetz M, Wehrschuetz E, Schuchlenz H, et al. Accuracy of MSCT coronary angiography with 64 row CT scanner—Facing the facts. Clinical Medicine Insights: Cardiology. 2010;4:15-22. Full-text exclusion reason(s): All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 20567636].
Wei K, Crouse L, Weiss J, et al. Comparison of usefulness of dipyridamole stress myocardial contrast echocardiography to technetium-99m sestamibi single-photon emission computed tomography for detection of coronary artery disease (PB127 Multicenter Phase 2 Trial results). Am J Cardiol. 2003;91(11):1293-8. Full-text exclusion reason(s): All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 12767419].
Wei L, Kadoya M, Momose M, et al. Serial assessment of left ventricular function in various patient groups with Tl-201 gated myocardial perfusion SPECT. Radiat Med. 2007;25(2):65-72. Full-text exclusion reason(s): All women in the study are known to have CAD; Study does not compare one NIT to another or to diagnostic cardiac catheterization; Data for women not reported as a subgroup. [pmid: 17541515].
Weigold WG, Abbara S, Achenbach S, et al. Standardized medical terminology for cardiac computed tomography: a report of the Society of Cardiovascular Computed Tomography. J Cardiovasc Comput Tomogr. 2011;5(3):136-44. Full-text exclusion reason(s): Not a clinical study report. [pmid: 21640690].
Weininger M, Schoepf UJ, Ramachandra A, et al. Adenosine-stress dynamic real-time myocardial perfusion CT and adenosine-stress first-pass dual-energy myocardial perfusion CT for the assessment of acute chest pain: Initial results. Eur J Radiol. 2010. Full-text exclusion reason(s): All women in the study are known to have CAD; Study does not compare one NIT to another or to diagnostic cardiac catheterization; Data for women not reported as a subgroup; No outcomes of interest.
Weinsaft JW, Gade CL, Wong FJ, et al. Diagnostic impact of SPECT image display on assessment of obstructive coronary artery disease. J Nucl Cardiol. 2007;14(5):659-68. Full-text exclusion reason(s): All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 17826319].
Weinsaft JW, Manoushagian SJ, Patel T, et al. Stress-induced ST-segment deviation in relation to the presence and severity of coronary artery disease in patients with normal myocardial perfusion imaging. Coron Artery Dis. 2009;20(1):41-9. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 19050598].
Weiss MB, Narasimhadevara SM, Feng GQ, et al. Computer-enhanced frequency-domain and 12-lead electrocardiography accurately detect abnormalities consistent with obstructive and nonobstructive coronary artery disease. Heart Dis. 2002;4(1):2-12. Full-text exclusion reason(s): No data for NITs of interest (ECG, ECHO, SPECT, PET, CMR, CTA). [pmid: 11975826].
Weiss SJ, Ernst AA, Godorov G, et al. Bioimpedance-derived differences in cardiac physiology during exercise stress testing in low-risk chest pain patients. South Med J. 2003;96(11):1121-7. Full-text exclusion reason(s): Data for women not reported as a subgroup; No outcomes of interest. [pmid: 14632361].
Wenger NK. Coronary heart disease in women: highlights of the past 2 years—stepping stones, milestones and obstructing boulders. Nat Clin Pract Cardiovasc Med. 2006;3(4):194-202. Full-text exclusion reason(s): Not original peer-reviewed data or a secondary analysis of RCT, prospective or retrospective observational study, or registry. [pmid: 16568128].
Wenger NK, Shaw LJ, Vaccarino V. Coronary heart disease in women: update 2008. Clin Pharmacol Ther. 2008;83(1):37-51. Full-text exclusion reason(s): Not original peer-reviewed data or a secondary analysis of RCT, prospective or retrospective observational study, or registry. [pmid: 18043680].
Wertman BM, Cheng VY, Kar S, et al. Characterization of complex coronary artery stenosis morphology by coronary computed tomographic angiography. JACC Cardiovasc Imaging. 2009;2(8):950-8. Full-text exclusion reason(s): No women with symptomatic chest pain, or results are not reported separately for symptomatic subgroup; All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 19679283].
Weustink AC, Neefjes LA, Kyrzopoulos S, et al. Impact of heart rate frequency and variability on radiation exposure, image quality, and diagnostic performance in dual-source spiral CT coronary angiography. Radiology. 2009;253(3):672-80. Full-text exclusion reason(s): All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 19864512].
Weustink AC, Neefjes LA, Rossi A, et al. Diagnostic performance of exercise bicycle testing and single-photon emission computed tomography: comparison with 64-slice computed tomography coronary angiography. Int J Cardiovasc Imaging. 2011. Full-text exclusion reason(s): Data for women not reported as a subgroup.
Wexler O, Yoder SR, Elder JL, et al. Effect of gender on cardiovascular risk stratification with ECG gated SPECT left ventricular volume indices and ejection fraction. J Nucl Cardiol. 2009;16(1):28-37. Full-text exclusion reason(s): All women in the study are known to have CAD; Study does not compare one NIT to another or to diagnostic cardiac catheterization. [pmid: 19152126].
White CS, Kuo D, Kelemen M, et al. Chest pain evaluation in the emergency department: can MDCT provide a comprehensive evaluation?. AJR Am J Roentgenol. 2005;185(2):533-40. Full-text exclusion reason(s): Study does not compare one NIT to another or to diagnostic cardiac catheterization; Data for women not reported as a subgroup. [pmid: 16037533].
Wijesekera NT, Padley SPG, Ansede G, et al. Is there a role for 64-multi-detector CT coronary angiography in octogenarians? A single-centre experience. Br J Cardiol. 2010;17(1):40-43. Full-text exclusion reason(s): Data for women not reported as a subgroup.
Williams BR, Mullani NA, Jansen DE, et al. A retrospective study of the diagnostic accuracy of a community hospital-based PET center for the detection of coronary artery disease using rubidium-82. J Nucl Med. 1994;35(10):1586-92. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 7931654].
Williams KA, Schneider CM. Increased stress right ventricular activity on dual isotope perfusion SPECT: a sign of multivessel and/or left main coronary artery disease. J Am Coll Cardiol. 1999;34(2):420-7. Full-text exclusion reason(s): All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 10440154].
Winter R, Gudmundsson P, Willenheimer R. Real-time perfusion adenosine stress echocardiography in the coronary care unit: a feasible bedside tool for predicting coronary artery stenosis in patients with acute coronary syndrome. Eur J Echocardiogr. 2005;6(1):31-40. Full-text exclusion reason(s): All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 15664551].
Wittlinger T, Voigtlander T, Rohr M, et al. Magnetic resonance imaging of coronary artery occlusions in the navigator technique. Int J Cardiovasc Imaging. 2002;18(3):203-11. discussion 213–5. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 12123312].
Wolak A, Gutstein A, Cheng VY, et al. Dual-source coronary computed tomography angiography in patients with atrial fibrillation: initial experience. J Cardiovasc Comput Tomogr. 2008;2(3):172-80. Full-text exclusion reason(s): No women with symptomatic chest pain, or results are not reported separately for symptomatic subgroup; All women in the study are known to have CAD; Study does not compare one NIT to another or to diagnostic cardiac catheterization; Data for women not reported as a subgroup. [pmid: 19083942].
Wolber T, Maeder M, Weilenmann D, et al. Integration of B-type natriuretic peptide levels with clinical data and exercise testing for predicting coronary artery disease. Am J Cardiol. 2006;98(6):764-7. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 16950181].
Wolff SD, Schwitter J, Coulden R, et al. Myocardial first-pass perfusion magnetic resonance imaging: a multicenter dose-ranging study. Circulation. 2004;110(6):732-7. Full-text exclusion reason(s): All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 15289374].
Wong RC, Sinha AK, Mahadevan M, et al. Diagnostic utility, safety, and cost-effectiveness of emergency department-initiated early scheduled technetium-99m single photon emission computed tomography imaging followed by expedited outpatient cardiac clinic visits in acute chest pain syndromes. Emergency Radiology. 2010;17(5):375-380. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 20437252].
Wright DJ, Williams SG, Lindsay HS, et al. Assessment of adenosine, arbutamine and dobutamine as pharmacological stress agents during (99m)Tc-tetrofosmin SPECT imaging: a randomized study. Nucl Med Commun. 2001;22(12):1305-11. Full-text exclusion reason(s): Study does not compare one NIT to another or to diagnostic cardiac catheterization; Data for women not reported as a subgroup. [pmid: 11711900].
Wu CC, Ho YL, Kao SL, et al. Dobutamine stress echocardiography for detecting coronary artery disease. Cardiology. 1996;87(3):244-9. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 8725322].
Wu MC, Chin KC, Lin KH, et al. Diagnostic efficacy of a low-dose 32-projection SPECT 99mTc-sestamibi myocardial perfusion imaging protocol in routine practice. Nucl Med Commun. 2009;30(2):140-7. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 19194212].
Wu YW, Huang PJ, Su MY, et al. Myocardiun viability assessed by delayed contrast-enhanced magnetic resonance imaging in patients with severe ischemic heart failure: A comparison with thallium SPECT and dobutamine echocardiography. World Heart Journal. 2008;1(1):57-68. Full-text exclusion reason(s): No women with symptomatic chest pain, or results are not reported separately for symptomatic subgroup; All women in the study are known to have CAD; Data for women not reported as a subgroup.
Xiao Y, Tian JM, Gong J, et al. Screening for consecutive patient population with suspected CAD by 64-slice CT coronary angiography. Zhonghua Yu Fang Yi Xue Za Zhi. Suppl. 2007;41:134-7. Full-text exclusion reason(s): Non-English. [pmid: 17767879].
Xie F, Hankins J, Mahrous HA, et al. Detection of coronary artery disease with a continuous infusion of definity ultrasound contrast during adenosine stress real time perfusion echocardiography. Echocardiography. 2007;24(10):1044-50. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 18001357].
Xie F, Tsutsui JM, McGrain AC, et al. Comparison of dobutamine stress echocardiography with and without real-time perfusion imaging for detection of coronary artery disease. Am J Cardiol. 2005;96(4):506-11. Full-text exclusion reason(s): All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 16098301].
Xu L, Yang L, Fan Z, et al. Diagnostic performance of 320-detector CT coronary angiography in patients with atrial fibrillation: preliminary results. Eur Radiol. 2011;21(5):936-43. Full-text exclusion reason(s): Study does not compare one NIT to another or to diagnostic cardiac catheterization; Data for women not reported as a subgroup; No outcomes of interest. [pmid: 21153826].
Xu Y, Fish M, Gerlach J, et al. Combined quantitative analysis of attenuation corrected and non-corrected myocadial perfusion SPECT: Method development and clinical validation. J Nucl Cardiol. 2010;17(4):591-599. Full-text exclusion reason(s): Study does not compare one NIT to another or to diagnostic cardiac catheterization; Data for women not reported as a subgroup. [pmid: 20387137].
Xu Y, Tang L, Zhu X, et al. Comparison of dual-source CT coronary angiography and conventional coronary angiography for detecting coronary artery disease. Int J Cardiovasc Imaging. Suppl 1. 2010;26:75-81. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 20049537].
Yalcin H, Aktas A, Erol T, et al. Myocardial perfusion SPECT and dobutamine stress tissue Doppler imaging in evaluation of patients with stable angina pectoris. Anadolu Kardiyol Derg. 2010;10(4):334-9. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 20693129].
Yamabe H, Fujiwara S, Rin K, et al. Resting 123I-BMIPP scintigraphy for detection of organic coronary stenosis and therapeutic outcome in patients with chest pain. Ann Nucl Med. 2000;14(3):187-92. Full-text exclusion reason(s): No women with symptomatic chest pain, or results are not reported separately for symptomatic subgroup; Data for women not reported as a subgroup. [pmid: 10921483].
Yamada AT, Soares J Jr, Meneghetti JC, et al. Planar myocardial perfusion imaging for evaluation of patients with acute chest pain. Int J Cardiol. 2004;97(3):447-53. Full-text exclusion reason(s): All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 15561332].
Yamada K, Hirai M, Abe K, et al. Diagnostic usefulness of postexercise systolic blood pressure response for detection of coronary artery disease in patients with echocardiographic left ventricular hypertrophy. Can J Cardiol. 2004;20(7):705-11. Full-text exclusion reason(s): No women with symptomatic chest pain, or results are not reported separately for symptomatic subgroup; Data for women not reported as a subgroup. [pmid: 15197423].
Yamada T, Sawada T, Yamano T, et al. Evaluation of coronary arterial stenoses using 2D magnetic resonance coronary angiography. Minimally Invasive Therapy and Allied Technologies. 2002;11(1):7-15. Full-text exclusion reason(s): No women with symptomatic chest pain, or results are not reported separately for symptomatic subgroup; All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 16754040].
Yamaguchi M, Shimizu M, Ino H, et al. Diagnostic usefulness of the post-exercise systolic blood pressure response for the detection of coronary artery disease in patients with diabetes mellitus. Jpn Circ J. 2000;64(12):949-52. Full-text exclusion reason(s): No women with symptomatic chest pain, or results are not reported separately for symptomatic subgroup; Data for women not reported as a subgroup. [pmid: 11194289].
Yang CW, Carr JC, Francois CJ, et al. Coronary magnetic resonance angiography using magnetization-prepared contrast-enhanced breath-hold volume-targeted imaging (MPCE-VCATS). Invest Radiol. 2006;41(8):639-44. Full-text exclusion reason(s): No women with symptomatic chest pain, or results are not reported separately for symptomatic subgroup; Data for women not reported as a subgroup. [pmid: 16829747].
Yang L, Zhang Z, Fan Z, et al. 64-MDCT coronary angiography of patients with atrial fibrillation: influence of heart rate on image quality and efficacy in evaluation of coronary artery disease. AJR Am J Roentgenol. 2009;193(3):795-801. Full-text exclusion reason(s): No women with symptomatic chest pain, or results are not reported separately for symptomatic subgroup; Data for women not reported as a subgroup. [pmid: 19696294].
Yang MF, Dou KF, Liu XJ, et al. Prognostic value of normal exercise 99mTc-sestamibi myocardial tomography in patients with angiographic coronary artery disease. Nucl Med Commun. 2006;27(4):333-8. Full-text exclusion reason(s): No women with symptomatic chest pain, or results are not reported separately for symptomatic subgroup; Data for women not reported as a subgroup. [pmid: 16531918].
Yang PC, Santos JM, Nguyen PK, et al. Dynamic real-time architecture in magnetic resonance coronary angiography—a prospective clinical trial. J Cardiovasc Magn Reson. 2004;6(4):885-94. Full-text exclusion reason(s): No women with symptomatic chest pain, or results are not reported separately for symptomatic subgroup; All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 15646892].
Yang Q, Li K, Liu X, et al. Contrast-enhanced whole-heart coronary magnetic resonance angiography at 3.0-T: a comparative study with X-ray angiography in a single center. J Am Coll Cardiol. 2009;54(1):69-76. Full-text exclusion reason(s): No women with symptomatic chest pain, or results are not reported separately for symptomatic subgroup; All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 19555843].
Yang WI, Hur J, Ko YG, et al. Assessment of tissue characteristics of noncalcified coronary plaques by 64-slice computed tomography in comparison with integrated backscatter intravascular ultrasound. Coron Artery Dis. 2010;21(3):168-74. Full-text exclusion reason(s): All women in the study are known to have CAD; Study does not compare one NIT to another or to diagnostic cardiac catheterization; Data for women not reported as a subgroup. [pmid: 20299980].
Yang X, Gai LY, Li P, et al. Diagnostic accuracy of dual-source CT angiography and coronary risk stratification. Vasc Health Risk Manag. 2010;6:935-41. Full-text exclusion reason(s): No women with symptomatic chest pain, or results are not reported separately for symptomatic subgroup; All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 21057578].
Yanik A, Yetkin E, Senen K, et al. Value of dobutamine stress echocardiography for diagnosis of coronary artery disease in patients with left bundle branch blockage. Coron Artery Dis. 2000;11(7):545-8. Full-text exclusion reason(s): No women with symptomatic chest pain, or results are not reported separately for symptomatic subgroup; Data for women not reported as a subgroup. [pmid: 11023242].
Yao SS, Bangalore S, Chaudhry FA. Prognostic implications of stress echocardiography and impact on patient outcomes: An effective gatekeeper for coronary angiography and revascularization. Journal of the American Society of Echocardiography. 2010;23(8):832-839. Full-text exclusion reason(s): No women with symptomatic chest pain, or results are not reported separately for symptomatic subgroup; All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 20554154].
Yao SS, Qureshi E, Sherrid MV, et al. Practical applications in stress echocardiography: risk stratification and prognosis in patients with known or suspected ischemic heart disease. J Am Coll Cardiol. 2003;42(6):1084-90. Full-text exclusion reason(s): No women with symptomatic chest pain, or results are not reported separately for symptomatic subgroup; All women in the study are known to have CAD; Study does not compare one NIT to another or to diagnostic cardiac catheterization; Data for women not reported as a subgroup. [pmid: 13678935].
Yao SS, Shah A, Bangalore S, et al. Transient ischemic left ventricular cavity dilation is a significant predictor of severe and extensive coronary artery disease and adverse outcome in patients undergoing stress echocardiography. J Am Soc Echocardiogr. 2007;20(4):352-8. Full-text exclusion reason(s): All women in the study are known to have CAD; Study does not compare one NIT to another or to diagnostic cardiac catheterization; Data for women not reported as a subgroup. [pmid: 17400113].
Yao SS, Weinberg C, Bangalore S, et al. The changing paradigm of stress echocardiography: risk stratification, prognosis, and future directions. Hosp Pract (Minneap). 2010;38(3):26-39. Full-text exclusion reason(s): Not original peer-reviewed data or a secondary analysis of RCT, prospective or retrospective observational study, or registry. [pmid: 20499770].
Yao Z, Liu XJ, Shi R, et al. A comparison of 99mTc-MIBI myocardial SPET with electron beam computed tomography in the assessment of coronary artery disease. Eur J Nucl Med. 1997;24(9):1115-20. Full-text exclusion reason(s): No women with symptomatic chest pain, or results are not reported separately for symptomatic subgroup; All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 9283103].
Yao Z, Liu XJ, Shi RF, et al. A comparison of 99Tcm-MIBI myocardial SPET and electron beam computed tomography in the assessment of coronary artery disease in two different age groups. Nucl Med Commun. 2000;21(1):43-8. Full-text exclusion reason(s): No women with symptomatic chest pain, or results are not reported separately for symptomatic subgroup; All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 10717901].
Yao ZM, Li W, Qu WY, et al. Comparison of 9(9m)Tc-methoxyisobutylisonitrile myocardial single-photon emission computed tomography and electron beam computed tomography for detecting coronary artery disease in patients with no myocardial infarction. Chin Med J (Engl). 2004;117(5):700-705. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 15161537].
Yap LB, Arshad W, Jain A, et al. Significance of ST depression during exercise treadmill stress and adenosine infusion myocardial perfusion imaging. Int J Cardiovasc Imaging. 2005;21(2–3):253-8. discussion 259–60. Full-text exclusion reason(s): All women in the study are known to have CAD. [pmid: 16015437].
Yeo TC, Ling LH, Ng WL, et al. Dobutamine stress echocardiography: angiographic correlates. Ann Acad Med Singapore. 1996;25(2):196-9. Full-text exclusion reason(s): No women with symptomatic chest pain, or results are not reported separately for symptomatic subgroup; Data for women not reported as a subgroup. [pmid: 8799005].
Yeon SB, Sabir A, Clouse M, et al. Delayed-enhancement cardiovascular magnetic resonance coronary artery wall imaging: comparison with multislice computed tomography and quantitative coronary angiography. J Am Coll Cardiol. 2007;50(5):441-7. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 17662397].
Yildirir A, Kaynar G, Gulmez O, et al. Is it possible to increase the diagnostic value of exercise electrocardiography by post-exercise B-type natriuretic peptide levels?. Acta Cardiol. 2007;62(1):39-45. Full-text exclusion reason(s): Study does not compare one NIT to another or to diagnostic cardiac catheterization; Data for women not reported as a subgroup. [pmid: 17375891].
Yilmaz MH, Yasar D, Albayram S, et al. Coronary calcium scoring with MDCT: the radiation dose to the breast and the effectiveness of bismuth breast shield. Eur J Radiol. 2007;61(1):139-43. Full-text exclusion reason(s): All women in the study are known to have CAD; Study does not compare one NIT to another or to diagnostic cardiac catheterization. [pmid: 16962280].
Yip GW, Chandrasekaran K, Miller TD, et al. Feasibility of continuous venous infusion of SonoVue for qualitative assessment of reversible coronary perfusion defects in stress myocardial contrast echocardiography. Int J Cardiovasc Imaging. 2003;19(6):473-81. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 14690186].
Yorgun H, Kaya EB, Hazirolan T, et al. Prevalence of incidental pulmonary findings and early follow-up results in patients undergoing dual-source 64-slice computed tomography coronary angiography. J Comput Assist Tomogr. 2010;34(2):296-301. Full-text exclusion reason(s): All women in the study are known to have CAD; Study does not compare one NIT to another or to diagnostic cardiac catheterization; Data for women not reported as a subgroup. [pmid: 20351524].
Yosefy C, Cantor A, Reisin L, et al. The diagnostic value of QRS changes for prediction of coronary artery disease during exercise testing in women: false-positive rates. Coron Artery Dis. 2004;15(3):147-54. Full-text exclusion reason(s): Study does not compare one NIT to another or to diagnostic cardiac catheterization. [pmid: 15096995].
Yoshinaga K, Chow BJ, Williams K, et al. What is the prognostic value of myocardial perfusion imaging using rubidium-82 positron emission tomography?. J Am Coll Cardiol. 2006;48(5):1029-39. Full-text exclusion reason(s): No women with symptomatic chest pain, or results are not reported separately for symptomatic subgroup; All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 16949498].
Yoshitani H, Takeuchi M, Mor-Avi V, et al. Comparative diagnostic accuracy of multiplane and multislice three-dimensional dobutamine stress echocardiography in the diagnosis of coronary artery disease. J Am Soc Echocardiogr. 2009;22(5):437-42. Full-text exclusion reason(s): No women with symptomatic chest pain, or results are not reported separately for symptomatic subgroup; All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 19307099].
Yoshitani H, Takeuchi M, Sakamoto K, et al. Effect of one or more co-morbid conditions on diagnostic accuracy of coronary flow velocity reserve for detecting significant left anterior descending coronary stenosis. Heart. 2005;91(10):1294-8. Full-text exclusion reason(s): No women with symptomatic chest pain, or results are not reported separately for symptomatic subgroup; All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 16162619].
Younis LT, Byers S, Shaw L, et al. Prognostic importance of silent myocardial ischemia detected by intravenous dipyridamole thallium myocardial imaging in asymptomatic patients with coronary artery disease. J Am Coll Cardiol. 1989;14(7):1635-41. Full-text exclusion reason(s): No women with symptomatic chest pain, or results are not reported separately for symptomatic subgroup; Study does not compare one NIT to another or to diagnostic cardiac catheterization; Data for women not reported as a subgroup. [pmid: 2584551].
Yuda S, Khoury V, Marwick TH. Influence of wall stress and left ventricular geometry on the accuracy of dobutamine stress echocardiography. J Am Coll Cardiol. 2002;40(7):1311-9. Full-text exclusion reason(s): No women with symptomatic chest pain, or results are not reported separately for symptomatic subgroup; Data for women not reported as a subgroup. [pmid: 12383580].
Zafrir N, Mats I, Solodky A, et al. Prognostic value of stress myocardial perfusion imaging in octogenarian population. J Nucl Cardiol. 2005;12(6):671-5. Full-text exclusion reason(s): No women with symptomatic chest pain, or results are not reported separately for symptomatic subgroup; All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 16344229].
Zafrir N, Mats I, Solodky A, et al. Myocardial perfusion profile in a young population with and without known coronary artery disease: comparison by gender. Clin Cardiol. 2010;33(2):E39-43. Full-text exclusion reason(s): Study does not compare one NIT to another or to diagnostic cardiac catheterization. [pmid: 20043334].
Zaid G, Tanchilevitch A, Rivlin E, et al. Diagnostic accuracy of serum B-type natriuretic peptide for myocardial ischemia detection during exercise testing with spect perfusion imaging. Int J Cardiol. 2007;117(2):157-64. Full-text exclusion reason(s): No women with symptomatic chest pain, or results are not reported separately for symptomatic subgroup; All women in the study are known to have CAD; Data for women not reported as a subgroup; No outcomes of interest. [pmid: 16997398].
Zaid G, Yehudai D, Rosenschein U, et al. Coronary artery disease in an asymptomatic population undergoing a multidetector computed tomography (mdct) coronary angiography. Open Cardiovascular Medicine Journal. 2010;4:7-13. Full-text exclusion reason(s): No women with symptomatic chest pain, or results are not reported separately for symptomatic subgroup; Study does not compare one NIT to another or to diagnostic cardiac catheterization. [pmid: 20161814].
Zakavi SR, Taherpour M, Saleh F, et al. Electrocardiographic changes after dipyridamole infusion in patients undergoing myocardial perfusion imaging. Nucl Med Commun. 2010;31(6):502-505. Full-text exclusion reason(s): No women with symptomatic chest pain, or results are not reported separately for symptomatic subgroup; Study does not compare one NIT to another or to diagnostic cardiac catheterization; Data for women not reported as a subgroup. [pmid: 20145578].
Zaman MM, Haque SS, Siddique MA, et al. Correlation between Severity of Coronary Artery Stenosis and Perfusion Defect Assessed by SPECT Myocardial Perfusion Imaging. Mymensingh Med J. 2010;19(4):608-13. Full-text exclusion reason(s): Full-text unobtainable. [pmid: 20956907].
Zanco P, Zampiero A, Favero A, et al. Myocardial technetium-99m sestamibi single-photon emission tomography as a prognostic tool in coronary artery disease: multivariate analysis in a long-term prospective study. Eur J Nucl Med. 1995;22(9):1023-8. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 7588939].
Zellweger MJ, Dubois EA, Lai S, et al. Risk stratification in patients with remote prior myocardial infarction using rest-stress myocardial perfusion SPECT: prognostic value and impact on referral to early catheterization. J Nucl Cardiol. 2002;9(1):23-32. Full-text exclusion reason(s): All women in the study are known to have CAD; Study does not compare one NIT to another or to diagnostic cardiac catheterization; Data for women not reported as a subgroup. [pmid: 11845126].
Zerahn B, Jensen BV, Nielsen KD, et al. Increased prognostic value of combined myocardial perfusion imaging and exercise electrocardiography in patients with coronary artery disease. J Nucl Cardiol. 2000;7(6):616-22. Full-text exclusion reason(s): No women with symptomatic chest pain, or results are not reported separately for symptomatic subgroup; All women in the study are known to have CAD; Data for women not reported as a subgroup. [pmid: 11144476].
Zhang JJ, Liu T, Feng Y, et al. Diagnostic value of 64-slice dual-source CT coronary angiography in patients with atrial fibrillation: Comparison with invasive coronary angiography. Korean J Radiol. 2011;12(4):416-423. Full-text exclusion reason(s): No women with symptomatic chest pain, or results are not reported separately for symptomatic subgroup; Data for women not reported as a subgroup. [pmid: 21852901].
Zhang LJ, Wu SY, Wang J, et al. Diagnostic accuracy of dual-source CT coronary angiography: The effect of average heart rate, heart rate variability, and calcium score in a clinical perspective. Acta Radiol. 2010;51(7):727-40. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 20707657].
Zhang ZH, Jin ZY, Li DJ, et al. Non-invasive imaging of coronary artery with 16-slice spiral computed tomography. Chin Med Sci J. 2004;19(3):174-9. Full-text exclusion reason(s): No women with symptomatic chest pain, or results are not reported separately for symptomatic subgroup; Data for women not reported as a subgroup. [pmid: 15506642].
Zhao Y, Wei JP, Hua Q, et al. Comparison of multi-slice CT coronary artery imaging with coronary angiography. Journal of Clinical Rehabilitative Tissue Engineering Research. 2008;12(44):8792-8796. Full-text exclusion reason(s): Data for women not reported as a subgroup.
Zoghbi WA, Cheirif J, Kleiman NS, et al. Diagnosis of ischemic heart disease with adenosine echocardiography. J Am Coll Cardiol. 1991;18(5):1271-9. Full-text exclusion reason(s): Data for women not reported as a subgroup. [pmid: 1918704].