# Quality and Applicability of Included Studies

Table D-1 Quality, applicability, and relevant Key Questions (KQs)

Table D-2 QUADAS tool for quality assessment of diagnostic accuracy