# List of Included Studies

Abramson BL, Ruddy TD, deKemp RA, et al. Stress perfusion/metabolism imaging: a pilot study for a potential new approach to the diagnosis of coronary disease in women. J Nucl Cardiol. 2000;7(3):205-12. [pmid: 10888390].
Agati L, Renzi M, Sciomer S, et al. Transesophageal dipyridamole echocardiography for diagnosis of coronary artery disease. J Am Coll Cardiol. 1992;19(4):765-70. [pmid: 1545071].
Barolsky SM, Gilbert CA, Faruqui A, et al. Differences in electrocardiographic response to exercise of women and men: a non-Bayesian factor. Circulation. 1979;60(5):1021-7. [pmid: 487535].
Bjornstad K, Aakhus S, Hatle L. Comparison of digital dipyridamole stress echocardiography and upright bicycle stress echocardiography for identification of coronary artery stenosis. Cardiology. 1995;86(6):514-20. [pmid: 7585764].
Bokhari S, Shahzad A, Bergmann SR. Superiority of exercise myocardial perfusion imaging compared with the exercise ECG in the diagnosis of coronary artery disease. Coron Artery Dis. 2008;19(6):399-404. [pmid: 18955833].
Burgi Wegmann B, Sutsch G, Rickli H, et al. Gender and noninvasive diagnosis of coronary artery disease in women and men. J Womens Health (Larchmt). 2003;12(1):51-9. [pmid: 12639369].
Chae SC, Heo J, Iskandrian AS, et al. Identification of extensive coronary artery disease in women by exercise single-photon emission computed tomographic (SPECT) thallium imaging. J Am Coll Cardiol. 1993;21(6):1305-11. [pmid: 8473634].
Cin VG, Tartanoglu O, Duzenli A, et al. The use of basic clinical and exercise variables in postmenopausal women for the diagnosis of coronary artery disease. Int Angiol. 2000;9(3):135-137.
Coelho-Filho OR, Seabra LF, Mongeon FP, et al. Stress Myocardial Perfusion Imaging by CMR Provides Strong Prognostic Value to Cardiac Events Regardless of Patient’s Sex. JACC Cardiovasc Imaging. 2011;4(8):850-61. [pmid: 21835377].
DePasquale EE, Nody AC, DePuey EG, et al. Quantitative rotational thallium-201 tomography for identifying and localizing coronary artery disease. Circulation. 1988;77(2):316-27. [pmid: 3257422].
Dewey M, Rutsch W, Hamm B. Is there a gender difference in noninvasive coronary imaging? Multislice computed tomography for noninvasive detection of coronary stenoses. BMC Cardiovasc Disord. 2008;8:2. [pmid: 18230167].
Dewey M, Teige F, Schnapauff D, et al. Noninvasive detection of coronary artery stenoses with multislice computed tomography or magnetic resonance imaging. Ann Intern Med. 2006;145(6):407-15. [pmid: 16983128].
Dewey M, Vavere AL, Arbab-Zadeh A, et al. Patient characteristics as predictors of image quality and diagnostic accuracy of MDCT compared with conventional coronary angiography for detecting coronary artery stenoses: CORE-64 Multicenter International Trial. AJR Am J Roentgenol. 2010;194(1):93-102. [pmid: 20028910].
Dharampal AS, Rossi A, Papadopoulou SL, et al. Is there a difference in the diagnostic accuracy of computed tomography coronary angiography between women and men?. Coron Artery Dis. 2011;22(6):421-427. [pmid: 21606842].
Dionisopoulos PN, Collins JD, Smart SC, et al. The value of dobutamine stress echocardiography for the detection of coronary artery disease in women. J Am Soc Echocardiogr. 1997;10(8):811-7. [pmid: 9356945].
Dodi C, Cortigiani L, Masini M, et al. The incremental prognostic value of pharmacological stress echo over exercise electrocardiography in women with chest pain of unknown origin. Eur Heart J. 2001;22(2):145-52. [pmid: 11161916].
Doyle M, Fuisz A, Kortright E, et al. The impact of myocardial flow reserve on the detection of coronary artery disease by perfusion imaging methods: an NHLBI WISE study. J Cardiovasc Magn Reson. 2003;5(3):475-85. [pmid: 12882078].
Doyle M, Weinberg N, Pohost GM, et al. Prognostic Value of Global MR Myocardial Perfusion Imaging in Women With Suspected Myocardial Ischemia and No Obstructive Coronary Disease Results From the NHLBI-Sponsored WISE (Women’s Ischemia Syndrome Evaluation) Study. JACC Cardiovasc Imaging. 2010;3(10):1030-6. [pmid: 20947048].
Elhendy A, Geleijnse ML, van Domburg RT, et al. Gender differences in the accuracy of dobutamine stress echocardiography for the diagnosis of coronary artery disease. Am J Cardiol. 1997;80(11):1414-8. [pmid: 9399713].
Elhendy A, Schinkel AF, Bax JJ, et al. Accuracy of stress Tc-99m tetrofosmin myocardial perfusion tomography for the diagnosis and localization of coronary artery disease in women. J Nucl Cardiol. 2006;13(5):629-34. [pmid: 16945742].
Elhendy A, van Domburg RT, Bax JJ, et al. Noninvasive diagnosis of coronary artery stenosis in women with limited exercise capacity: comparison of dobutamine stress echocardiography and 99mTc sestamibi single-photon emission CT. Chest. 1998;114(4):1097-104. [pmid: 9792583].
Emmett L, Iwanochko RM, Freeman MR, et al. Reversible regional wall motion abnormalities on exercise technetium-99m-gated cardiac single photon emission computed tomography predict high-grade angiographic stenoses. J Am Coll Cardiol. 2002;39(6):991-8. [pmid: 11897441].
Faisal AW, Abid AR, Azhar M. Exercise Tolerance Test: a comparison between true positive and false positive test results. J Ayub Med Coll Abbottabad. 2007;19(4):71-4. [pmid: 18693603].
Friedman TD, Greene AC, Iskandrian AS, et al. Exercise thallium-201 myocardial scintigraphy in women: correlation with coronary arteriography. Am J Cardiol. 1982;49(7):1632-7. [pmid: 7081050].
Gebker R, Jahnke C, Hucko T, et al. Dobutamine stress magnetic resonance imaging for the detection of coronary artery disease in women. Heart. 2010;96(8):616-20. [pmid: 19687013].
Gentile R, Vitarelli A, Schillaci O, et al. Diagnostic accuracy and prognostic implications of stress testing for coronary artery disease in the elderly. Ital Heart J. 2001;2(7):539-45. [pmid: 11501963].
Guiteras P, Chaitman BR, Waters DD, et al. Diagnostic accuracy of exercise ECG lead systems in clinical subsets of women. Circulation. 1982;65(7):1465-74. [pmid: 7074802].
Gulati M, Pratap P, Kansal P, et al. Gender differences in the value of ST-segment depression during adenosine stress testing. Am J Cardiol. 2004;94(8):997-1002. [pmid: 15476611].
Hlatky MA, Pryor DB, Harrell FE Jr, et al. Factors affecting sensitivity and specificity of exercise electrocardiography. Multivariable analysis. Am J Med. 1984;77(1):64-71. [pmid: 6741986].
Ho YL, Wu CC, Huang PJ, et al. Assessment of coronary artery disease in women by dobutamine stress echocardiography: comparison with stress thallium-201 single-photon emission computed tomography and exercise electrocardiography. Am Heart J. 1998;135(4):655-62. [pmid: 9539482].
Hoilund-Carlsen PF, Johansen A, Christensen HW, et al. Usefulness of the exercise electrocardiogram in diagnosing ischemic or coronary heart disease in patients with chest pain. Am J Cardiol. 2005;95(1):96-9. [pmid: 15619400].
Hoilund-Carlsen PF, Johansen A, Vach W, et al. High probability of disease in angina pectoris patients: is clinical estimation reliable?. Can J Cardiol. 2007;23(8):641-7. [pmid: 17593989].
Hosokawa J, Shen JT, Imhoff M. Computerized 2-lead resting ECG analysis for the detection of relevant coronary artery stenosis in comparison with angiographic findings. Congest Heart Fail. 2008;14(5):251-60. [pmid: 18983288].
Hung J, Chaitman BR, Lam J, et al. Noninvasive diagnostic test choices for the evaluation of coronary artery disease in women: a multivariate comparison of cardiac fluoroscopy, exercise electrocardiography and exercise thallium myocardial perfusion scintigraphy. J Am Coll Cardiol. 1984;4(1):8-16. [pmid: 6736458].
Jenkins SM, Johnston N, Hawkins NM, et al. Limited clinical utility of CT coronary angiography in a district hospital setting. QJM. 2010. [pmid: 20847015].
Johansen A, Hoilund-Carlsen PF, Christensen HW, et al. Observer variability in the evaluation of dual-isotope Tl-201/Tc-99m sestamibi rest/stress myocardial perfusion SPECT in men and women with known or suspected stable angina pectoris. J Nucl Cardiol. 2004;11(6):710-8. [pmid: 15592195].
Johnson BD, Shaw LJ, Buchthal SD, et al. Prognosis in women with myocardial ischemia in the absence of obstructive coronary disease: results from the National Institutes of Health-National Heart, Lung, and Blood Institute-Sponsored Women’s Ischemia Syndrome Evaluation (WISE). Circulation. 2004;109(24):2993-9. [pmid: 15197152].
Kaminek M, Myslivecek M, Husak V, et al. The accuracy of myocardial perfusion SPECT imaging in the evaluation of coronary artery disease in women and men. Nucl Med Rev Cent East Eur. 2001;4(2):69-72. [pmid: 14600887].
Kiat H, Van Train KF, Maddahi J, et al. Development and prospective application of quantitative 2-day stress-rest Tc-99m methoxy isobutyl isonitrile SPECT for the diagnosis of coronary artery disease. Am Heart J. 1990;120(6 Pt 1):1255-66. [pmid: 2248175].
Klem I, Greulich S, Heitner JF, et al. Value of cardiovascular magnetic resonance stress perfusion testing for the detection of coronary artery disease in women. JACC Cardiovasc Imaging. 2008;1(4):436-45. [pmid: 19356464].
Koide Y, Yotsukura M, Yoshino H, et al. A new coronary artery disease index of treadmill exercise electrocardiograms based on the step-up diagnostic method. Am J Cardiol. 2001;87(2):142-7. [pmid: 11152828].
Langer C, Peterschroder A, Franzke K, et al. Noninvasive coronary angiography focusing on calcification: multislice computed tomography compared with magnetic resonance imaging. J Comput Assist Tomogr. 2009;33(2):179-85. [pmid: 19346842].
Laurienzo JM, Cannon RO 3rd, Quyyumi AA, et al. Improved specificity of transesophageal dobutamine stress echocardiography compared to standard tests for evaluation of coronary artery disease in women presenting with chest pain. Am J Cardiol. 1997;80(11):1402-7. [pmid: 9399711].
Lehmkuhl HB, Siniawski H, Lehmkuhl E, et al. Value and limitations of dobutamine stress echocardiography in women with suspected coronary artery disease. Zeitschrift fur Herz-, Thorax- und Gefasschirurgie. 2007;21(6):250-258.
Lewandowski M, Szwed H, Kowalik I. Searching for the optimal strategy for the diagnosis of stable coronary artery disease. Cost-effectiveness of the new algorithm. Cardiol J. 2007;14(6):544-51. [pmid: 18651520].
Lewis JF, Lin L, McGorray S, et al. Dobutamine stress echocardiography in women with chest pain. Pilot phase data from the National Heart, Lung and Blood Institute Women’s Ischemia Syndrome Evaluation (WISE). J Am Coll Cardiol. 1999;33(6):1462-8. [pmid: 10334409].
Lewis JF, McGorray S, Lin L, et al. Exercise treadmill testing using a modified exercise protocol in women with suspected myocardial ischemia: findings from the National Heart, Lung and Blood Institute-sponsored Women’s Ischemia Syndrome Evaluation (WISE). Am Heart J. 2005;149(3):527-33. [pmid: 15864243].
Lu C, Lu F, Fragasso G, et al. Comparison of exercise electrocardiography, technetium-99m sestamibi single photon emission computed tomography, and dobutamine and dipyridamole echocardiography for detection of coronary artery disease in hypertensive women. Am J Cardiol. 2010;105(9):1254-60. [pmid: 20403475].
Maffei E, Seitun S, Martini C, et al. CT coronary angiography and exercise ECG in a population with chest pain and low-to-intermediate pre-test likelihood of coronary artery disease. Heart. 2010;96(24):1973-9. [pmid: 21051457].
Majstorov V, Pop Gjorceva D, Vaskova O, et al. Gender differences in detecting coronary artery disease with dipyridamole stress myocardial perfusion imaging using 99m-Tc sestamibi gated SPECT. Prilozi. 2005;26(1):93-102. [pmid: 16118618].
Mak KH, Ang ES, Goh AS, et al. Myocardial perfusion imaging with technetium-99m sestamibi SPECT in the evaluation of coronary artery disease. Australas Radiol. 1995;39(2):112-7. [pmid: 7605313].
Marwick T, D’Hondt AM, Baudhuin T, et al. Optimal use of dobutamine stress for the detection and evaluation of coronary artery disease: combination with echocardiography or scintigraphy, or both?. J Am Coll Cardiol. 1993;22(1):159-67. [pmid: 8509537].
Marwick TH, Anderson T, Williams MJ, et al. Exercise echocardiography is an accurate and cost-efficient technique for detection of coronary artery disease in women. J Am Coll Cardiol. 1995;26(2):335-41. [pmid: 7608432].
Masini M, Picano E, Lattanzi F, et al. High dose dipyridamole-echocardiography test in women: correlation with exercise-electrocardiography test and coronary arteriography. J Am Coll Cardiol. 1988;12(3):682-5. [pmid: 3403825].
Mazeika P, Nihoyannopoulos P, Joshi J, et al. Uses and limitations of high dose dipyridamole stress echocardiography for evaluation of coronary artery disease. Br Heart J. 1992;67(2):144-9. [pmid: 1540434].
Meijboom WB, Meijs MF, Schuijf JD, et al. Diagnostic accuracy of 64-slice computed tomography coronary angiography: a prospective, multicenter, multivendor study. J Am Coll Cardiol. 2008;52(25):2135-44. [pmid: 19095130].
Meijboom WB, Weustink AC, Pugliese F, et al. Comparison of diagnostic accuracy of 64-slice computed tomography coronary angiography in women versus men with angina pectoris. Am J Cardiol. 2007;100(10):1532-7. [pmid: 17996514].
Merkle N, Wöhrle J, Nusser T, et al. Diagnostic performance of magnetic resonance first pass perfusion imaging is equally potent in female compared to male patients with coronary artery disease. Clin Res Cardiol. 2010;99(1):21-8. [pmid: 19756814].
Merz CN, Kelsey SF, Pepine CJ, et al. The Women’s Ischemia Syndrome Evaluation (WISE) study: protocol design, methodology and feasibility report. J Am Coll Cardiol. 1999;33(6):1453-61. [pmid: 10334408].
Michaelides AP, Fourlas CA, Chatzistamatiou EI, et al. QRS score improves diagnostic ability of treadmill exercise testing in women. Coron Artery Dis. 2007;18(4):313-8. [pmid: 17496496].
Mieres JH, Makaryus AN, Cacciabaudo JM, et al. Value of electrocardiographically gated single-photon emission computed tomographic myocardial perfusion scintigraphy in a cohort of symptomatic postmenopausal women. Am J Cardiol. 2007;99(8):1096-9. [pmid: 17437734].
Mieres JH, Shaw LJ, Hendel RC, et al. The WOMEN study: what is the optimal method for ischemia evaluation in women? A multi-center, prospective, randomized study to establish the optimal method for detection of coronary artery disease (CAD) risk in women at an intermediate-high pretest likelihood of CAD: study design. J Nucl Cardiol. 2009;16(1):105-12. [pmid: 19152135].
Miller JM, Dewey M, Vavere AL, et al. Coronary CT angiography using 64 detector rows: methods and design of the multi-centre trial CORE-64. Eur Radiol. 2009;19(4):816-28. [pmid: 18998142].
Miller TD, Roger VL, Milavetz JJ, et al. Assessment of the exercise electrocardiogram in women versus men using tomographic myocardial perfusion imaging as the reference standard. Am J Cardiol. 2001;87(7):868-73. [pmid: 11274942].
Mohiuddin SM, Ravage CK, Esterbrooks DJ, et al. The comparative safety and diagnostic accuracy of adenosine myocardial perfusion imaging in women versus men. Pharmacotherapy. 1996;16(4):646-51. [pmid: 8840371].
Morise AP. Are the American College of Cardiology/American Heart Association guidelines for exercise testing for suspected coronary artery disease correct?. Chest. 2000;118(2):535-41. [pmid: 10936152].
Morise AP, Diamond GA. Comparison of the sensitivity and specificity of exercise electrocardiography in biased and unbiased populations of men and women. Am Heart J. 1995;130(4):741-7. [pmid: 7572581].
Morise AP, Diamond GA, Detrano R, et al. Incremental value of exercise electrocardiography and thallium-201 testing in men and women for the presence and extent of coronary artery disease. Am Heart J. 1995;130(2):267-76. [pmid: 7631606].
Morise AP, Lauer MS, Froelicher VF. Development and validation of a simple exercise test score for use in women with symptoms of suspected coronary artery disease. Am Heart J. 2002;144(5):818-25. [pmid: 12422150].
Morise AP, Olson MB, Merz CN, et al. Validation of the accuracy of pretest and exercise test scores in women with a low prevalence of coronary disease: the NHLBI-sponsored Women’s Ischemia Syndrome Evaluation (WISE) study. Am Heart J. 2004;147(6):1085-92. [pmid: 15199360].
Nascimento BR, Chequer G, Barbosa MP, et al. Stable angina and ST-segment depression: diagnostic value in patients undergoing coronary angiography. Rev Port Cardiol. 2008;27(12):1567-80. [pmid: 19280997].
Ozdemir K, Altunkeser BB, Aydin M, et al. New parameters in the interpretation of exercise testing in women: QTc dispersion and QT dispersion ratio difference. Clin Cardiol. 2002;25(4):187-92. [pmid: 12000077].
Pundziute G, Schuijf JD, Jukema JW, et al. Gender influence on the diagnostic accuracy of 64-slice multislice computed tomography coronary angiography for detection of obstructive coronary artery disease. Heart. 2008;94(1):48-52. [pmid: 17540687].
Raman SV, Donnally MR, McCarthy B. Dobutamine stress cardiac magnetic resonance imaging to detect myocardial ischemia in women. Prev Cardiol. 2008;11(3):135-40. [pmid: 18607148].
Richardson MT, Holly RG, Amsterdam EA, et al. The value of ten common exercise tolerance test measures in predicting coronary disease in symptomatic females. Cardiology. 1995;86(3):243-8. [pmid: 7614498].
Robert AR, Melin JA, Detry JM. Logistic discriminant analysis improves diagnostic accuracy of exercise testing for coronary artery disease in women. Circulation. 1991;83(4):1202-9. [pmid: 2013142].
Roger VL, Pellikka PA, Bell MR, et al. Sex and test verification bias. Impact on the diagnostic value of exercise echocardiography. Circulation. 1997;95(2):405-10. [pmid: 9008457].
Rollan MJ, San Roman JA, Vilacosta I, et al. Dobutamine stress echocardiography in the diagnosis of coronary artery disease in women with chest pain: comparison with different noninvasive tests. Clin Cardiol. 2002;25(12):559-64. [pmid: 12492125].
San Roman JA, Vilacosta I, Castillo JA, et al. Selection of the optimal stress test for the diagnosis of coronary artery disease. Heart. 1998;80(4):370-6. [pmid: 9875115].
Sanfilippo AJ, Abdollah H, Knott TC, et al. Stress echocardiography in the evaluation of women presenting with chest pain syndrome: a randomized, prospective comparison with electrocardiographic stress testing. Can J Cardiol. 2005;21(5):405-12. [pmid: 15861257].
Santana-Boado C, Candell-Riera J, Castell-Conesa J, et al. Diagnostic accuracy of technetium-99m-MIBI myocardial SPECT in women and men. J Nucl Med. 1998;39(5):751-5. [pmid: 9591568].
Sawada SG, Ryan T, Fineberg NS, et al. Exercise echocardiographic detection of coronary artery disease in women. J Am Coll Cardiol. 1989;14(6):1440-7. [pmid: 2809000].
Schupbach WM, Emese B, Loretan P, et al. Non-invasive diagnosis of coronary artery disease using cardiogoniometry performed at rest. Swiss Med Wkly. 2008;138(15–16):230-8. [pmid: 18431698].
Severi S, Picano E, Michelassi C, et al. Diagnostic and prognostic value of dipyridamole echocardiography in patients with suspected coronary artery disease. Comparison with exercise electrocardiography. Circulation. 1994;89(3):1160-73. [pmid: 8124803].
Sharir T, Germano G, Waechter PB, et al. A new algorithm for the quantitation of myocardial perfusion SPECT. II: validation and diagnostic yield. J Nucl Med. 2000;41(4):720-7. [pmid: 10768575].
Shaw LJ, Mieres JH, Hendel RH, et al. Comparative effectiveness of exercise electrocardiography with or without myocardial perfusion single photon emission computed tomography in women with suspected coronary artery disease: results From the What Is the Optimal Method for Ischemia Evaluation in Women (WOMEN) Trial. Circulation. 2011. [pmid: 21844080].
Shi H, Santana CA, Rivero A, et al. Normal values and prospective validation of transient ischaemic dilation index in 82Rb PET myocardial perfusion imaging. Nucl Med Commun. 2007;28(11):859-63. [pmid: 17901769].
Shin JH, Shiota T, Kim YJ, et al. False-positive exercise echocardiograms: impact of sex and blood pressure response. Am Heart J. 2003;146(5):914-9. [pmid: 14597944].
Shivalkar B, Goovaerts I, Salgado RA, et al. Multislice cardiac computed tomography in symptomatic middle-aged women. Ann Med. 2007;39(4):290-7. [pmid: 17558600].
Siegler JC, Rehman S, Bhumireddy GP, et al. The Accuracy of the Electrocardiogram during Exercise Stress Test Based on Heart Size. PLoS One. 2011;6(8):e23044. [pmid: 21857990].
Sinha DP, Das M, Banerjee AK, et al. Comparative study to assess whether high sensitive C-reactive protein and carotid intima media thickness improve the predictive accuracy of exercise stress testing for coronary artery disease in perimenopausal women with typical angina. J Indian Med Assoc. 2008;106(2):86. 88. 90 passim. [pmid: 18705250].
Sketch MH, Mohiuddin SM, Lynch JD, et al. Significant sex differences in the correlation of electrocardiographic exercise testing and coronary arteriograms. Am J Cardiol. 1975;36(2):169-73. [pmid: 1155337].
Slavich GA, Guerra UP, Morocutti G, et al. Feasibility of simultaneous Tc99m sestamibi and 2D-echo cardiac imaging during dobutamine pharmacologic stress. Preliminary results in a female population. Int J Card Imaging. 1996;12(2):113-8. [pmid: 8864790].
Slomka PJ, Nishina H, Abidov A, et al. Combined quantitative supine-prone myocardial perfusion SPECT improves detection of coronary artery disease and normalcy rates in women. J Nucl Cardiol. 2007;14(1):44-52. [pmid: 17276305].
Slomka PJ, Nishina H, Berman DS, et al. Automated quantification of myocardial perfusion SPECT using simplified normal limits. J Nucl Cardiol. 2005;12(1):66-77. [pmid: 15682367].
Svart K, Lehtinen R, Nieminen T, et al. Exercise electrocardiography detection of coronary artery disease by. International Journal of Cardiology. 2010;140(2):182-188. [pmid: 19068271].
Taillefer R, DePuey EG, Udelson JE, et al. Comparative diagnostic accuracy of Tl-201 and Tc-99m sestamibi SPECT imaging (perfusion and ECG-gated SPECT) in detecting coronary artery disease in women. J Am Coll Cardiol. 1997;29(1):69-77. [pmid: 8996297].
Takeuchi M, Sonoda S, Miura Y, et al. Comparative diagnostic value of dobutamine stress echocardiography and stress thallium-201 single-photon-emission computed tomography for detecting coronary artery disease in women. Coron Artery Dis. 1996;7(11):831-5. [pmid: 8993941].
Travin MI, Katz MS, Moulton AW, et al. Accuracy of dipyridamole SPECT imaging in identifying individual coronary stenoses and multivessel disease in women versus men. J Nucl Cardiol. 2000;7(3):213-20. [pmid: 10888391].
Van Train KF, Garcia EV, Maddahi J, et al. Multicenter trial validation for quantitative analysis of same-day rest-stress technetium-99m-sestamibi myocardial tomograms. J Nucl Med. 1994;35(4):609-18. [pmid: 8151383].
Vashist A, Collins D, Prasad Y, et al. Does cardiac SPECT using attenuation and scatter correction accurately predict coronary artery disease in a minority women population?. Med Sci Monit. 2007;13(9):CR386-390. [pmid: 17767117].
Weiner DA. Accuracy of cardiokymography during exercise testing: results of a multicenter study. J Am Coll Cardiol. 1985;6(3):502-9. [pmid: 3897339].
Weiner DA, Ryan TJ, McCabe CH, et al. Exercise stress testing. Correlations among history of angina, ST-segment response and prevalence of coronary-artery disease in the Coronary Artery Surgery Study (CASS). N Engl J Med. 1979;301(5):230-5. [pmid: 449990].
Weustink AC, Meijboom WB, Mollet NR, et al. Reliable high-speed coronary computed tomography in symptomatic patients. J Am Coll Cardiol. 2007;50(8):786-94. [pmid: 17707184].
Weustink AC, Mollet NR, Neefjes LA, et al. Preserved diagnostic performance of dual-source CT coronary angiography with reduced radiation exposure and cancer risk. Radiology. 2009;252(1):53-60. [pmid: 19451542].
Williams MJ, Marwick TH, O’Gorman D, et al. Comparison of exercise echocardiography with an exercise score to diagnose coronary artery disease in women. Am J Cardiol. 1994;74(5):435-8. [pmid: 8059721].
Wolak A, Slomka PJ, Fish MB, et al. Quantitative diagnostic performance of myocardial perfusion SPECT with attenuation correction in women. J Nucl Med. 2008;49(6):915-22. [pmid: 18483092].
Wong Y, Rodwell A, Dawkins S, et al. Sex differences in investigation results and treatment in subjects referred for investigation of chest pain. Heart. 2001;85(2):149-52. [pmid: 11156662].
Yamauchi K, Simonson E, Dahl JC, et al. Sex differences in submaximal exercise tests correlation with coronary cineangiography in 133 patients. Nagoya J Med Sci. 1985;47(1–2):67-75. [pmid: 3990772].
Yeih DF, Huang PJ, Ho YL. Enhanced diagnosis of coronary artery disease in women by dobutamine thallium-201 ST-segment/heart rate slope and thallium-201 myocardial SPECT. J Formos Med Assoc. 2007;106(10):832-9. [pmid: 17964962].