# Data Abstraction Elements

I Study Characteristics
- Study dates
- Study sites
- Geographic location
- Funding source
- Study design
- If discernable: Is this article known to be a report of data from a population discussed in another article?
  ○ If Yes, note the primary publication for the study by entering the citation information or study identifier (trial name, acronym, or NCT number). Citation information is preferred.
- Testing setting (select all that apply)
  ○ Emergency Department/Chest Pain Unit
  ○ Outpatient
  ○ Inpatient
  ○ Other (specify)
  ○ Not Reported/Unclear
- Duration of longest follow-up after completion of final test. Enter with units (days, weeks, months). NR if Not Reported. Enter NA if Not Applicable (i.e. if the study did not include a follow-up period).
- Was screening and enrollment consecutive?
- Inclusion criteria: Copy/paste inclusion criteria as reported in the article.
- Exclusion criteria: Copy/paste exclusion criteria as reported in the article.
- Study Enrollment
  ○ Total population
    ▪ Number of subjects enrolled
    ▪ Number of subjects with known CAD
    ▪ Number of subjects without known CAD
    ▪ If applicable, enter the definition of known CAD
  ○ Female
    ▪ Number of subjects enrolled
    ▪ Number of subjects with known CAD
    ▪ Number of subjects without known CAD
    ▪ If applicable, enter the definition of known CAD
  ○ Male
    ▪ Number of subjects enrolled
    ▪ Number of subjects with known CAD
    ▪ Number of subjects without known CAD
    ▪ If applicable, enter the definition of known CAD
- Study Completion
  ○ Total population
    ▪ Number of subjects who received all study-specified diagnostic tests
    ▪ Number of subjects who completed follow-up phase to completion
  ○ Female
    ▪ Number of subjects who received all study-specified diagnostic tests
    ▪ Number of subjects who completed follow-up phase to completion
  ○ Male
    ▪ Number of subjects who received all study-specified diagnostic tests
    ▪ Number of subjects who completed follow-up phase to completion

II Baseline Demographics
- No known CAD reported
  ○ Age in years (Total, Female, and Male)
    ▪ p value (Female vs. Male data)
    ▪ Mean
    ▪ SD
    ▪ Min age
    ▪ Max age
    ▪ 25% IQR
    ▪ 75% IQR
  ○ Ethnicity (Total, Female, and Male)
    ▪ Hispanic or Latino
    ▪ Not Hispanic or Latino
  ○ Race (Total, Female, and Male)
    ▪ American Indian or Alaska Native
    ▪ Asian
    ▪ Black or African American
    ▪ Native Hawaiian or other Pacific Islander
    ▪ White
    ▪ Other
    ▪ Multiracial
    ▪ Not reported
  ○ Was body size reported?
    ▪ If yes, describe the measurement type and units.
    ▪ If yes, provide the characteristics as reported (e.g. range, mean with standard deviation, etc.)
  ○ Was heart size reported?
    ▪ If yes, describe the measurement type and units.
    ▪ If yes, provide the characteristics as reported (e.g. range, mean with standard deviation, etc.)
  ○ Was functional status (exercise capacity) reported?
    ▪ If yes, describe the measurement type and units
    ▪ If yes, provide the characteristics as reported (e.g. range, mean with standard deviation, etc.)
- Mixed known/no known CAD reported
  ○ Age in years (Total, Female, and Male)
    ▪ p value (Female vs. Male data)
    ▪ Mean
    ▪ SD
    ▪ Min age
    ▪ Max age
    ▪ 25% IQR
    ▪ 75% IQR
  ○ Ethnicity (Total, Female, and Male)
    ▪ Hispanic or Latino
    ▪ Not Hispanic or Latino
  ○ Race (Total, Female, and Male)
    ▪ American Indian or Alaska Native
    ▪ Asian
    ▪ Black or African American
    ▪ Native Hawaiian or other Pacific Islander
    ▪ White
    ▪ Other
    ▪ Multiracial
    ▪ Not reported
  ○ Was body size reported?
    ▪ If yes, describe the measurement type and units.
    ▪ If yes, provide the characteristics as reported (e.g. range, mean with standard deviation, etc.)
  ○ Was heart size reported?
    ▪ If yes, describe the measurement type and units.
    ▪ If yes, provide the characteristics as reported (e.g. range, mean with standard deviation, etc.)
  ○ Was functional status (exercise capacity) reported?
    ▪ If yes, describe the measurement type and units
    ▪ If yes, provide the characteristics as reported (e.g. range, mean with standard deviation, etc.)

III NIT and Comparator Characteristics
- NITs included in study
  ○ Electrocardiogram (exercise/stress or resting) = ECG
  ○ Echocardiography (with or without contrast) = ECHO
  ○ Exercise/stress radionuclide myocardial perfusion imaging (MPI). Includes:
    ▪ Single proton emission computed tomography = SPECT,
    ▪ Positron emission tomography = PET,
    ▪ Scintigraphy
  ○ Cardiac perfusion and stress magnetic resonance imaging = CMR
  ○ Multidetector cardiac computed tomography angiography = CTA

IV ECG Module
- Type (multiple selections)
  ▪ Exercise stress
  ▪ Pharmacologic stress
  ▪ Multifunction Cardiogram [MCG]
- If exercise stress, type of exercise performed (multiple selections)
  ▪ Treadmill
  ▪ Bicycle
  ▪ Step
  ▪ Other (specify)
  ▪ Not exercise stress
- If pharmacologic stress, type of agent used.
  ▪ Dobutamine
  ▪ Adenosine
  ▪ Dipyridamole
  ▪ Other (specify)
  ▪ Not pharmacologic stress
- Definition of a positive result
  - ≥ 1 mm ST depression
  - 1–2 mm ST depression
  - ≥ 2 mm ST depression
  - Other (specify)

V Stress ECHO Module
- Type of stressor (multiple selections)
  ○ Exercise stress
  ○ Pharmacologic stress
- If exercise stress, type of exercise performed (multiple selections)
  ○ Treadmill
  ○ Bicycle
  ○ Other (specify)
  ○ Not exercise stress
- If pharmacologic stress, type of agent used.
  ▪ Dobutamine
  ▪ Adenosine
  ▪ Dipyridamole
  ▪ Other (specify)
  ▪ Not pharmacologic stress
- Was contrast agent used?
- Definition of a positive result
  ▪ Wall Motion Abnormality (WMA) at rest and at stress
  ▪ Wall Motion Abnormality (WMA) at stress, but not at rest
  ▪ Wall Motion Abnormality (WMA) not otherwise specified
- If ECG used, definition of a positive result
  - ≥ 1 mm ST depression
  - 1–2 mm ST depression
  - ≥ 2 mm ST depression
    ▪ Other (specify)

VI Exercise/stress myocardial perfusion imaging Module
- Modality
  ○ Single selection: SPECT, PET, scintigraphy
- Type of stressor
  ○ Exercise stress, Pharmacologic stress
  ○ If exercise stress, type of exercise performed.
    - Treadmill
    - Bicycle
    - Other (specify)
    - Not exercise stress
- If pharmacologic stress, type of agent used.
  ○ Dobutamine
  ○ Adenosine
  ○ Dipyridamole
  ○ Other (specify)
  ○ Not pharmacologic stress
- Radionuclide used
  ○ Technetium Tc 99m sestamibi (MIBI)
  ○ Thallous chloride TL-201 (thallium)
  ○ Fluorodeoxyglucose (FDG)
  ○ Other (specify)
- Definition of a positive result
  ○ Reported by Sum Stress Score (SSS)?
    - If yes, enter threshold value for positive result
  ○ Reported by % ischemic LV?
    - If yes, enter threshold value for positive result
  ○ Reported by evidence of ischemia in any segment?
    - If yes, enter number of segments considered a positive result
  ○ Reported by Transient Ischemic Dilation (or Total Perfusion Deficit)?
    - If yes, enter threshold value for positive result
- If ECG used, definition of a positive result
  - ≥ 1 mm ST depression
  - 1–2 mm ST depression
  - ≥ 2 mm ST depression
  - Other (specify)

VII Cardiac perfusion and stress magnetic resonance imaging (CMR) Module
- Type of test (multiple selections):
  ▪ Dobutamine cine CMR
  ▪ Vasodilator stress perfusion
  ▪ Delayed enhanced (DE-CMR)
  ▪ Other (specify)
- Type of stressor (multiple selections):
  ▪ Exercise stress
  ▪ Pharmacologic stress
- If exercise stress, type of exercise performed. If not exercise, select “Not exercise stress.” (multiple selections):
  ▪ Bicycle
  ▪ Other (specify)
  ▪ Not exercise stress
- If pharmacologic stress, type of agent used (multiple selections):
  ○ Dobutamine
  ○ Adenosine
  ○ Dipyridamole
  ○ Other (specify w/free text field)
  ○ Not pharmacologic stress
- Was contrast agent used?
  ▪ If yes, specify the contrast agent.
- Definition of positive result
  ▪ Reported by perfusion defect?
    - If yes, enter threshold value for positive result
  ▪ MRA of coronary arteries performed?
    - If yes, enter threshold value for positive result
  ▪ Wall Motion Abnormalities (WMA) assessed?
    - If yes, select definition of positive result
      ○ Wall Motion Abnormality (WMA) at rest and at stress
      ○ Wall Motion Abnormality (WMA) at stress, but not at rest
      ○ Wall Motion Abnormality (WMA) not otherwise specified

VIII Multidetector cardiac computed tomography angiography (CTA) Module
- Was contrast agent used?
  ○ If yes, specify the contrast agent and dose (including units).
- Number of slices (multiple selections):
  ○ 4-slice
  ○ 16-slice
  ○ 32-slice
  ○ Other number less than 64 (specify w/text box)
  ○ 64-slice or greater
- Was calcium score testing performed?
- Definition of positive result (multiple selections):
  - ≥ 50% stenosis
  - ≥ 70% stenosis
  - ≥ 50% Left Main
  - Other (specify)

IX Diagnostic catheterization Module
- Angiographic definition of disease (multiple selections):
  ○ ≥ 50% stenosis
  ○ ≥ 70% stenosis
  ○ ≥ 50% Left Main
  ○ Other (specify)

X Modality comparisons
- Specify modality comparisons [one NIT to another (different) NIT, or a NIT to diagnostic cardiac catheterization].

XI Applicability to Key Questions
- KQ 1:
  - What is the accuracy of one noninvasive technology (NIT) in diagnosing obstructive and nonobstructive CAD when compared to another NIT or to coronary angiography in women with chest pain syndrome?
    ○ Exercise electrocardiogram (ECG) stress test (including resting ECG technology, such as a multifunctional cardiogram)
    ○ Exercise/stress echocardiography (ECHO) with or without a contrast agent
    ○ Exercise/stress radionuclide myocardial perfusion imaging (including single proton emission computed tomography [SPECT] and positron emission tomography [PET])
    ○ Cardiac perfusion and stress magnetic resonance imaging (CMR)
    ○ Multidetector cardiac computed tomography angiography (CTA)
- KQ 2:
  ○ What are the predictors of diagnostic accuracy (age, race/ethnicity, body size, heart size, menopausal status, functional status, stress modality) of different NITs in women?
- KQ 3:
  ○ Is there evidence that the use of NITs (when compared to other NITs or to diagnostic cardiac catheterization) in women improves:
    a. Risk stratification/prognostic information?
    b. Decisionmaking regarding treatment options (e.g., revascularization, optimal medical therapy)?
    c. Clinical outcomes (e.g., death, myocardial infarction, unstable angina, hospitalization, revascularization, angina relief, quality of life)?
- KQ 4:
  ○ Are there significant safety concerns/risks (i.e., radiation exposure, access site complications, contrast agent-induced nephropathy, nephrogenic systemic fibrosis, anaphylaxis, arrhythmias) associated with the use of different NITs to diagnose CAD in women with chest pain syndromes?

XII KQ 1
- Which modality-level comparison(s) from the “NIT and Comparators” form does this data correspond to? Select all that apply. Space is provided for up to 6 modality-level comparisons.
- Enter total N for each category, NR for not reported, or NA for not applicable (Total population, Female, Male)
- Number of subjects with known CAD
- Number of subjects without known CAD
- If applicable, enter the definition of known CAD
- For the modality-level comparison(s) indicated above, does the article present data separately for both “no known CAD” and “mixed known/no known CAD” populations?
  ○ If data is reported for a “no known CAD” population, enter age, ethnicity, race, body size, heart size, and functional status information for the “no known CAD” population in the section below labeled “No known CAD.”
  ○ If data is reported for a “mixed known/no known CAD” population, enter age, ethnicity, race, body size, heart size, and functional status information for the mixed population in the section below labeled “Mixed known/no known CAD.”
- Enter by Total population, Female, Male:
  ○ SD
  ○ Min age
  ○ Max age
  ○ 25% IQR
  ○ 75% IQR
  ○ Ethnicity
    ▪ Hispanic
    ▪ Non-Hispanic or Latino
  ○ Race
    ▪ American Indian or Alaska Native
    ▪ Asian
    ▪ Black or African American
    ▪ Native Hawaiian or other Pacific Islander
    ▪ White
    ▪ Other
    ▪ Multiracial
    ▪ Not reported
  ○ Was body size reported?
  ○ Was heart size reported?
  ○ Was functional status (exercise capacity) reported?

XIII KQ 2
- Indicate test modalities compared
- Indicate which predictive factor this data addresses
  ○ Age
  ○ Race/ethnicity
  ○ Body size
  ○ Heart size
  ○ Menopausal status
  ○ Functional status
  ○ Stress modality
- Indicate CAD status of the population
  ○ No known CAD
  ○ Mixed known/no known CAD
- Specify the female subgroups analyzed for this predictor and pair of test modalities. Columns are provided to capture up to 5 subgroup categories. Complete only the number needed to capture the data presented in the study.
- Define the groups
- Number of patients who received the index test
- Number of patients who received diagnostic cardiac cath
- Number of patients with adequate exercise for index test (if exercise is applicable)
- Number of patients with positive index test
- Number of patients with negative index test
- Disease prevalence (# of patients)
- Disease prevalence (%)
- True positive (# of patients)
- True negative (# of patients)
- False positive (# of patients)
- False negative (# of patients)
- Indeterminate or technically inadequate results (# of patients)
- Sensitivity (%)
- Sensitivity (Std dev)
- Sensitivity (Upper confidence interval bound)
- Sensitivity (Lower confidence interval bound)
- Specificity (%)
- Specificity (Std dev)
- Specificity (Upper confidence interval bound)
- Specificity (Lower confidence interval bound)
- Positive predictive value (%)
- Positive predictive value (Std dev)
- Positive predictive value (Upper confidence interval bound)
- Positive predictive value (Lower confidence interval bound)
- Negative predictive value (%)
- Negative predictive value (Std dev)
- Negative predictive value (Upper confidence interval bound)
- Negative predictive value (Lower confidence interval bound)
- Negative likelihood ratio
- Positive likelihood ratio
- Cath results
  ○ Number of patients with single-vessel disease
  ○ Number of patients with 2-vessel disease
  ○ Number of patients with 3-vessel disease
  ○ Number of patients with Left Main disease

XIV KQ 3
- Indicate test modalities compared
- Indicate CAD status of the population
- Does the study provide data on risk stratification/prognostic information?
- Describe the risk/prognostic findings by gender
- Risk/prognostic information
  ○ Decisionmaking about treatment (Treatments may include: None, Medical management, Invasive management)
  ○ Describe any decisionmaking findings not captured by gender
- Clinical outcomes measured by Total population, Female, Male: (multiple selections):
  ○ MI
  ○ Unstable angina
  ○ Hospitalization
  ○ Mortality
  ○ Revascularization
  ○ Angina relief
  ○ Quality of life
  ○ Composite (specify)

XV KQ 4a
- Indicate test modalities compared
- Indicate CAD status of the population
- Data by gender for each category of adverse outcome.
  ○ Average total body radiation exposure (specify units)
  ○ Access site complications
  ○ IV site complications
  ○ Contrast-agent induced nephropathy
  ○ Nephrogenic systemic fibrosis
  ○ Anaphylaxis
  ○ Arrythmias
- If access site complications were reported, describe how these complications were defined.
- Does the article report tissue-level radiation data?
- Describe tissue-level radiation findings

XVI KQ 4b
- Does the article report harms data broken down by any demographic factors other than gender? (Gender data is to be captured in form KQ 4a.)
- Indicate test modalities compared
- Indicate CAD status of the population
- Specify the categories for this subgroup analysis. Columns are provided to capture up to 5 categories. Complete only the number needed to capture the data presented in the study. Define the categories, then complete the tables below with as much information as is provided in the study.
- Harms
  ○ Average total body radiation exposure (specify units)
  ○ Access site complications
  ○ IV site complications
  ○ Contrast-agent induced nephropathy
  ○ Nephrogenic systemic fibrosis
  ○ Anaphylaxis
  ○ Arrythmias
- If access site complications were reported, describe how these complications were defined.
- Does the article report tissue-level radiation data?
- Describe tissue-level radiation findings

XVII Quality Assessment
- QUADAS Tool for Quality Assessment of Studies of Diagnostic Accuracy
- Answer each of the 14 questions below. A user’s guide explaining each question and how to score your responses is available in the 2003 QUADAS article here: http://www.biomedcentral.com/1471-2288/3/25
  1. Was the spectrum of patients representative of the patients who will receive the test in practice?
  2. Were selection criteria clearly described?
  3. Is the reference standard likely to correctly classify the target condition?
  4. Is the time period between reference standard and index test short enough to be reasonably sure that the target condition did not change between the two tests?
  5. Did the whole sample or a random selection of the sample, receive verification using a reference standard of diagnosis?
  6. Did patients receive the same reference standard regardless of the index test result?
  7. Was the reference standard independent of the index test (i.e. the index test did not form part of the reference standard)?
  8. Was the execution of the index test described in sufficient detail to permit replication of the test?
  9. Was the execution of the reference standard described in sufficient detail to permit its replication?
  10. Were the index test results interpreted without knowledge of the results of the reference standard?
  11. Were the reference standard results interpreted without knowledge of the results of the index test?
  12. Were the same clinical data available when test results were interpreted as would be available when the test is used in practice?
  13. Were uninterpretable/intermediate test results reported?
  14. Were withdrawals from the study explained?
- Summary Judgment
  ○ Good (low risk of bias). No major features that risk biased results. RCTs are considered a high study design type, but studies that include consecutive patients representative of the intended sample for whom diagnostic uncertainty exists may also meet this standard. A “good” study avoids the multiple biases to which medical test studies are subject (e.g., use of an inadequate reference standard, verification bias), and key study features are clearly described, including the comparison groups, measurement of outcomes, and the characteristics of patients who failed to have actual state (diagnosis or prognosis) verified.
  ○ Fair. Susceptible to some bias, but flaws not sufficient to invalidate the results. The study does not meet all the criteria required for a rating of good quality, but no flaw is likely to cause major bias. The study may be missing information, making it difficult to assess limitations and potential problems.
  ○ Poor (high risk of bias). Significant flaws that imply biases of various types that may invalidate the results. The study has significant biases determined a priori to be major or “fatal” (i.e., likely to make the results either uninterpretable or invalid).
- If the study is rated as “Fair” or “Poor,” provide rationale for decision.

XVIII Applicability Assessment
- Use the PICOTS format to identify specific issues that may limit the applicability of the study as described in the draft Methods Guide for Medical Test Reviews. Indicate the most important limitations affecting applicability, if any, from the list below.
- Population (P)
  ○ Source of population not described
  ○ Study population poorly specified
  ○ Key characteristics not reported
- Intervention (I)
  ○ Version/instrumentation not specified
  ○ Training/quality control not described
  ○ Screening and diagnostic uses mixed
- Comparator (C)
  ○ Gold standard not applied
  ○ Correlational data only
- Outcome of use of the test (O)
  ○ Failure to test “normals” or subset with gold standard
  ○ Precision of estimates not provided
- Clinical outcomes from test results (O)
  ○ Populations and study designs heterogeneous with varied findings
  ○ Data not stratified or adjusted for key predictors
- Timing (T)
  ○ Sequence of use of other diagnostics unclear
  ○ Time from results to treatment not reported
  ○ Order of testing varies across subjects and was not randomly assigned
- Setting (S)
  ○ Resources available to providers for diagnosis and treatment of condition vary widely
  ○ Provider type/specialty varies across settings
  ○ Comparability of care in international settings unclear