# Abbreviations

ACC: American College of Cardiology
AHA: American Heart Association
AV: atrioventricular
CABG: coronary artery bypass grafting
CAD: coronary artery disease
CMR: cardiac magnetic resonance imaging
CT: computed tomography
CTA: coronary computed tomography angiography
ECHO: echocardiography/echocardiogram
ECG: electrocardiography/electrocardiogram
KQ: Key Question
LBBB: left bundle branch block
LV: left ventricle
LVH: left ventricular hypertrophy
MI: myocardial infarction
MIBI: methoxyisobutyl
MPS: myocardial perfusion scintigraphy
NA: not applicable
NIT: noninvasive technology
NR: not reported
PET: positron emission tomography
PVC: premature ventricular contractions
SPECT: single proton emission computed tomography
SVT: supraventricular tachycardia
VT: ventricular tachycardia