# Key Informants and Technical Expert Panel^*^ * These Key Informants also comprised the Technical Expert Panel.

Francine Kaufman, M.D.

Children’s Hospital of Los Angeles

Los Angeles, CA

Wanda Nicholson, M.D., M.P.H., M.B.A.

University of North Carolina

Chapel Hill, NC

Robert Ratner, M.D.

Medstar Health Research Institute

Washington, DC