# Results

## Search Results

Figure 2 summarizes the search results. From our search, we retrieved 7,002 unique records. After title and abstract review, we decided 741 articles were potentially relevant to review, and retrieved the full articles (see Appendix D for the list of studies excluded). We included a total of 41 studies (in 44 publications) in this review.

Figure 2 Summary of the literature search

CENTRAL = Central Register of Controlled Trials; CSII = continuous subcutaneous insulin infusion; hrs = hours; MDI = multiple daily injections; rt-CGM = real-time continuous glucose monitor; SMBG = self-monitoring of blood glucose

^*^Total may exceed number in corresponding box, as articles could be excluded for more than one reason at this level.

^†^41 studies in 44 publications: 28 compared CSII with MDI (9 in children and adolescents with type 1 diabetes; 9 in adults with type 1 diabetes; 4 (5 publications) in adults with type 2 diabetes; 6 in pregnant women with pre-existing type 1diabetes); 9 (10 publications) compared rt-CGM with SMBG; 4 (5 publications) compared a sensor-augmented pump with MDI/SMBG

Figure 2 summarizes the literature search. We searched PubMed, Cochrane, and EMBASE, retrieving 10958 articles, 3956 of which were duplicates. We then reviewed 7002 titles, excluding 3238, which left 3764 for the abstract review. 3023 articles were excluded at the abstract review, and 741 were reviewed at the full article level. We excluded 697 at the article review level, including a total of 44 publications. To the left of the review flow chart are the reasons for exclusion at abstract level and at article level. The reasons for exclusion at the abstract review level are: no original data, nor formal diagnosis of diabetes, does not evaluate CSII or rt-CGM, does not compare placebo or usual care, usage of time of device less than 24 hours, not in an outpatient setting, case series of case reports or cross sectional, no human subjects, does not apply to a key question, and other. The reasons for exclusion at the article review level are the same as abstract, with the addition of regular insulin used in pump and observational study that does not evaluate a microvascular, macrovascular, maternal, or fetal outcome.

Of the included studies, 28 studies compared the effects of continuous subcutaneous insulin infusion (CSII) with multiple daily injections (MDI). Nine of these studies were conducted in children or adolescents with type 1 diabetes, nine were conducted among adults with type 1 diabetes, four (in five publications) were conducted among adults with type 2 diabetes, and six were conducted among pregnant women with pre-existing type 1 or type 2 diabetes.

Nine studies (in 10 publications) compared the effects of real-time continuous glucose monitoring (rt-CGM) with self-monitoring of blood glucose (SMBG) in children and adults with type 1 diabetes. We did not identify any studies comparing rt-CGM with SMBG among patients with type 2 diabetes or among pregnant women with pre-existing type 1 or type 2 diabetes.

An additional four studies (in five publications) evaluated the effects of a sensor-augmented pump compared with MDI and SMBG.

We did not find any studies that reported on microvascular outcomes, macrovascular outcomes, and most process measures.

Eighteen studies evaluated health-related quality of life (QOL) using 15 different validated QOL assessment tools. Table 3 lists how the QOL assessment tools were categorized into general QOL, disease-specific QOL, and treatment-specific QOL.

Table 3 Health-related quality of life assessment tools used in each category

Domain | Instrument | Range of Total Scores (High Scores Indication)
General health-related QOL | Pediatric QOL Inventory | 0 – 100 (better QOL)
General health-related QOL | Short Form-36 (SF-36) | 0 – 100 (higher level of health)
General health-related QOL | Short Form-12 (SF-12) | 0 – 100 (higher level of health)
General health-related QOL | World Health Organization-5 Well Being Index (WHO-5) | 0 – 100 (better well-being)
Diabetes-specific QOL | Diabetes QOL | 0 – 100 (better QOL)
Diabetes-specific QOL | Diabetes QOL Clinical Trial Questionnaire | 0 – 100 (higher satisfaction)
Diabetes-specific QOL | Diabetes QOL – Youth | 0 – 100 (better QOL)
Diabetes-specific QOL | Problem Areas in Diabetes | 0 – 100 (more serious problem)
Treatment-related QOL | Altered Hypoglycemia Awareness Questionnaire | 0 – 7 (altered hypoglycemia)
Treatment-related QOL | Blood Glucose Monitoring System Rating Questionnaire | 0 – 100 (higher satisfaction)
Treatment-related QOL | Diabetes Treatment Satisfaction Questionnaire | 0 – 36 (higher satisfaction)
Treatment-related QOL | Hypoglycemia Fear Survey | 0 – 92 (higher level of fear)
Treatment-related QOL | Insulin Delivery System Rating Questionnaire | 0 – 100 (higher satisfaction)
Treatment-related QOL | Phase V Outcomes system diabetes treatment satisfaction questionnaire | 0 – 100 (higher satisfaction)
Treatment-related QOL | User Acceptance Questionnaire | 0 – 100 (more positive ratings (with exception of “problems” section))

QOL = quality of life

## Key Question 1 In patients receiving intensive insulin therapy, does mode of delivery (CSII vs. MDI) have a differential effect on process measures, intermediate outcomes, and clinical outcomes in patients with diabetes mellitus?

### Comparative Effectiveness of CSII Versus MDI in Children and Adolescents With Type 1 Diabetes

#### Key Points and Evidence Grades

- The strength of the evidence was moderate comparing CSII with MDI for the outcome of HbA_1c_. Mean between-group difference in how HbA_1c_ changed from baseline was -0.14 percent, decreasing slightly more with CSII than with MDI (95% confidence interval [CI], -0.48 to 0.20, P=0.41). Results were similar among adolescents over 12 years old (mean between-group difference in the change from baseline HbA_1c_, -0.10 percent; 95% CI, -0.47 to 0.27) and were less different among children less than 12 years old (mean between-group difference in the change from baseline HbA_1c_, -0.05 percent; 95% CI, -1.01 to 0.96).
- There was low strength of evidence to suggest no significant difference in daytime hypoglycemia frequency between MDI and CSII intervention groups (mean between-group difference in perceived hypoglycemic events over 104 weeks, 0; 95% CI, -1.1 to 1.1;^48^ mean between-group difference in the change from baseline to 24 weeks in the number of blood glucose excursions below 70 mg/dL, -0.9; 95% CI, -2.1 to 0.3;^49^ mean between-group difference in number of hypoglycemic episodes/patient at 52 weeks, -3.7; 95% CI, -13.2 to 5.8).50
- There was low strength of evidence to suggest no significant difference in nocturnal hypoglycemia between the MDI and CSII intervention groups. In one study, there were four events/patient/study period (95% CI, 0.3 to 7.7) for MDI versus three events/patient/study period (95% CI, 1.0 to 5.0) over 52 weeks.50 In the other study, there were two patients with one or more events in the CSII arm but no events reported in the MDI arm over 16 weeks.51
- The strength of the evidence comparing CSII with MDI was insufficient for mild hypoglycemia. One study found no significant difference in mild hypoglycemia (events with blood sugar less than 70 mg/dL) between the MDI (22 events/patient) and CSII (19.8 events/patient) intervention groups over 14 weeks.52
- The strength of evidence was low indicating similar rates of severe hypoglycemia between the two intervention arms. The mean incidence rate ratio for severe hypoglycemic event rates in randomized controlled trials (RCTs) for CSII versus MDI was 0.99 (95% CI, 0.57 to 1.71, P=0.97). Results were similar among adolescents over 12 years of age (mean incidence rate ratio for CSII versus MDI, 0.95; 95% CI, 0.42 to 2.13) and children less than 12 years of age (mean incidence rate ratio for CSII versus MDI, 1.02; 95% CI, 0.49 to 2.16).
- The strength of evidence comparing CSII with MDI was insufficient for hyperglycemia. One study found no difference in the frequency of hyperglycemia between the MDI (6.7 events) and CSII (7.9 events) intervention groups over 14 weeks.52
- The strength of evidence comparing CSII with MDI was insufficient for the ratio of basal to bolus insulin. One study reported no difference in the ratio of basal to bolus insulin between the MDI and CSII (mean between-group difference, 1.7; 95% CI, -2.5 to 5.9) intervention groups.53
- The strength of evidence was low comparing CSII with MDI for weight change. The mean between-group difference in how body mass index (BMI) standard deviation score changed from baseline was -0.12 units, decreasing slightly more with CSII than MDI (95% CI, -0.55 to 0.30 units).
- The strength of evidence was low comparing CSII with MDI for general QOL. Two studies49 54 used the Pediatric Quality of Life Inventory. A meta-analysis of these studies did not favor CSII or MDI in this population (mean between-group difference, 2.3; 95% CI, -6.9 to 11.5; P=0.95).
- The strength of evidence was low comparing CSII with MDI for diabetes-specific QOL. Three studies used the Diabetes Treatment Satisfaction Questionnaire and showed improvement in diabetes treatment satisfaction favoring CSII.48 50 52 A meta-analysis of two of these studies favored CSII over MDI (mean between-group difference in the Diabetes Treatment Satisfaction Questionnaire, 5.7; 95% CI, 5.0 to 6.4; P<0.001). One study showed improvement in diabetes-specific QOL favoring CSII (Diabetes Quality of Life-Youth baseline score 77.4 [95% CI, 69.5 to 85.3] and end of study 76.4 [95% CI, 68.3 to 84.5] for MDI and 82.7 [95% CI, 75.3 to 90.1] for CSII).50 One study did not find a difference in the Diabetes Quality of Life-Youth scores between the two interventions (numerical data not presented).51
- There was insufficient evidence comparing CSII with MDI for certain process measures (frequency of adjusting insulin therapy, adherence, health visits) and clinical outcomes (microvascular and macrovascular disease and mortality) as no studies addressed these.

#### Study Design

Nine studies evaluated CSII versus MDI therapy in children and adolescents with type 1 diabetes (Appendix E, Table 1).48-56 They were conducted in diverse countries, including the U.S.,49 51 Italy,55 Sweden,48 Spain,53 Saudi Arabia,56 the Netherlands,55 57 and Israel.50 52 Studies varied in their sources of support—four received industry support,48 50-52 four received government support,48 51 53 54 and four received other sources of support.48-50 54 Sources of support were not reported for two studies.55 56

Of the nine studies, four were parallel arm RCTs,48 49 51 55 three were randomized crossover trials,50 52 54 and two were non-randomized trials.53 56 Three studies included a run-in period,51 52 54 three did not,48 50 55 and three studies did not report a run-in period.49 53 56 Enrollment into three studies started and ended after 2000,^48^ 49 56 but most studies did not report the dates of enrollment period.50-55 The median followup time for all studies was 52 weeks, with a range of 16 to 104 weeks. One study did not report followup duration.53 These studies screened 24,^52^ 36,^55^ and 200^53^ patients and enrolled a median of 32 patients (range 16 to 72) into randomized clinical trials. Most studies did not report the number of patients screened.48-51 54 56 Seven studies recruited patients from referral clinics.49-51 54-56

The majority of studies excluded pregnant patients.48-51 53-56 Some studies excluded patients based on HbA_1c_ less than 6.5 percent,51 7.5 percent,53 or 8 percent,54 55 or greater than 11 percent.51 Certain studies excluded patients if they were being treated with insulin for less than 1 year54 or less than 2 years,52 were using glargine insulin,51 were not currently treated with intensive insulin therapy,50 53 or had ever used insulin pump therapy.51

#### Population Characteristics

The mean age of participants in the randomized controlled trials was 16.5 years (range 4.4 to 18.9 years) and 11.4 years (range 4.4 to 17.9 years) in the MDI and CSII groups, respectively (see Appendix E, Table 2). One study did not report the ages of the participants.51 Males were 50 percent and 38 percent of the study populations, respectively, for the MDI and CSII groups. The majority of studies did not report the racial composition of their study populations.48 50 52 53 55 56 The majority of studies included Caucasian participants and one study reported a very small number of African American and Hispanic participants.51

Glycemic control was sub-optimal in participants at the time of study enrollment. The mean HbA_1c_ was 8.5 percent and 8.6 percent in the MDI and CSII groups, respectively. In the one study that reported baseline BMI, the means in the MDI and CSII groups were 15.9 kg/m^249^ and 20.9 kg/m^249^ and 19.8 kg/m^2^, respectively.57 Weight and/or BMI was reported as BMI standard deviation scores in two studies50 53 and were not reported in one study.56

#### Interventions

The MDI arms varied across studies in the type of insulin used: neutral protamine Hagedorn (NPH) and aspart,48 NPH and lispro,49 NPH and regular insulin,50 glargine and regular insulin,52 55 glargine and lispro,53 56 and glargine and aspart (see Appendix E, Table 3).51 One study specified the short-acting insulin used in the MDI arm but not the basal insulin.54 The MDI schedule was three injections daily in three studies,49 53 54 and four or more times daily in six studies.48 50-52 55 56

Three studies used insulin aspart in the CSII arm48 51 54 and six studies used insulin lispro in the CSII arm.49 50 52 53 55 56 In terms of insulin pumps, three studies used the DR HTron v100,^48^ 53 54 one used the Tayco Disetronic,50 one used the Animas,49 three used the MiniMed 508,^51^ 52 56 and one used the Medtronic MiniMed Paradigm 511 insulin pump.51 One study did not specify the type of insulin pump used.55 Three studies included training in insulin pump use prior to its initiation.48 49 52

Three studies monitored blood glucose using SMBG51 52 54 and one study monitored blood glucose using rt-CGM.49 Five studies did not report how blood glucose was monitored.48 50 53 55 56 The duration of therapy in each intervention arm ranged from 3.5 to 24 months with six studies having 12 or more months of followup.48 50 53-56 Five studies provided guidelines for insulin dose titration in the intervention arms,49 51-54 and one study provided insulin dose titration instructions only for the CSII arm.55 Only three studies reported their glycemic targets (preprandial glucose of 70 to 140 mg/dL and 2-hour postprandial glucose <180 mg/dL;53 HbA_1c_ of 7 percent, preprandial glucose of 70 to 120 mg/dL and bedtime glucose of 90 to 150 mg/dL;51 and preprandial glucose of 79.2 to 149.4 mg/dL).52

#### Outcomes

Details of the outcomes are reported in Appendix E, Table 4. We found studies evaluating HbA_1c_, hypoglycemia (daytime, nocturnal, and mild), severe hypoglycemia, hyperglycemia, ratio of basal to bolus insulin, weight, general QOL, and diabetes-specific QOL. We did not find any studies evaluating the effects on mortality, microvascular disease, macrovascular disease, frequency of adjusting insulin therapy, adherence, or health visits.

##### HbA_1c_

Nine studies examined the comparative effectiveness of CSII and MDI on HbA_1c_. Three studies showed a significant reduction in HbA_1c_ favoring CSII.51 55 56 The remaining studies showed no difference in the change in HbA_1c_ between the CSII and MDI groups.48-50 52-54

A meta-analysis of seven RCTs showed no significant difference between the MDI and CSII intervention groups in how the HbA_1c_ changed from baseline after 16 or more weeks of followup; HbA_1c_ decreasing slightly more with CSII than with MDI (combined mean between-group difference, -0.14; 95% CI, -0.48 to 0.20, P=0.41) (see Figure 3). We did not find evidence of statistical heterogeneity and none of the studies influenced results substantially. Egger's test (P=0.21) and funnel plot did not suggest publication bias.

Figure 3 Between-group difference between CSII and MDI in how HbA_1c_ changed from baseline among children with type I diabetes

CI = confidence interval; CSII = continuous subcutaneous insulin infusion; HbA_1c_ = hemoglobin A_1c_; MDI = multiple daily injections

Boxes indicate individual study point estimates. The box size denotes the weight of the study, with larger boxes contributing more to the pooled estimate. The width of the horizontal lines represents the 95% confidence intervals for each study. The diamond at the bottom of the graph indicates the 95% confidence interval for the random-effects pooled estimate.

Test for heterogeneity: Q = 4.32 with 6 degrees of freedom (p = 0.63)

Figure 3 is a forest plot type of diagram summarizing the between-group differences between MDI and CSII in how HbA1c changed from baseline among children and adolescents with type 1 diabetes. Seven RCTs (which are Weintrob 2003, Cohen 2003, Doyle 2004, Schiaffini 2007, Opipari-Arrigan 2007, Skogsberg 2008, and Nuboer 2008) are displayed and show a non significant difference between the MDI and CSII intervention groups in how the HbA1c changed from baseline, decreasing slightly more with CSII than with MDI, as the combined mean between-group difference was -0.14 with a 95% conficence interval of -0.48 to 0.20 and p value of 0.634. All but Weintrob 2003 favor CSII and Skosberg 2008 is at 0.

##### Studies in Children 12 Years of Age or Younger

Two studies focused primarily on the comparative effectiveness of MDI and CSII in children whose mean age was 12 years or younger based on age at diagnosis and diabetes duration.48 49 One study showed a nonsignificant reduction in HbA_1c_ favoring CSII49 while the other study found no difference in HbA_1c_ between the two groups.48 A meta-analysis of these two studies showed no significant difference in the change from baseline HbA_1c_ between the MDI and CSII intervention groups (combined mean between-group difference in the change from baseline HbA_1c_, -0.05 percent; 95% CI, -1.01 to 0.96 percent) (see Figure 4). There was no evidence of statistical heterogeneity, and none of the studies influenced the results substantially. There were too few studies to assess for publication bias.

Figure 4 Between-group difference between CSII and MDI in how HbA_1c_ changed from baseline among children 12 years of age or less with type 1 diabetes

CI = confidence interval; CSII = continuous subcutaneous insulin infusion; HbA_1c_ = hemoglobin A_1c_; MDI = multiple daily injections

Boxes indicate individual study point estimates. The box size denotes the weight of the study, with larger boxes contributing more to the pooled estimate. The width of the horizontal lines represents the 95% confidence intervals for each study. The diamond at the bottom of the graph indicates the 95% confidence interval for the random-effects pooled estimate.

Test for heterogeneity: Q = 0.01 with 1 degree of freedom (p = 0.90)

Figure 4 is a forest plot type of diagram summarizing the between-group differences between MDI and CSII in how HbA1c changed from baseline among young children with type 1 diabetes. Two RCTs are displayed, which are Opipari-Arrigan 2007 and Skogsberg 2008. Overall, there is a non significant difference between the MDI and CSII intervention groups in how the HbA1c changed from baseline, decreasing slightly more with CSII than with MDI, as the combined mean between-group difference was -0.05 with a 95% conficence interval of -1.05 to 0.96 and p value of 0.904. Both slightly favor CSII.

##### Studies in Adolescents (Older Than 12 Years of Age)

Four studies focused on the comparative effectiveness of MDI and CSII in adolescents whose mean age was over 12 years based on age at diagnosis and diabetes duration. In those studies, three showed no significant reduction in HbA_1c_ favoring CSII50 54 55 while one study found no significant reduction in HbA_1c_ favoring MDI.52 A meta-analysis of these studies showed no significant difference in the change from baseline HbA_1c_ between the MDI and CSII intervention groups favoring CSII (combined mean between-group difference in the change from baseline HbA_1c_, -0.10 percent; 95% CI, -0.48 to 0.27 percent) (see Figure 5). We did not find evidence of statistical heterogeneity and none of the studies influenced results substantially. There were too few studies to adequately assess for publication bias, although the funnel plot suggested publication of more studies favoring CSII. One study did not report the age of participants.51

Figure 5 Between-group difference between CSII and MDI in how HbA_1c_ changed from baseline among adolescents with type 1 diabetes

CI = confidence interval; CSII = continuous subcutaneous insulin infusion; HbA_1c_ = hemoglobin A_1c_; MDI = multiple daily injections

Boxes indicate individual study point estimates. The box size denotes the weight of the study, with larger boxes contributing more to the pooled estimate. The width of the horizontal lines represents the 95% confidence intervals for each study. The diamond at the bottom of the graph indicates the 95% confidence interval for the random-effects pooled estimate.

Test for heterogeneity: Q = 3.32 with 3 degrees of freedom (p = 0.35)

Figure 5 is a forest plot type of diagram summarizing the between group difference between MDI and CSII in how HbA1c changed from baseline among adolescents with type 1 diabetes. In the four included RCTs, which are Cohen 2003, Weintrob 2003, Schiaffini 2007, and Nuboer 2008, there was a non-significant difference in the change from baseline HbA1c between the MDI and CSII intervention groups favoring CSII. The combined mean between-group difference in the change from baseline HbA1c is -0.10% with a 95% confidence interval of -0.48 to 0.27 and a p value of 0.345 and I-squared value of 9.6%. All but Weintrob 2003 favor CSII.

##### Daytime And Nocturnal Hypoglycemia

Three studies examined the comparative effectiveness of CSII and MDI on daytime hypoglycemia. The studies defined participants as being hypoglycemic if they had perceived hypoglycemia,48 average blood sugar excursions/day below 70 mg/dL,49 and mean number of hypoglycemia episodes/patient/study period.50 One study did not specify the timeframe for units of measures.48 There was no significant difference in daytime hypoglycemia frequency between the two groups.48-50 Two studies examined the comparative effectiveness of CSII and MDI on nocturnal hypoglycemia and found no significant differences between the two groups.50 51

##### Mild Hypoglycemia

One study examined the frequency of mild hypoglycemia (defined as blood sugar below 70 mg/dL) in the MDI and CSII interventions groups52 and found no significant difference between the CSII group (19.8 events/patient) compared with the MDI group (22 events/patient).52

##### Severe Hypoglycemia

Six studies examined the frequency of severe hypoglycemia in the MDI and CSII intervention groups. The definitions of hypoglycemia used in studies varied (see Table 4). While one study found a significantly lower frequency of severe hypoglycemia in the CSII group compared with the MDI group,52 five studies found no difference in frequency between the two groups.49-51 53 55

Table 4 Definitions of severe hypoglycemia in the studies of children and adolescents with type 1 diabetes

Author, Year | Severe Hypoglycemia Definition
Opipari-Arrigan, 2007^49^ | Seizure, obtundation, or combativeness preventing administration of oral glucose in association with a capillary blood glucose of less than 100 mg/dL
Schiaffini, 2007^55^ | Hypoglycemic event requiring assistance from another person, infusion of glucose or resulting in severe symptoms, such as seizure or coma
Garcia-Garcia, 2007^53^ | Hypoglycemia requiring parental treatment
Doyle, 2004^51^ | Event resulting in coma or seizure
Cohen, 2003^50^ | Not explicitly defined
Weintrob, 2003^52^ | Event requiring assistance from another person or resulting in a seizure/coma

mg/dL – milligrams per deciliter

A meta-analysis of five RCTs did not find a significant difference in severe hypoglycemia event rates between the two intervention arms (combined mean incidence rate ratio for CSII vs. MDI, 0.99; 95% CI, 0.57 to 1.71, P=0.97) (see Figure 6). We did not find evidence of statistical heterogeneity and none of the studies influenced results substantially. Egger's test (P=0.04) and the funnel plot suggested publication bias of studies showing a benefit of CSII. One randomized clinical trial was not included in the meta-analysis because it did not report severe hypoglycemia event rates for the CSII group.51

Figure 6 Incident rate ratios for severe hypoglycemia in CSII versus MDI interventions among children and adolescents with type 1 diabetes

CI = confidence interval; CSII = continuous subcutaneous insulin infusion; IRR = incidence rate ratio; MDI = multiple daily injections

Boxes indicate individual study point estimates. The box size denotes the weight of the study, with larger boxes contributing more to the pooled estimate. The width of the horizontal lines represents the 95% confidence intervals for each study. The diamond at the bottom of the graph indicates the 95% confidence interval for the random-effects pooled estimate.

Test for heterogeneity: Q = 4.28 with 4 degrees of freedom (p = 0.37)

Figure 6 is a forest plot type diagram summarizing the incident rate ratios for severe hypoglycemia in MDI versus CSII interventions among children and adolescents. The meta-analysis of the five RCTs (which were Cohen 2003, Weintrob 2003, Opipari-Arrigan 2007, Schiaffini 2007, and Skogsberg 2008) did not find a significant difference in severe hypoglycemia event rates between the two intervention arms. The combined mean incident rate ratio for CSII versus MDI was 0.99 with a 95% confidence interval of 0.57 to 1.71 and a p value of 0.37 and I-squared value of 6.5%. Cohen 2003, Weintrob 2003, and Opipari-Arrigan 2007 favor CSII while Schiaffini 2007 and Skogsberg 2008 favor MDI.

##### Studies in Children 12 Years of Age or Less

In the two RCTs of young children, one study showed a lower rate of severe hypoglycemia favoring CSII that was not significant,49 while the other study showed a lower rate of severe hypoglycemia favoring MDI that was also not significant.48 A meta-analysis of these two studies did not show a significant difference in the severe hypoglycemia event rates between the two intervention arms (combined mean incidence rate ratio for CSII versus MDI, 1.02; 95% CI, 0.49 to 2.16) (See Figure 7). We did not find evidence of statistical heterogeneity and none of the studies influenced results substantially. There were too few studies to adequately assess publication bias.

Figure 7 Incident rate ratios for severe hypoglycemia in CSII versus MDI interventions among children 12 years of age or less with type 1 diabetes

CI = confidence interval; CSII = continuous subcutaneous insulin infusion; IRR = incidence rate ratio; MDI = multiple daily injections

Boxes indicate individual study point estimates. The box size denotes the weight of the study, with larger boxes contributing more to the pooled estimate. The width of the horizontal lines represents the 95% confidence intervals for each study. The diamond at the bottom of the graph indicates the 95% confidence interval for the random-effects pooled estimate.

Test for heterogeneity: Q = 0.80 with 1 degree of freedom (p = 0.37)

Figure 7 is a forest plot type diagram summarizing the incident rate ratios for severe hypoglycemia in MDI versus CSII interventions among children and adolescents with type 1 diabetes. The two results displayed are Opipari-Arrigan 2007 and Skogsberg 2008. Opipari-Arrigan 2007 favors CSII for an incident rate ratio for severe hypoglycemia in events per person-year, whild Skogsberg 2008 favors MDI. The overall incident rate ratio is 1.02 with a 95% confidence interval of 0.49 to 2.16, an I-squared of 0% and a p value of 0.370).

##### Studies in Adolescents Older Than 12 Years of Age

Three of the five RCTs were performed in adolescents. Two studies showed a lower rate of severe hypoglycemia favoring CSII that was not significant,50 52 while one study showed a lower event rate favoring MDI that was also not significant.55 A meta-analysis of these three studies did not show a significant difference in the severe hypoglycemia event rates between the two intervention arms (combined mean incidence rate ratio for CSII vs. MDI, 0.95; 95% CI, 0.42 to 2.13) (See Figure 8). We did not find evidence of statistical heterogeneity and none of the studies influenced results substantially. There were too few studies to adequately assess publication bias.

Figure 8 Incident rate ratios for severe hypoglycemia in CSII versus MDI interventions among children with type 1 diabetes

CI = confidence interval; CSII = continuous subcutaneous insulin infusion; IRR = incidence rate ratio; MDI = multiple daily injections

Boxes indicate individual study point estimates. The box size denotes the weight of the study, with larger boxes contributing more to the pooled estimate. The width of the horizontal lines represents the 95% confidence intervals for each study. The diamond at the bottom of the graph indicates the 95% confidence interval for the random-effects pooled estimate.

Test for heterogeneity: Q = 3.45 with 2 degrees of freedom (p = 0.18)

Figure 8 is a forest plot type diagram summarizing the incident rate ratios for severe hypoglycemia in MDI versus CSII interventions among children with type 1 diabetes. Three RCTs were included in the meta-analysis which were Cohen 2003, Weintrob 2003, and Schiaffini 2007 and it did not show a significant difference the severe hypoglycemia event rates between the two intervention arms. The combined mean incidence rate ratio for CSII versus MDI was 0.95 with a 95% confidence interval of 0.42 to 2.13, I-squared of 42.1%, and a p value of 0.178. Cohen 2003 and Weintrob 2003 favored CSII and Schiaffini 2007 favored MDI.

##### Hyperglycemia

One study examined the frequency of hyperglycemia in the MDI and CSII intervention groups over 14 weeks.52 The study defined participants as being hyperglycemic if they had polyuria, polydipsia, or nocturia and/or a capillary blood glucose level of more than 400 mg/dL with or without urinary ketones. While there were more events in the CSII group (7.9) than in the MDI group (6.7), this difference was not statistically significant.

##### Ratio of Basal to Bolus Insulin: Proportion of Basal Insulin

One study examined the ratio of basal to bolus insulin in the MDI and CSII intervention groups and found no difference in the ratios between the two groups.53

##### Weight Gain

Table 5 summarizes three studies that compared CSII with MDI for changes in weight as measured by BMI SDS in children with type 1 diabetes.50-52 BMI SDS is a measure of BMI used in children that indicates how many standard deviations the measurement is above or below the median of the distribution. Two studies were randomized open crossover trials conducted at the same institution.50 52 One found no significant change in BMI-SDS over the course of the study in either treatment arm.50 The other crossover study reported a slight, but statistically significant, increase in BMI-SDS during MDI therapy and no significant change during CSII.52 The third study was an RCT that showed a BMI change from baseline that was not statistically significant and measured less than 1 kg/m^2^ in both groups.51 A meta-analysis of two studies showed a difference that was not significant in the change from baseline BMI SDS between the MDI and CSII intervention groups favoring CSII (combined mean between-group difference in the change from baseline BMI SDS, -0.12; 95% CI, -0.55 to 0.30) (see Figure 9). There was no evidence of statistical heterogeneity and none of the studies influenced the results substantially. There were too few studies to assess for publication bias. We did not include one study in the meta-analysis because there was not sufficient data provided on estimates.51

Table 5 Weight gain in CSII versus MDI interventions among children with type 1 diabetes

Author, Year | MDI, N | CSII, N | Timepoints (Weeks) | BMI-SDS at Start – MDI | BMI-SDS at Start – CSII | BMI-SDS at End - MDI | BMI-SDS at End - CSII | CSII Effect on BMI-SDS Versus MDI | P Value
Cohen, 2003^50^ | 16 | 16 | 24 | 0.20 | 0.30 | 0.25 | 0.23 | No significant change | NS
Weintrob, 2003^52^ | 23 | 23 | 14 | 0.29 | 0.40 | 0.37 | 0.35 | Decrease | 0.01
Doyle 2004^51^ | 16 | 16 | 4 | NA | NA | NA | NA | No significant change | NS

BMI = body mass index; CSII = continuous subcutaneous injections; MDI = multiple daily injections; NA = not applicable; NS = not significant; SDS = standard deviation score

Figure 9 Between-group difference between CSII and MDI in how BMI SDS changed from baseline among children and adolescents with type 1 diabetes

BMI SDS = body mass index standard deviation score; CI = confidence interval; CSII = continuous subcutaneous insulin infusion; MDI = multiple daily injections

Boxes indicate individual study point estimates. The box size denotes the weight of the study, with larger boxes contributing more to the pooled estimate. The width of the horizontal lines represents the 95% confidence intervals for each study. The diamond at the bottom of the graph indicates the 95% confidence interval for the random-effects pooled estimate.

Test for heterogeneity: Q = 0.00 with 1 degree of freedom (p = 0.98)

Figure 9 is a forest plot type diagram summarizing the between-group difference between MDI and CSII in how BMI SDA changed from baseline among children and adolescents with type 1 diabetes. The included RCTs are Cohen 2003 and Weintrob 2003. Both favor CSII, with a combined mean between-group difference of -0.12 with a 95% confidence interval of -0.55 to 0.30, an I-squared value of 0% and p value of 0.984.

##### Quality of Life, Including General, Diabetes-Specific, and Treatment-Related

Six studies examined the comparative effectiveness of CSII versus MDI on general, diabetes-specific, and diabetes treatment-related QOL in children and adolescents with type 1 diabetes (see Table 6). Two studies examined general QOL in children and adolescents with type 1 diabetes using the Pediatric Quality of Life Inventory (scores range from 0 to 100, with higher scores indicating better QOL).49 54 Both of these studies showed improvement in general QOL favoring CSII (see Table 6), but not in a statistically significant fashion. It should be noted that while both of the studies used a similar measure, one of the studies used the Dutch translation of that instrument.54 A meta-analysis of these studies did not favor CSII or MDI in this population (mean between-group difference, 2.3; 95% CI, -6.9 to 11.5) (see Figure 10).

Table 6 Quality of life in CSII versus MDI interventions among children and adolescents with type 1 diabetes

QOL Domain | Author, Year | N by Intervention Group | Comparison | Population | Difference in QOL Between Comparison and Baseline Groups | Group Favored for QOL Measure
Pediatric Quality of Life Inventory^*^ | Nuboer, 2008^54^ | 19 CSII, 19 MDI | CSII vs. MDI with MDI run-in period | 38 children and adolescents (age range 6-16 yr) with type 1 diabetes | After 7 months of followup, PedsQOL difference from baseline to end of randomization was 2.8 (95% CI, -3.1 to 8.7) in CSII vs. 0.4 (95% CI, -7.4 to 8.2) in MDI | CSII
Pediatric Quality of Life Inventory^*^ | Opipari-Arrigan, 2007^49^ | 6 CSII, 8 MDI | CSII vs. MDI | Sixteen children (age range 3.1–5.3 yrs) with type 1 diabetes | After 6 months of followup, PedsQOL (symptom domains) difference from baseline to end of experimental phase was 8 (95% CI, -5.6 to 21.6) in CSII vs. 6.5 (95% CI, -16.4 to 29.4) in MDI | CSII
DQOL-Y^†^ | Doyle, 2004^51^ | 16 CSII, 16 MDI | CSII vs. MDI | 32 children and adolescents with type 1 diabetes (age range 8 –21 yrs) | “There were no differences in DQOL-Y scores between the two groups at baseline or 16 weeks (data not shown)” | Neither
DQOL-Y^†^ | Cohen, 2003^50^ | 16 enrolled; 12 completed the study | CSII vs. MDI (crossover study) | 16 adolescents (range 15-18) with type 1 diabetes for at least 2 years “and no other chronic disease which could interfere with diabetes treatment” | Data for the individual treatment groups was not given. “The Satisfaction score was 77.4 (95% CI, 69.5 to 85.3) at the beginning of the study, 76.4 (95% CI, 68.3 to 84.5) at the end of the MDI arm, and 82.7 (95% CI, 75.3 to 90.1) at the end of the CSII arm (P<0.05)” | CSII
DTSQ^‡^ | Skogsberg, 2008^48^ | 34 CSII, 38 MDI | CSII vs. MDI | 72 children and adolescents (age range 7-17 yrs) with type 1 diabetes | At the end of 24 months, 33.1 (95% CI, 32.8 to 33.4) in CSII vs. 27.5 (95% CI, 26.8 to 28.2) in MDI, P<0.001. | CSII
DTSQ^‡^ | Cohen, 2003^50^ | 16 enrolled; 12 completed the study | CSII vs. MDI (crossover study) | 16 adolescents (age range 15-18 yrs) with type 1 diabetes for at least 2 years “and no other chronic disease which could interfere with diabetes treatment” | Total score was 20.5 (95% CI, 18.7 to 22.3) at the beginning of the study, 21.8 (95% CI, 19.7 to 23.9) at the end of the MDI arm (after 6 months), and 32 (95% CI, 28.3 to 35.7) at the end of the CSII arm (after 6 months) (P<0.05) | CSII
DTSQ^‡^ | Weintrob, 2003^52^ | 23 children | CSII vs. MDI (crossover study) | 23 children (age range 9 to 13 yrs) with type 1 diabetes for at least 2 years, and “ability to cope, with the parents, with treatment” | Total score was 21.4 (95% CI, 20.1 to 22.7) at the beginning of the study, 21.9 (95% CI, 19.7 to 24.1) at the end of the MDI arm (after 3.5 months of treatment), and 30.6 (95% CI, 28.4 to 32.8) at the end of the CSII arm (after 3.5 months of treatment (P<0.001). | CSII

CSII = continuous subcutaneous insulin infusion; CI = confidence interval; DQOL-Y = Diabetes Quality of Life – Youth; DTSQ = Diabetes Treatment Satisfaction Questionnaire; MDI = multiple daily injections; QOL = quality of life; yr = year

* General QOL measure. Total scores from the Pediatric Qualtiy of Life Inventory range from 0 to 100, with higher scores indicating better quality of life.

† Diabetes-specific QOL measure. Total scores from the Diabetes Quality of Life-Youth range from 0 to 100, with higher scores indicating higher satisfaction.

‡ Diabetes treatment-related QOL measure. Total scores from the Diabetes Treatment Satisfaction Questionnaire range from 0 to 36, with higher scores indicating higher satisfaction.

Figure 10 Between-group difference between CSII and MDI in how Pediatric Quality of Life measure changed from baseline among children and adolescents with type 1 diabetes

CI = confidence interval; CSII = continuous subcutaneous insulin infusion; MDI = multiple daily injections

^*^Quality of life is measured in terms of the Pediatric Quality of Life Inventory. Total scores range from 0 to 100, with higher scores indicating better quality of life.

Boxes indicate individual study point estimates. The box size denotes the weight of the study, with larger boxes contributing more to the pooled estimate. The width of the horizontal lines represents the 95% confidence intervals for each study. The diamond at the bottom of the graph indicates the 95% confidence interval for the random-effects pooled estimate.

Test for heterogeneity: Q = 0.00 with 1 degree of freedom (p = 0.95)

Figure 10 is a forest plot type diagram summarizing the between group difference between MDI and CSII in how Pediatric Quality of Life measure changed from baseline among children and adolescents with type 1 diabetes. The included RCTs are Nuboer 2008 and Opipari-Arrigan 2007. Both favor CSII, with the overall mean difference being 2.29 with a 95 percent confidence interval of -6.87 to 11.45, an I-squared value of 0, and a p value of 0.950.

Two studies examined the comparative effectiveness of CSII versus MDI on diabetes-specific QOL.50 51 Two studies used the Diabetes Quality of Life-Youth instrument (scores range from 0 to 100, with higher scores indicating better QOL) and while one showed improvement in QOL favoring CSII,50 the other study did not find a difference in QOL between the two intervention arms.51

Three studies examined the comparative effectiveness of CSII versus MDI on diabetes treatment-related QOL.50 52 58 The three studies that used the Diabetes Treatment Satisfaction Questionnaire (scores range from 0 to 36, with higher scores indicating greater satisfaction) showed an improvement in diabetes-specific QOL favoring CSII.50 52 58 A meta-analysis of two studies favored CSII over MDI (mean between-group difference, 5.7; 95% CI, 5.0 to 6.4; P<0.001). However, the variation in the effect due to heterogeneity was significant, with an I^2^ of 64% (see Figure 11). We did not include one study in the meta-analysis because it did not present the baseline values by intervention group.50 However, in that study the mean between-group difference in the final scores likewise favored CSII (10.2; 95% CI, 4.0 to 16.4).

Figure 11 Between-group difference between CSII and MDI in how Diabetes Treatment Satisfaction Questionnaire changed from baseline among children and adolescents with type 1 diabetes

CI = confidence interval; CSII = continuous subcutaneous insulin infusion; MDI = multiple daily injections

^*^Quality of life is measured in terms of the Diabetes Treatment Satisfaction Questionnaire, which is an 8-item questionnaire. The total score ranges from 6 to 36. Higher scores indicate greater satisfaction.

Boxes indicate individual study point estimates. The box size denotes the weight of the study, with larger boxes contributing more to the pooled estimate. The width of the horizontal lines represents the 95% confidence intervals for each study. The diamond at the bottom of the graph indicates the 95% confidence interval for the random-effects pooled estimate.

Test for heterogeneity: Q = 4.85 with 2 degrees of freedom (p = 0.09)

Figure 11 is a forest plot type diagram summarizing the between group difference between MDI and CSII in how Diabetes Treatment Satisfaction Questionnaire changed from baseline among children and adolescents with type 1 diabetes. Two RCTs are included in the analysis, which are Skogsberg 2008 and Weintrob 2003. Both favor CSII, with an overall mean difference of 5.72 and a 95 percent confidence interval of 5.03 to 6.41, an I-squared value of 64.9 percent, and a p value of 0.092.

#### Study Quality

Among the RCTs on children and adolescents, one study was good quality,51 three studies were fair quality,48 52 54 and three studies were poor quality (see Appendix E, Table 5).49 50 55 A lack of reporting on most quality items limited our assessment of the risk of bias. Only one study, which was rated as good quality, reported on sequence generation.51

Among the non-randomized trials, one was fair quality53 and one was fair or poor quality (see Appendix E, Table 6).56 Studies had incomplete53 or no56 description of the study setting or population and only described some key characteristics that affected outcomes. One study did not describe inclusion and exclusion criteria and it was unclear if the study derived patients in the two groups from the same population.56 All but one study56 performed adjusted or stratified analyses.

#### Strength of Evidence

The strength of evidence examining the comparative effectiveness of CSII versus MDI was moderate for HbA_1c_, and low for daytime and nocturnal hypoglycemia, severe hypoglycemia, weight gain, and general and disease-specific quality of life due to the small number of studies addressing these outcomes (see Table 7). Because only one study addressed the outcomes of mild hypoglycemia, hyperglycemia, and ratio of basal to bolus insulin, there was insufficient data to determine strength of evidence for these outcomes. The magnitude of effect of the interventions on HbA_1c_ outcome was small and there was no effect on hyperglycemia, severe hypoglycemia, daytime, nocturnal, and mild hypoglycemia, ratio of basal to bolus insulin, or weight gain. Risk of bias was medium for the outcomes of HbA_1c_, severe hypoglycemia, daytime and nocturnal hypoglycemia, and weight gain and high for mild hypoglycemia, hyperglycemia, and ratio of basal to bolus insulin.

Table 7 Numbers of studies and subjects, strength of evidence domains, magnitude of effect, and overall strength of evidence for CSII versus MDI in children and adolescents with type 1 diabetes

Outcome | Number of Studies (Participants) | Domains Pertaining to Strength of Evidence | | | | | Magnitude of Effect and Strength of Evidence
Outcome | Number of Studies (Participants) | Risk of Bias: Design/ Quality | Consistency | Directness | Precision | Publication Bias | Magnitude of Effect and Strength of Evidence
Mortality | 0 | NA | NA | NA | NA | NA | Strength of evidence: Insufficient
Microvascular outcomes | 0 | NA | NA | NA | NA | NA | Strength of evidence: Insufficient
Macrovascular outcomes | 0 | NA | NA | NA | NA | NA | Strength of evidence: Insufficient
HbA_1c_ | 9 (260) | Medium | Consistent | Direct | Precise | No | Magnitude of effect: Small Strength of evidence: Moderate
Hyperglycemia | 1 (23) | High | Unknown | Direct | Imprecise | Uncertain | Magnitude of effect: No effect Strength of evidence: Insufficient
Severe hypoglycemia | 6 (152) | Medium | Consistent | Direct | Imprecise | Yes | Magnitude of effect: No effect Strength of evidence: Low
Daytime hypoglycemia | 3 (122) | Medium | Consistent | Direct | Imprecise | Uncertain | Magnitude of effect: No effect Strength of evidence: Low
Nocturnal hypoglycemia | 2 (64) | Medium | Consistent | Direct | Imprecise | Uncertain | Magnitude of effect: No effect Strength of evidence: Low
Mild hypoglycemia | 1 (23) | High | Unknown | Direct | Imprecise | Uncertain | Magnitude of effect: No effect Strength of evidence: Insufficient
Ratio of basal to bolus insulin | 1 (32) | High | Unknown | Direct | Imprecise | Uncertain | Magnitude of effect: No effect Strength of evidence: Insufficient
Frequency of adjusting insulin therapy | 0 | NA | NA | NA | NA | NA | Strength of evidence: Insufficient
Adherence to insulin therapy | 0 | NA | NA | NA | NA | NA | Strength of evidence: Insufficient
Frequency of professional or allied health visits | 0 | NA | NA | NA | NA | NA | Strength of evidence: Insufficient
Weight gain | 3 (110) | Medium | Consistent | Direct | Imprecise | Uncertain | Magnitude of effect: No effect Strength of evidence: Low
General QOL | 2 (52) | Medium | Consistent | Direct | Imprecise | Uncertain | Magnitude of effect: Small Strength of evidence: Low
Diabetes-specific QOL | 2 (44) | Medium | Inconsistent | Direct | Imprecise | Uncertain | Magnitude of effect: Small Strength of evidence: Low
Treatment-specific QOL | 3 (107) | Medium | Inconsistent | Direct | Precise | Uncertain | Magnitude of effect: Small Strength of evidence: Low

HbA_1c_ = hemoglobin A_1c_; NA = not applicable; QOL = quality of life

The strength of the evidence was defined as follows: High = High confidence that the evidence reflects the true effect. Further research is unlikely to change our confidence in the estimate of the effect. Moderate = Moderate confidence that the evidence reflects the true effect. Further research may change our confidence in the estimate of the effect and may change the estimate. Low = Low confidence that the evidence reflects the true effect. Further research is likely to change our confidence in the estimate of the effect and is likely to change the estimate. Insufficient = Evidence is unavailable, does not permit a conclusion, or consists of only one study with high risk of bias.

#### Applicability

The majority of studies in children and adolescents with type 1 diabetes were small, with the largest clinical trial including 72 participants.48 Most RCTs were fair or poor quality and only one RCT was good quality. The majority of studies focused on adolescents, with fewer studies in children 12 years of age or less. Studies generally did not report race but based on the countries in which they were conducted, the majority of which were outside of the United States, most studies included Caucasian participants. This is consistent with the fact that the majority of children with type 1 diabetes and adolescents and are Caucasian.5 Participants generally had poor glycemic control at study entry (mean HbA_1c_ 8–9 percent), were treated in the intervention groups for an average of 52 weeks, and had diabetes for 5–6 years prior to study entry.

### Comparative Effectiveness of CSII Versus MDI in Adults With Type 1 Diabetes

#### Key Points and Evidence Grades

- The strength of evidence was low that CSII produced a larger reduction in HbA1c than MDI (mean between-group difference from baseline, -0.30 percent; 95% CI, -0.58 to -0.02 percent, P=0.038). However, the pooled result was influenced by one study, which had a higher HbA1c at enrollment compared with the other studies. After removing this study, the difference between CSII and MDI became null (mean between-group difference from baseline, -0.01 percent, 95% CI, -0.35 to 0.34 percent).
- There was low strength of evidence comparing CSII with MDI for daytime hypoglycemia. One study reported more symptomatic and asymptomatic hypoglycemia between 8 a.m.and midnight in the MDI compared with the CSII intervention arm (P<0.05).59
- The strength of evidence was low comparing CSII with MDI for nocturnal hypoglycemia. Three studies reported nocturnal hypoglycemia. In one crossover trial, the proportion of patients experiencing nocturnal hypoglycemia was similar between the MDI and CSII intervention arms (relative risk [RR] for any, 0.98; 95% CI, 0.83 to 1.17; RR for symptomatic, 0.87; 95% CI, 0.64 to 1.19), although there were fewer episodes per person in the CSII compared with the MDI group (incidence rate ratio, 0.76; 95% CI, 0.63 to 0.91; P=0.0024).59 In two other studies, there was not a statistically significant difference in nocturnal hypoglycemic episodes between the two intervention groups.60 61
- We found low strength of evidence showing an increased risk of symptomatic hypoglycemia for CSII compared with MDI (combined incidence rate ratio, 1.30; 95% CI, 1.18 to 1.42; P<0.001), but we found evidence of substantial statistical heterogeneity for this meta-analysis. When excluding a study that required participants to have had recent severe hypoglycemia61 (compared with the other two which excluded those with recent severe hypoglycemia60 62) we saw an incidence rate ratio suggesting no relative difference in the incidence of symptomatic hypogycemia for CSII compared with MDI (combined incidence rate ratio, 0.99; 95% CI, 0.85 to 1.14). Another study, which did not provide sufficient quantitative results, reported slightly more symptomatic hypoglycemic events with CSII versus MDI (incidence rate ratio, 1.14; 95% CI, 1.00 to 1.29; P=0.05), although a similar proportion of participants experienced events over 5 weeks (RR, 1.05; 95% CI, 0.89 to 1.24).59
- The strength of evidence was low to suggest no difference in severe hypoglycemia incidence between the two intervention groups (combined RR, 0.74; 95% CI, 0.30 to 1.83, P=0.52). Four crossover trials did not provide quantitative results on severe hypoglycemia by period and therefore were not included in the meta-analysis. Two studies showed more severe hypoglycemia with MDI compared with CSII59 63 with one study reporting a relative risk of 2.6 (95% CI, 2.08 to 3.25).63 One study showed less severe hypoglycemia with MDI compared with CSII (incidence rate ratio, 3.00; 95% CI, 0.24 to 157.49).64 One study found similar rates of severe hypoglycemia between the two groups (1.1 events/patient for CSII vs. 1.3 events/patient for MDI over 4 months, P=0.33).65
- The strength of the evidence comparing CSII with MDI was low for other nonsevere hypoglycemia. Three studies found no difference in nonsevere hypoglycemia between the two intervention groups (in one study, mean between-group difference in asymptomatic hypoglycemia event rate, -0.2; 95% CI, -1.39 to 0.99; P=0.97).60 In two studies, the incidence of mild hypoglycemia was higher in the CSII compared with the MDI group59 66 with the relative difference statistically significant in one study (between-group difference in change in hypoglycemic rate, 0.99; 95% CI, 0.11 to 1.87).66 One additional study found a higher frequency of hypoglycemia in the MDI compared with the CSII group (RR, 1.12; 95% CI, 1.08 to 1.17).63
- The strength of evidence was low comparing CSII with MDI for fasting glucose. The mean between group difference in fasting glucose over 6 months was -12.3 mg/dL (95% CI, -32.9 to 8.2 mg/dL; P=NS) favoring CSII in one study.60 Two other studies reported no difference in fasting glucose between the MDI and CSII groups.
- The strength of evidence was low comparing CSII with MDI for pre-prandial glucose. The mean between-group difference in preprandial glucose over 6 months was -17.1 mg/dL (95% CI, -42.1 to 8.0 mg/dL; P=NS) favoring CSII in one study,60 and in another study, pre-dinner glucose was lower with CSII (128 mg/dL) compared with MDI (148 mg/dL) at the end of 5 weeks (P=NS).59 Predinner and prelunch glucoses were not significantly lower with CSII compared with MDI at 4 months (estimates not reported) in a third study.66
- There was insufficient strength of evidence to determine the relative effects of CSII and MDI on glucose at bedtime. A single study reported no difference in glucose at bedtime in the CSII compared to MDI arm but did not provide glucose results.66
- The strength of evidence was low comparing CSII with MDI for post-prandial glucose suggesting slightly lower postprandial glucoses with CSII compared with MDI treatment. Comparing CSII and MDI, the reported mean between-group difference in post-prandial glucose was -5.5 mg/dl (95% CI, -29.9 to 18.9 mg/dl) in one study60 and -24 and -15 mg/dl postbreakfast and postdinner, respectively, in another.59 Postbreakfast glucoses were not significantly higher in the MDI compared with CSII arm in a third study.66
- The strength of evidence was low comparing CSII with MDI for nocturnal hyperglycemia. Two studies found no difference in between-group difference in nocturnal glucose60 66 with one reporting an increase in nocturnal glucose in both arms (between-group difference for CSII compared to MDI, 54.8; 95% CI, -7.2 to 116.7 mg/dl).60
- The strength of evidence was low to suggest no difference in weight gain comparing CSII with MDI (combined between-group difference, -0.25 kg; 95% CI, -3.14 to 2.64 kg; P=0.86). Two additional studies reported no difference in weight gain but did not report sufficient quantitative results.
- The strength of evidence was low comparing CSII with MDI for general QOL. Two studies showed an improvement in general QOL between the two intervention groups favoring CSII. In one study, the Short Form (SF)-36 Physical Component Score change was -1.2 for CSII and 5.9 for MDI (P=0.048) and the Mental Component Score change was -0.6 for CSII and 5.2 for MDI (P=0.05).63 The other study did not report estimates but there was no difference in the Physical Component Score but a change in the Mental Component Score favoring CSII (P<0.05).
- There was low strength of evidence comparing CSII with MDI for diabetes-specific QOL. Three studies showed an improvement in diabetes-specific QOL favoring CSII. A meta-analysis favored CSII over MDI for Diabetes Quality of Life (mean between-group difference in Diabetes Quality of Life, 2.99; 95% CI, 0.006 to 5.97). One study showed improvement favoring MDI (Diabetes QOL mean between-group difference in change from baseline -18.00, 95% CI, -50.14 to 14.14).61
- The strength of evidence comparing CSII with MDI for diabetes treatment-related QOL was insufficient. Altered Hypoglycemia Awareness Questionnaire scores were similar in the CSII and MDI groups over 24 weeks (RR of Altered Hypoglycemia Awareness Questionnaire score greater than 4, 0.75; 95% CI, 0.26 to 2.18). Hypoglycemia Fear Survey scores decreased in the both CSII (-3±25) and MDI (-8±33) groups (mean between-group difference in the change from baseline, 5; 95% CI, -32.66 to 42.66).61
- We found insufficient evidence of the effects of MDI versus CSII among adults with type 1 diabetes in terms of any process measures, microvascular disease, macrovascular disease, and mortality, as no studies reported on these outcomes.

#### Study Design

Nine studies evaluated the effectiveness and safety of CSII versus MDI among adults with type 1 diabetes (see Appendix E, Table 1).59-67 Studies occurred in European countries,64-67 Canada,62 and the U.S.59 Two studies were multi-national.60 63 Five were parallel arm studies,60-62 66 67 and four used a crossover design.59 63-65 All studies randomized participants to the intervention with the exception of a single study.67 The duration of interventions ranged from 5 weeks to 1 year.59-67 Treatment lasted for 5 weeks in one study;59 4 months in three studies;64-66 6 months in three studies;60 61 63 and 9 months68 and 1 year67 in the other two studies. Studies included 21 to 272 participants. Four studies occurred in clinical settings.62 64-66 The other studies did not report study setting.59-61 63 67 Two studies did not report on the use of a run-in period.61 67

No study focused solely on an elderly population with type 1 diabetes. Two studies set a lower limit for HbA_1c_ for eligibility: 6.5 percent60 and 8.5 percent,67 and four studies set an upper limit for HbA_1c_ for eligibility: 8.5 percent,66 9 percent,59 60 and 10 percent.64 Eligibility criteria for prior insulin use varied across studies with three studies requiring that participants be on intensified insulin therapy with MDI,60 62 63 one study requiring MDI therapy be less than 1 year in duration,67 two studies excluding participants based on lack of recent CSII use,59 65 and one study excluding participants based on prior CSII use.60 Three studies excluded participants with frequent severe hypoglycemia,59 60 62 and another study excluded participants without severe hypoglycemia in the last 6 months.61

#### Population Characteristics

About one half of participants in the included studies were men with little imbalance by intervention strategy (see Appendix E, Table 2).60 63-67 One study consisted mainly of men with 62 percent of participants male in the CSII and 71 percent male in the MDI arm.62 Studies did not report on race. Mean HbA_1c_ was similar by intervention allocation with the exception of one study in which HbA_1c_ was 0.4 percent higher in the MDI versus CSII arm.62 Intervention arm-specific HbA_1c_ ranged from 7.4 percent to 9.3 percent at baseline.60 62 63 65 66 The mean duration of type 1 diabetes ranged from 14.4 to 25 years in studies reporting this.60-67 Mean duration of diabetes was 4.9 years higher in the CSII arm compared with the MDI arm in one study67 but otherwise similar by intervention strategy across studies.59-63 65 66

Five studies did not report on withdrawals by intervention allocation.59 60 63 65 67 In the other studies, withdrawals during the first treatment period varied by arm across studies: one in CSII and none in MDI,62 seven in CSII and none in MDI,66 and 16 in CSII and 15 in MDI.63 A cross-over trial reported five withdrawals from the CSII-MDI treatment group and four from the MDI-CSII treatment group.59 And another cross-over trial reported a single withdrawal during MDI therapy.64 One study reported the mistaken randomization of eight participants and an additional seven withdrawals without differentiation by treatment arm.60

#### Interventions

Four studies used NPH insulin as the long-acting insulin for the MDI arm,62-64 66 and the other studies used insulin glargine (see Appendix E, Table 3).59-61 65 67 All studies used insulin aspart or insulin lispro as the short-acting insulin during MDI treatment.59-67 Two studies incorporated 7 days of CGM.59 61 Eight studies specified provider guidelines for insulin titration based on SMBG.59-66 Five studies reported the use of insulin titration guidelines for participants.61-64 66

#### Outcomes

Details of the outcomes are reported in Appendix E, Table 4. These studies evaluated the effects of CSII and MDI in terms of HbA_1c_, hyperglycemia, hypoglycemia, severe hypoglycemia, weight, and quality of life. None of the included studies reported effects on mortality, microvascular disease, macrovascular disease, or any of the process measures.

##### HbA_1c_

Four RCTs reported a mean decrease in HbA_1c_ in both CSII and MDI treatment groups. CSII produced a larger reduction in HbA_1c_ than MDI (combined mean between-group difference, -0.30 percent; 95% CI, -0.58 to -0.02 percent, P=0.038) (Figure 12).60-62 66 However, the pooled estimate was influenced by one study,66 in which participants had a higher HbA_1c_ at enrollment (9.3 percent) compared with the other studies (7.7 to 8.2 percent), resulting in greater opportunity for a large HbA_1c_ reduction in that study (-0.84 percent) compared with the other studies (-0.1 to 0.25 percent). After removing this study, the difference between CSII and MDI became null (combined mean between-group difference, -0.01 percent, 95% CI, -0.35 to 0.34 percent; P=0.972). Study duration ranged from 4 months to 1 year.60-62 66 Egger's test and the funnel plot did not suggest bias due to absence of small studies. A fifth study reported a nonsignificant difference in improvement in HbA_1c_ from baseline. We did not include this study in the meta-analysis because it did not provide quantitative results.67 Because of anticipated carryover effects, we could not determine the effect of CSII and MDI on HbA_1c_ from the four crossover studies.59 63-65 These studies had an insufficient63 or no59 64 65 wash-out period between treatments and did not report results from the first treatment period. Additionally, the treatment periods in Hirsch et al. were only 5 weeks in duration.59

Figure 12 Between-group difference between CSII and MDI in how HbA_1c_ changed from baseline among adults with type 1 diabetes

CI = confidence interval; CSII = continuous subcutaneous insulin infusion; HbA_1c_ = hemoglobin A_1c_; MDI = multiple daily injections

Boxes indicate individual study point estimates. The box size denotes the weight of the study, with larger boxes contributing more to the pooled estimate. The width of the horizontal lines represents the 95% confidence intervals for each study. The diamond at the bottom of the graph indicates the 95% confidence interval for the random-effects pooled estimate.

Test for heterogeneity: Q = 8.45 with 3 degrees of freedom (p = 0.038); Q = 0.76 with 2 degrees of freedom (p = 0.684)

Figure 12 is a forest plot type diagram summarizing the between-group difference between MDI and CSII in how HbA1c changed from baseline among adults with type 1 diabetes. The included RCTs are DeVries 2002, Thomas 2007, Tsui 2001, and Bolli 2009. The combined mean between-group difference is -0.05 with a 95% confidence interval of -0.42 to 0.31% with a p value of 0.812 and I-squared value of 0%. Devries 2002, Thomas 2007, and Bolli 2008 favor CSII while Tsui 2001 favors MDI.

##### Symptomatic Hypoglycemia

Four trials evaluated symptomatic hypoglycemia.59-62 We combined results from three of these studies in a meta-analysis which revealed a significant increase in the incidence of symptomatic hypoglycemia events/person-year with CSII compared with MDI (combined incidence rate ratio, 1.30; 95% CI, 1.18 to 1.42; P<0.001) (see Figure 13).60-62 We found evidence of substantial statistical heterogeneity (I^2^ = 96 percent). Given the small number of studies, we were unable to perform meta-regression to formally explore causes of this heterogeneity. A likely source of the observed heterogeneity is a difference in study populations. While two of the studies excluded participants with more than two severe hypoglycemic episodes in the past 6 months,60 62 the other only included participants with at least one episode of severe hypoglycemia in the past 6 months.61 This study was influential and removal of this study from the meta-analysis resulted in a combined incidence rate ratio of 0.99 (95% CI, 0.85 to 1.14) for CSII versus MDI. Egger's test and the funnel plot did not reveal publication bias. Of participants experiencing probable (not documented) symptomatic hypoglycemia in a cross-over trial, symptomatic hypoglycemia occurred slightly more frequently during CSII treatment compared with MDI treatment (6.9 events/person versus 6.1 events/person; P=0.05) although the percentage of participants experiencing symptomatic hypoglycemia were similar at 5 weeks (75 percent for CSII versus 72 percent for MDI).59 We did not include this study in the meta-analysis because of its cross-over design and a lack of reporting results from a paired analysis or by period, thus precluding a valid estimate of variance for the meta-analysis.59

Figure 13 Incident rate ratios for symptomatic hypoglycemia in CSII versus MDI interventions among adults with type 1 diabetes

CI = confidence interval; CSII = continuous subcutaneous insulin infusion; IRR = incidence rate ratio; MDI = multiple daily injections

Boxes indicate individual study point estimates. The box size denotes the weight of the study, with larger boxes contributing more to the pooled estimate. The width of the horizontal lines represents the 95% confidence intervals for each study. The diamond at the bottom of the graph indicates the 95% confidence interval for the random-effects pooled estimate.

Test for heterogeneity: Q = 50.32 with 2 degrees of freedom (p = 0.00)

Figure 13 is a forest plot type diagram summarizing the incident rate ratios for symptomatic hypoglycemia in MDI versus CSII interventions among adults with type 1 diabetes. There are three RCTs included, which are Tsui 2001, Thomas 2007, and Bolli 2009. All but Bolli 2009 favor MDI, with an overall incident rate ratio of 1.30 and 95 percent confidence interval of 1.19 to 1.42, an I-squared value of 96 percent, and a p value of 0.

##### Daytime Hypoglycemia

A single RCT using a crossover design reported more hypoglycemic events between 8 a.m. and midnight during MDI treatment than during CSII treatment (P<0.05).59 Hypoglycemia could be symptomatic or asymptomatic and the study defined it as glucose less than 50 mg/dL not necessitating assistance from a third party.59

##### Nocturnal Hypoglycemia

Three studies reported on nocturnal hypoglycemia (Table 8).59-61 One crossover trial reported a similar percentage of participants experiencing any nocturnal hypoglycemia (symptomatic, minor, or major) (72 percent vs. 73 percent) or symptomatic nocturnal hypoglycemia (42 percent vs. 48 percent) in the CSII and MDI treatment arms, respectively (statistical significance not reported).59 Of participants with any nocturnal hypoglycemia, the authors reported slightly but significantly fewer episodes per person in the CSII compared with MDI arm over five weeks of treatment (3.0 events per participant vs. 4.0 events per participant; P=0.002).59 A study of 58 participants also reported slightly fewer episodes of nocturnal hypoglycemia with CSII compared with MDI over 6 months, but this difference did not reach statistical significance (three events per person versus five events per person; P=0.34).60 A small trial of 14 participants with a history of severe hypoglycemia reported no episodes of nocturnal hypoglycemia (definition not provided) in the CSII arm after 6 months and did not report on this outcome in the MDI treatment arm.61 All studies employed SMBG for glucose monitoring and interval eight-point SMBG profiles.59-61 One study also measured glucose with a CGM system during the last week of each treatment period.59 We were unable to perform a meta-analysis for this outcome because of a lack of reporting of the necessary quantitative results. Hirsch, et al. was a crossover study that did not report results for a paired analysis or by period.59 Another study did not report on nocturnal hypoglycemia in the MDI arm.61

Table 8 Definition of nocturnal hypoglycemia in the studies of adults with type 1 diabetes

Author, Year | Definition of Nocturnal Hypoglycemia
Bolli, 2009^60^ | Between bedtime and rising
Hirsch, 2005^59^ | Symptomatic and not documented by blood glucose measurement
Hirsch, 2005^59^ | Asymptomatic glucose < 50 mg/dL, symptomatic glucose < 50 mg/dL without third party intervention required, or central nervous system symptoms requiring third party intervention
Thomas, 2007^61^ | Not specified

mg/dL = milligrams per deciliter

##### Other Mild Hypoglycemia

Six studies evaluated the incidence of other types of mild hypoglycemia with CSII compared with MDI therapy (Table 9).59 60 63-66 In one RCT, rates of asymptomatic hypoglycemia were similar in both groups over 6 months of treatment (1.4 events/patient versus 1.2 events/patient; P=0.97).60 In two studies, the incidence of mild hypoglycemia was higher during CSII compared with MDI treatment59 66 with the relative difference statistically significant in one of these studies.66 However, in another trial, the risk of self-managed mild hypoglycemia was higher during MDI treatment (RR, 1.12; 95% CI, 1.08 to 1.17).63 Two other studies found no difference in the incidence of biochemical hypoglycemia during CSII compared with MDI treatment.64 65 We did not combine these results in a meta-analysis because substantial heterogeneity in outcome definitions (Table 9).

Table 9 Definition of mild hypoglycemia in the studies of adults with type 1 diabetes

Author, Year | Definition of Mild Hypoglycemia
Bolli, 2009^60^ | Asymptomatic
Bruttomeso, 2008^65^ | Measured glucose 36 to 63 mg/dL
DeVries, 2002^66^ | Change in frequency of SMBG < 70 mg/dL per patient-week
Hanaire-Broutin, 2000^64^ | Measured glucose < 60 mg/dL during last 14 days of treatment
Hirsch, 2005^59^ | Asymptomatic glucose < 50 mg/dL or symptomatic glucose < 50 mg/dL without third party intervention required
Hoogma, 2006^63^ | No third party intervention required

mg/dL = milligrams per deciliter; SMBG = self-monitoring of blood glucose

##### Severe Hypoglycemia

A meta-analysis of three RCTs indicated no difference in the incidence of severe hypoglycemia with CSII compared with MDI treatment (combined RR, 0.74; 95% CI, 0.30 to 1.83, P=0.52) (Figure 14).60 61 66 Duration of these studies ranged from 4 to 6 months, and definitions of severe hypoglycemia required assistance from a third party in all three trials (Table 10). Of note, one study included in the meta-analysis required that participants have a history of severe hypoglycemia, but event rates were similar to those in the other two studies.61 We did not find evidence of statistical heterogeneity, and no single study influenced results substantially. Egger's test and the funnel plot did not suggest bias due to absence of small studies.

Figure 14 Pooled relative risk of severe hypoglycemia in CSII versus MDI interventions among adults with type 1 diabetes

CI = confidence interval; CSII = continuous subcutaneous insulin infusion; MDI = multiple daily injections; RR = relative risk

Boxes indicate individual study point estimates. The box size denotes the weight of the study, with larger boxes contributing more to the pooled estimate. The width of the horizontal lines represents the 95% confidence intervals for each study. The diamond at the bottom of the graph indicates the 95% confidence interval for the random-effects pooled estimate.

Test for heterogeneity: Q = 0.58 with 2 degrees of freedom (p = 0.75)

Figure 14 is a forest plot type diagram summarizing the pooled relative risk of severe hypoglycemia in MDI versus CSII interventions among adults with type 1 diabetes. The diagram displays the relative risk, 95% confidence interval, number of events of severe hypoglycemia on CSII, number of patients on CSII, number of events on MDI and number of patients on MDI. RCTs are DeVries 2002 with a relative risk of 0.51 and 95% confidence interval of 0.14 to 1.1; Thomas 2007 with a relative risk of 1.00 and 95% confidence interval of 0.19 to 5.24, and Bolli 2009 with a relative risk of 1.08 and 95% confidence interval of 0.17 to 7.10. Their combined relative risk is 0.74 with a 95% confidence interval of 0.3 to 1.83. DeVries 2002 favors CSII, Bolli 2009 favors MDI.

Table 10 Definition of severe hypoglycemia in the RCTs of adults with type 1 diabetes

Author, Year | Definition of Severe Hypoglycemia
Bolli, 2009^60^ | Requiring management assistance and either plasma glucose <2.0 mmol/l (<36 mg/dL) or prompt recovery after oral or intravenous carbohydrate or glucagon
Thomas, 2007^61^ | ADA definition: “An event requiring assistance of another person to actively administer carbohydrate, glucagons, or other resuscitative actions. These episodes may be associated with sufficient neuroglycopenia to induce seizure or coma. Plasma glucose measurements may not be available during such an event, but neurological recovery attributable to the restoration of plasma glucose to normal is considered sufficient evidence that the event was induced by a low plasma glucose concentration.”
DeVries, 2002^66^ | Requirement of third-party help
Tsui, 2001^62^ | Events requiring assistance or resulting in coma
Lepore, 2003^67^ | Event requiring assistance from another person or resulting in a seizure or coma

ADA = American Diabetes Association; mg/dL = milligrams per deciliter; mmol/L = millimole per liter; RCTs = randomized controlled trials

We did not include two additional studies in the meta-analysis because of a lack of quantitative results. One RCT reported a small difference that was not significant in the number of severe hypoglycemic events over 9 months in the CSII versus MDI treatment arm (six events vs. four events) but did not report if any individuals had more than one hypoglycemic event.62 The other study was non-randomized and reported that the number of severe hypoglycemia episodes decreased in both treatment arms during the study.67

Four cross-over trials did not provide quantitative results on severe hypoglycemia by period and were not included in the meta-analysis.59 63-65 Table 11 summarizes how severe hypoglycemia was defined in those trials. Severe hypoglycemia events were more frequent during MDI therapy compared with CSII therapy in two studies,59 63 with one study reporting a relative risk of 2.6 (95% CI, 2.08 to 3.25).63 Compared with CSII therapy, severe hypoglycemia occurred less frequently during MDI therapy in one study (three events vs. one event over 4 months.64 A fourth trial reported similar rates of severe hypoglycemia during CSII and MDI therapy (1.1 events/patient and 1.3 events/patient, respectively over 4 months; P=0.327).65

Table 11 Definition of severe hypoglycemia in the cross-over trials of adults with type 1 diabetes

Author, Year | Definition of Severe Hypoglycemia
Bruttomesso, 2008^65^ | Plasma glucose <36 mg/dL
Hoogma, 2006^63^ | Requirement of third-party help
Hirsch, 2005^59^ | Episodes with severe central nervous system symptoms consistent with hypoglycemia that the patient was unable to treat himself/herself, which had either (1) blood glucose <50 mg/dL or (2) reversal of symptoms after either food intake or glucagon/intravenous glucose administration
Haiare-Broutin, 2000^64^ | Events requiring external help, glucose administration, coma, or seizure

mg/dL = milligrams per deciliter

##### Hyperglycemia

We were unable to perform meta-analyses for the hyperglycemia outcomes because of a lack of reporting of the necessary quantitative results (detailed below).

##### Fasting Glucose

Fasting glucose did not vary significantly by treatment with CSII or MDI across three RCTs. In one RCT, fasting glucose decreased more with CSII than with MDI at 6 months (mean between-group difference, -12.3 mg/dL; 95% CI, -32.9 to 8.2 mg/dL).60 In a non-randomized trial, CSII and MDI lowered fasting glucose similarly at 12 months (quantitative results not reported).67 A third RCT reported a lower fasting glucose at 4 months in the CSII arm compared with the MDI arm, but this difference in fasting glucose was not statistically significant.66 The authors did not provide estimates of these glucose levels.66

##### Preprandial Glucose (Other Than Prebreakfast)

Three RCTs reported on the effect of CSII and MDI on preprandial glucose. In one RCT, CSII decreased preprandial glucose more than MDI at 6 months (mean between-group difference, -17.1 mg/dL; 95% CI, -42.1 to 8.0 mg/dL),60 but this difference was not significant. In a crossover trial, pre-dinner glucose was not significantly lower at 5 weeks at the end of the CSII period (128 mg/dL) compared with the MDI period (148 mg/dL).59 CSII lowered predinner and prelunch glucoses more than MDI nonsignificantly at 4 months in another study,66 but the authors did not provide estimates of these glucose levels.66

##### Glucose at Bedtime

In a single study, glucose at bedtime was not significantly lower in the CSII arm compared with MDI arm at 4 months.66 The authors did not provide estimates of these glucose levels.66

##### Nocturnal Glucose

Two trials did not find a significant between-group difference in nocturnal glucose levels. Nocturnal glucose increased in both arms in one study with a mean between-group difference of 54.8 mg/dL (95% CI, -7.2 to 116.7 mg/dL) at 6 months for CSII compared with MDI.60 The other study reported equal nocturnal blood glucoses at 4 months in both arms, but the authors did not provide estimates of these glucose levels.66

##### Postprandial Glucose

Three RCTs reported lower postprandial glucoses with CSII compared with MDI treatment. In one trial, postprandial glucose decreased in the CSII arm and increased in the MDI arm over 6 months (mean between-group difference for CSII versus MDI, -5.5 mg/dL; 95% CI, -29.9 to 18.9 mg/dL).60 In a crossover trial, postbreakfast and postdinner glucoses were lower after 5 weeks, for the CSII treatment period (mean glucose 158 mg/dL and 144 mg/dL for breakfast and dinner, respectively) compared with the MDI treatment period (mean glucose 182 mg/dL and 159 mg/dL for breakfast and dinner, respectively).59 In a third trial, postlunch and postdinner glucoses were similar at 4 months in the MDI and CSII arms, but postbreakfast glucose levels were nonsignificantly higher in the MDI compared with CSII arm.66 The authors did not provide estimates of these glucose levels in this study.66

##### Weight

Four studies examined the effects of MDI versus CSII on weight gain in adults with type 1 diabetes, and we outlined the results in Table 12.^61^ 65-67 Meta-analysis of two studies providing sufficient quantitative results showed no difference in weight gain for CSII compared with MDI (combined mean between-group difference in change from baseline, -0.25 kg; 95% CI, -3.14 to 2.64 kg; P=0.87) (Figure 15).61 66 We did not find evidence of statistical heterogeneity. The availability of only two studies for the meta-analysis limited our ability to explore influence of publication bias. The remaining two studies reported no significant change in weight, which one study attributed to the presence of a dietician.65 67

Table 12 Weight gain in CSII versus MDI interventions among adults with type 1 diabetes

Author, year | MDI, N | CSII, N | Timepoint (Weeks) | Weight Gain – MDI | Weight Gain – CSII | CSII Effect on Weight Gain vs. MDI (kg) | P Value
DeVries, 2002^66^ | 40 | 39 | 4 | 0.88 | 0.60 | -0.28 | 0.68
Lepore, 2003^67^ | 16 | 16 | 12 | - | - | - | -
Thomas, 2007^61^ | 7 | 7 | 6 | -1.0 | 0.5 | 1.5 | 0.88; 0.94
Bruttomesso, 2008^65^ | 39 | 39 | 4 | - | - | - | -

CSII = continuous subcutaneous insulin infusion; kg = kilogram; MDI = multiple daily injections

Figure 15 Between-group difference between CSII and MDI in how weight changed from baseline among adults with type 1 diabetes

CI = confidence interval; CSII = continuous subcutaneous insulin infusion; kg = kilograms; MDI = multiple daily injections

Boxes indicate individual study point estimates. The box size denotes the weight of the study, with larger boxes contributing more to the pooled estimate. The width of the horizontal lines represents the 95% confidence intervals for each study. The diamond at the bottom of the graph indicates the 95% confidence interval for the random-effects pooled estimate.

Test for heterogeneity: Q = 50.32 with 2 degrees of freedom (p = 0.00)

Figure 15 is a forest plot type diagram summarizing the between group difference between MDI and CSII in how weight changed from baseline among adults with type 1 diabetes. The two RCTs included in the analysis are DeVries 2002 and Thomas 2007. DeVries 2002 slightly favors CSII while Thomas 2007 slightly favors MDI. The overall mean difference is -0.25 with a 95 percent confidence interval of -3.14 to 2.64, an I-squared value of 0 and a p value of 0.882.

##### Quality of Life, Including General, Diabetes-Specific, and Treatment-Related

Five studies examined the comparative effectiveness of CSII versus MDI on general QOL, diabetes-specific QOL, and diabetes treatment-related QOL in adults with type 1 diabetes (Table 13). The studies measured general QOL using the Short Form (SF)-36^66^ and SF-12.^63^ Two studies showed an improvement in general QOL favoring CSII.63 66

Table 13 Quality of life in CSII versus MDI interventions among adults with type 1 diabetes

QOL Domain | Author, Year | N by Intervention Group | Comparison | Population | Difference in QOL Between Comparison and Baseline Groups | Group Favored for QOL Measure
SF-36^*^ | DeVries, 2002^66^ | 79 adults | CSII vs. MDI (crossover study) | 79 adults with type 1 diabetes, age between 18 and 70 years, and poor diabetes control with MDI | PCS: At 16 weeks, change in CSII group was -1.2 versus +5.9 in MDI (P=0.048) MCS: After 16 weeks, change in CSI group was -0.6 was versus +5.2 in MDI (P=0.050) | CSII
SF-12^*^ | Hoogma, 2006^63^ | 129 MDI-CSII, 127 CSII-MDI | CSII vs. MDI (crossover study) | 256 adults with type 1 diabetes, aged 18 to 65 years, on MDI for at least 6 months | At 8 months: PCS: no difference MCS: CSII favored over MDI (P<0.05) (no data given) | CSII
DQOL^†^ | Thomas, 2007^61^ | 7 CSII, 7 MDI, 7 education | CSII vs. optimized MDI vs. education and conventional insulin therapy | 21 adult patients with type 1 diabetes, age 33 to 53 years, with at least 1 episode of severe hypoglycemia in the past 6 months | At 24 weeks: difference of 5±28 compared with baseline in CSII; 11±23 in MDI; -9±19 in education | MDI
DQOL^†^ | Hoogma, 2006^63^ | 129 MDI-CSII, 127 CSII-MDI | CSII vs. MDI (crossover study) | 256 adults with type 1 diabetes, aged 18 to 65 years, on MDI for at least 6 months | At 8 months, 75 in CSII versus 71 in MDI (P<0.001) | CSII
DQOL^†^ | Tsui, 2001^62^ | 13 CSII, 14 MDI | CSII vs. MDI | 27 adults aged 18 to 60 years with type 1 diabetes | At 9 months, satisfaction score in the CSII group was 75.6, in the MDI group 68.3. CSII – MDI difference was 7.2 (95% CI, 3.4 to 17.9), P>0.10 | CSII
DQOL^†^ | Bolli, 2009^60^ | 24 CSI, 26 MDI | CSII vs. MDI | 50 adults with type 1 diabetes | At 24 weeks: 22.8± 8.1 at baseline to 31.5 ±4.9 in the CSII group and from 24.0 ± 6.3 to 28.8 ± 5.4 in the MDI group (treatment difference: 3.1 (95% CI, 0.1 to 6.1); P=0.04). | CSII
Altered Hypoglycemia Awareness Questionnaire^‡^ | Thomas, 2007^61^ | 7 CSII, 7 MDI, 7 education | CSII vs. optimized MDI vs. education and conventional insulin therapy | 21 adult patients with type 1 diabetes, age 33 to 53 years, with at least 1 episode of severe hypoglycemia in the past 6 months | At 24 weeks, AHA score in the education group was 2 compared with 7 at baseline; in the MDI group, 4 compared with 7 at baseline; in the CSII group, 3 compared with 7 at baseline | Neither
Hypoglycemia Fear Survey^‡^ | Thomas, 2007^61^ | 7 CSII, 7 MDI, 7 education | CSII vs. optimized MDI vs. education and conventional insulin therapy | 21 adult patients with type 1 diabetes, age 33-53, with at least 1 episode of severe hypoglycemia in the past 6 months | At 24 weeks, difference from baseline was -3 ± 25 in CSII; -8 ± 33 in MDI; 4 ± 20 in education | MDI

AHA = Altered Hypoglycemia Awareness; BMI = body mass index; CI = confidence interval; CSII = continuous subcutaneous insulin infusion; DQOL = Diabetes Quality of Life; HbA_1c_ = hemoglobin A_1c_; kg/m2 = kilograms per meters squared; MCS = Mental Component Score; MDI = multiple daily injections; PCS = Physical Component Score; QOL = quality of life; SF = Short Form

* General Quality of Life. Total scores from the Short Form-36 and Short Form-12 range from 0 to 100, with higher scores indicating higher level of health.

† Diabetes-specific Quality of Life. Total scores from the Diabetes Quality of Life questionnaire range from 0 to 100, with higher scores indicating better quality of life.

‡ Diabetes Treatment-Related Quality of Life. Total scores from the Altered Hypoglycemia Awareness questionnaire range from 0 to 7, with higher scores indicating altered awareness. Total scores from the Hypoglycemia Fear Survey range from 0 to 92, with higher scores indicating a higher level of fear.

Four studies examining the comparative effectiveness of CSII versus MDI on diabetes-specific QOL used the Diabetes Quality of Life questionnaire.60-63 Three studies showed an improvement in diabetes-specific QOL favoring CSII60 62 63 and one study showed improvement favoring MDI.61 A meta-analysis of those studies using Diabetes Quality of Life questionnaire as a measure, including only those studies which gave confidence intervals60 61 favored CSII (mean between-group difference, 2.99; 95% CI, 0.006 to 5.97, P=0.05) (Figure 16).

Figure 16 Between-group difference between CSII and MDI in how Diabetes Quality of Life Questionnaire score changed from baseline among adults with type 1 diabetes

CI = confidence interval; CSII = continuous subcutaneous insulin infusion; kg = kilograms; MDI = multiple daily injections

^*^Quality of life is measured in terms of the Diabetes Quality of Life Questionnaire. Total scores range from 0 to 100, with higher scores indicating better quality of life.

Boxes indicate individual study point estimates. The box size denotes the weight of the study, with larger boxes contributing more to the pooled estimate. The width of the horizontal lines represents the 95% confidence intervals for each study. The diamond at the bottom of the graph indicates the 95% confidence interval for the random-effects pooled estimate.

Test for heterogeneity: Q = 0.44 with 1 degree of freedom (p = 0.51)

Figure 16 is a forest plot type diagram summarizing the between group difference between MDI and CSII in how Diabetes Quality of life measure changed from baseline among adults with type 1 diabetes. The two RCTs included in the analysis are Thomas 2007 and Bolli 2009. Thomas 2007 favors MDI while Bolli 2009 favors CSII. The overall mean difference is 2.99 with a 95 percent confidence interval of 0.01 to 5.97, an I-squared value of 0 and p value of 0.509.

One study examined the comparative effectiveness of CSII versus MDI on diabetes treatment-related QOL using the Altered Hypoglycemia Awareness Questionnaire and the Hypoglycemia Fear Survey.61 There was no difference in hypoglycemia awareness or fear between the two intervention arms at the conclusion of the study.

#### Study Quality

We rated two studies as being of good quality62 64 with the others rated as being of fair or poor quality.59-61 63 65-67 All included studies were RCTs. A lack of reporting on most quality items limited our assessment of the risk of bias. Three studies reported an appropriate randomization sequence generation,62 65 66 and only two studies reported appropriate allocation concealment.62 66 Four studies did not mask outcome assessors to intervention arm.60 63 64 66 Two studies reported one withdrawal,62 64 and five did not handle missing data appropriately.59 60 63 65 66 All studies reported industry support with the exception of one.67 Studies did not otherwise report on these quality items.

#### Strength of Evidence

The strength of evidence examining the comparative effectiveness of CSII versus MDI in adults with type 1 diabetes was low for HbA_1c_ and low or insufficient for all other outcomes (see Table 14). All included studies were RCTs, and the risk of bias was medium or high. CSII produced a greater reduction in HbA_1c_ compared with MDI; however, there was heterogeneity and the results were heavily influenced by one study. When this study was removed, there was no difference in the effect of CSII compared with MDI on HbA_1c_. There was no apparent difference in the effects of CSII compared with MDI on weight change, most hypoglycemia outcomes, and fasting and pre-prandial glucose. The relative magnitude of effect on post-prandial glucose and symptomatic hypoglycemia was small for the interventions. The small number of studies affected our assessment of the overall strength of the evidence for the outcomes for the comparative effectiveness of CSII versus MDI in adults with type 1 diabetes. The studies were small, did not use the same definitions for many outcomes, and often did not report sufficient quantitative results limiting our ability to combine effect estimates across studies. Notably, the evidence on the risk of severe hypoglycemia was limited by low event rates and resultant imprecise results.

Table 14 Numbers of studies and subjects, strength of evidence domains, magnitude of effect, and overall strength of evidence for CSII versus MDI in adults with type 1 diabetes

Outcome | Number of Studies (Participants) | Domains Pertaining to Strength of Evidence | | | | | Magnitude of Effect and Strength of Evidence
Outcome | Number of Studies (Participants) | Risk of Bias: Design/ Quality | Consistency | Directness | Precision | Publication Bias | Magnitude of Effect and Strength of Evidence
Mortality | 0 | NA | NA | NA | NA | NA | Strength of evidence: Insufficient
Microvascular outcomes | 0 | NA | NA | NA | NA | NA | Strength of evidence: Insufficient
Macrovascular outcomes | 0 | NA | NA | NA | NA | NA | Strength of evidence: Insufficient
HbA_1c_ | 5 (227) | Medium | Inconsistent | Direct | Precise | None | Magnitude of effect: Smallt Strength of evidence: Low
Fasting glucose | 3 (161) | High | Consistent | Direct | Imprecise | Uncertain | Magnitude of effect: No effect Strength of evidence: Low
Post-prandial glucose | 3 (179) | Medium | Consistent | Direct | Precise | Uncertain | Magnitude of effect: Small Strength of evidence: Low
Pre-prandial glucose | 3 (179) | Medium | Consistent | Direct | Imprecise | Uncertain | Magnitude of effect: No effect Strength of evidence: Low
Glucose at bedtime | 1 (79) | Medium | Unknown | Direct | Imprecise | Uncertain | Magnitude of effect: Unable to determine Strength of evidence: Insufficient
Nocturnal glucose | 2 (129) | High | Consistent | Direct | Imprecise | Uncertain | Magnitude of effect: No effect Strength of evidence: Low
Symptomatic hypoglycemia | 4 (141) | Medium | Inconsistent | Direct | Precise | None | Magnitude of effect: Small Strength of evidence: Low
Daytime hypoglycemia | 1 (100) | Medium | Unknown | Direct | Precise | Uncertain | Magnitude of effect: Unable to determine Strength of evidence: Low
Nocturnal hypoglycemia | 3 (114) | Medium | Consistent | Direct | Imprecise | Uncertain | Magnitude of effect: Unable to determine Strength of evidence: Low
Severe hypoglycemia | 9 (588) | Medium | Inconsistent | Direct | Imprecise | None | Magnitude of effect: No effect Strength of evidence: Low
Other hypoglycemia | 6 (515) | Medium | Inconsistent | Direct | Imprecise | Uncertain | Magnitude of effect: Unable to determine Strength of evidence: Low
Weight | 4 (184) | Medium | Consistent | Direct | Imprecise | Uncertain | Magnitude of effect: No effect Strength of evidence: Low
Ratio of basal to bolus insulin | 0 | NA | NA | NA | NA | NA | Strength of evidence: Insufficient
Frequency of adjusting insulin therapy | 0 | NA | NA | NA | NA | NA | Strength of evidence: Insufficient
Adherence to insulin therapy | 0 | NA | NA | NA | NA | NA | Strength of evidence: Insufficient
Frequency of professional or allied health visits | 0 | NA | NA | NA | NA | NA | Strength of evidence: Insufficient
General QOL | 2 (335) | High | Consistent | Direct | Imprecise | Uncertain | Magnitude: Small Strength of evidence: Low
Diabetes-specific QOL | 3 (354) | High | Inconsistent | Direct | Imprecise | Uncertain | Magnitude: Small Strength of evidence: Low
Diabetes treatment-related QOL | 1 (21) | Medium | Unknown | Direct | Imprecise | Uncertain | Magnitude: Small Strength of evidence: Insufficient

HbA_1c_ = hemoglobin A_1c_; NA = not applicable; QOL = quality of life

The strength of the evidence was defined as follows: High = High confidence that the evidence reflects the true effect. Further research is unlikely to change our confidence in the estimate of the effect. Moderate = Moderate confidence that the evidence reflects the true effect. Further research may change our confidence in the estimate of the effect and may change the estimate. Low = Low confidence that the evidence reflects the true effect. Further research is likely to change our confidence in the estimate of the effect and is likely to change the estimate. Insufficient = Evidence is unavailable, does not permit a conclusion, or consists of only one study with high risk of bias.

#### Applicability

Few studies compared the effect of CSII with MDI in adults with type 1 diabetes. Existing studies were generally of fair or poor quality and did not report on most quality items of interest.

Studies did not report on many items of interest to determine the applicability of the studies to all adults with type 1 diabetes. Studies did not report on race, and no study focused on elderly adults with type 1 diabetes, although this would be expected to be a small proportion of individuals with type 1 diabetes. Four trials took place in outpatient clinics. Interventions lasted between 5 weeks and 12 months. The mean baseline HbA_1c_ was 7.4 to 9.3 percent across the studies. The duration of diabetes at enrollment was greater than 14 years in the studies reporting this. Eligibility criteria for MDI and insulin pump use varied significantly across the studies. Four studies reported training on insulin pump use.

### Comparative Effectiveness of CSII Versus MDI Among Adults With Type 2 Diabetes

#### Key Points and Evidence Grades

- The strength of the evidence was insufficient comparing the relative effects of CSII and MDI on mortality. A single study reported one death due to cancer in the CSII treatment arm.69
- The strength of evidence was moderate suggesting no difference between CSII and MDI for their effects on HbA_1c_ (mean between-group difference from baseline, -0.16 percent; 95% CI, -0.42 to 0.09 percent, P=0.21).
- The strength of the evidence comparing CSII with MDI for mild hypoglycemia was moderate and suggested no difference in the risk of mild hypoglycemia (combined RR, 0.90; 95% CI, 0.78 to 1.03; P=0.129).
- The strength of the evidence comparing CSII with MDI for nocturnal hypoglycemia was insufficient. In a single study, nocturnal hypoglycemia (occurring between midnight and 6 a.m.) was less common in patients in the CSII compared with the MDI arm (RR, 0.73; 95% CI, 0.35 to 1.54).
- The strength of the evidence was low that the risk of severe hypoglycemia did not differ between CSII and MDI (RR, 0.76; 95% CI, 0.26 to 2.19).
- The strength of the evidence was low comparing CSII with MDI for hyperglycemia. Mean post-prandial glucose (90 minutes after breakfast) was 167 mg/dL in the CSII arm and 192 mg/dL in the MDI arm at 24 weeks (mean between-group difference, -25 mg/dL; 95% CI, -45 to -5 mg/dL).36 Glucose measurements from other time points were similar between treatment groups at the end of the study. The incidence of blood glucose over 350 mg/dL was higher in the MDI compared with the CSII arm (26 vs. six events), affecting 18 percent and 5 percent of participants in the MDI and CSII arms, respectively (RR, 0.28; 95% CI, 0.08 to 0.94).36
- The strength of evidence was low suggesting no difference in weight gain between CSII and MDI groups, based on two studies (combined between-group difference in weight change from baseline, -0.49 kg; 95% CI, -1.25 to 0.26 kg).
- The strength of the evidence comparing CSII with MDI was insufficient for general QOL. One study showed no difference in general QOL between the CSII and MDI intervention groups. The difference in SF-36v2 Physical Component Score from baseline to follow-up was 0.6 for CSII versus 0.4 for MDI and for the Mental Component Score, the difference from baseline to follow-up was 1.0 for CSII and 2.5 for MDI.69
- The strength of the evidence comparing CSII with MDI was insufficient for diabetes-specific QOL. One study showed no difference in diabetes-specific QOL between the CSII and MDI intervention groups (Diabetes Quality of Life Clinical Trials Questionnaire scores improved from 52 to 81 for CSII and from 50 to 78 for MDI over 12 months).69
- The strength of the evidence comparing CSII with MDI was insufficient for diabetes treatment-related QOL. One study showed improvement in diabetes treatment satisfaction favoring CSII (mean between-group difference in Phase V Outcomes System Diabetes Treatment Satisfaction score change from baseline in 24 weeks, 13.1; 95% CI, 7.4 to 18.8).36
- We found insufficient strength of evidence evaluating the effects of MDI vs. CSII among patients with type 2 diabetes in terms of any of the process measures, microvascular disease, or macrovascular disease, as no studies reported on these outcomes.

#### Study Design

Of the four studies evaluating CSII versus MDI therapy in patients with type 2 diabetes, three were parallel-arm randomized trials,36 69 70 and one was a randomized cross-over trial (see Appendix E, Table 1).37 Treatment periods were 18 weeks in duration in the cross-over study,37 and the parallel-arm studies were 6 or 12 months in duration.36 69 70 The cross-over study enrolled patients from diabetes centers,37 and another study took place in a university clinic.70 The other two studies did not report on study setting.36 69 Three trials reported a run-in period.36 37 69

Two studies excluded participants with HbA_1c_ greater than 12 or 15 percent,36 37 and three studies excluded persons with HbA_1c_ less than 6, 7, or 8.5 percent.36 37 69 All studies required that participants be treated with insulin prior to the study.36 37 69 70

#### Population Characteristics

The number of participants per arm ranged from 20 to 66 in the included studies (see Appendix E, Table 2).36 37 69 70 All studies were conducted in adults, one study only included participants 60 years of age or older.69 More men were randomized to the CSII treatment group in two studies.36 69 Two studies did not report on the racial composition of their study populations, and the other two studies were multi-ethnic but predominantly white (> 80 percent).36 69 Mean HbA_1c_ was 0.3 percent higher at baseline in the CSII compared with MDI arm in one study.69 Mean BMI ranged from 29.5 to 32.5 kg/m^2^ and was similar by treatment group across the three parallel-arm studies.36 69 70 The mean duration of type 2 diabetes was greater than 10 years in the two studies reporting this and was 1.5 and 1.7 years higher in the CSII compared with MDI arms in these studies.36 69 Three studies reported four to six withdrawals per intervention arm, and the number of withdrawals did not vary by arm.36 37 69 One study had additional withdrawals after randomization (two from MDI and three from CSII) but before the treatment period began.36

#### Interventions

The type of insulin used in the MDI arms varied across studies: neutral protamine Hagedorm (NPH) and Regular insulin;37 insulin glargine and insulin lispro;69 70 and NPH insulin and insulin aspart (see Appendix E, Table 3).36 Insulin aspart was used in the CSII arm for one study,36 and insulin lispro was used in the CSII arm in the other studies.37 69 70 Three studies reported the use of provider guidelines for medication titration,36 37 69 but the targets varied. One study specified an HbA_1c_ target of 7 percent,37 and another specified both an HbA_1c_ target of 5.6 percent and glucose targets of 80 to 120 mg/dL for pre-prandial glucose, and 100 to 150 mg/dL at bedtime.69 The third study specified a fasting glucose of 80 to 120 mg/dL as its only target.36 Two studies provided guidelines for participants to use between visits.37 69

#### Outcomes

Details of the outcomes are reported in Appendix E, Table 4. These studies evaluated the effects of CSII and MDI in terms of mortality, HbA_1c_, hypoglycemia, severe hypoglycemia, hyperglycemia, weight, and quality of life. We did not include any studies that evaluated microvascular disease, macrovascular disease, or any of the process measures.

##### Mortality

A single study lasting 12 months reported a single death due to cancer in the CSII arm.69 The study did not provide further information on this event or the occurrence of events in the MDI arm.69

##### HbA_1c_

As shown in Figure 17, four RCTs of at least 18 weeks in duration reported a mean decrease from baseline in HbA_1c_ in both CSII and MDI treatment groups, with the reduction greater during CSII treatment compared with MDI that was not significant (combined mean between-group difference from baseline, -0.16 percent; 95% CI, -0.42 to 0.09 percent, P=0.21).36 37 69 70 We did not find evidence of statistical heterogeneity, and no single study influenced results substantially. Egger's test (P=0.084) and the funnel plot suggested bias due to absence of small studies reporting a benefit of MDI over CSII, but a trim-and-fill analysis was unremarkable.

Figure 17 Between-group difference between CSII and MDI in how HbA_1c_ changed from baseline among adults with type 2 diabetes

CI = confidence interval; CSII = continuous subcutaneous insulin infusion; HbA_1c_ = hemoglobin A_1c_; MDI = multiple daily injections

Boxes indicate individual study point estimates. The box size denotes the weight of the study, with larger boxes contributing more to the pooled estimate. The width of the horizontal lines represents the 95% confidence intervals for each study. The diamond at the bottom of the graph indicates the 95% confidence interval for the random-effects pooled estimate.

Test for heterogeneity: Q = 0.60 with 3 degrees of freedom (p = 0.90)

Figure 17 is a forest plot type diagram summarizing the between-group difference between MDI and CSII in how HbA1c changed from baseline among adults with type 2 diabetes. Four RCTs, Raskin 2003, Herman 2005, Wainstein 2005, and Derosa 2009 are included for a combined mean between-group difference from baseline of -0.16 and a 95% confidence interval of -0.42 to 0.09, an I-squared value of 0% and a p value of 0.896. All the RCTs favor CSII.

##### Mild Hypoglycemia

Three trials reported on mild hypoglycemia in patients with type 2 diabetes randomized to MDI and CSII therapy.36 37 69 The combined risk of mild hypoglycemia was lower with CSII compared with MDI treatment across two studies but not significant (combined relative risk 0.90; 95% CI, 0.78 to 1.03; P=0.129; Figure 18).36 69 We did not find statistical evidence of heterogeneity in this meta-analysis.The availability of only two studies precluded the use of Egger's test to evaluate for publication bias. Both studies were small and showed similar effects that were not significant (Figure 18). The third study, a cross-over trial, did not provide quantitative results but concluded that mild hypoglycemia did not vary over the period of the study.37

Figure 18 Pooled relative risk of mild hypoglycemia in CSII versus MDI interventions among adults with type 2 diabetes

CI = confidence interval; CSII = continuous subcutaneous insulin infusion; MDI = multiple daily injections; RR = relative risk

Boxes indicate individual study point estimates. The box size denotes the weight of the study, with larger boxes contributing more to the pooled estimate. The width of the horizontal lines represents the 95% confidence intervals for each study. The diamond at the bottom of the graph indicates the 95% confidence interval for the random-effects pooled estimate.

Test for heterogeneity: Q = 0.02 with 1 degree of freedom (p = 0.90)

Figure 18 is a forest plot type diagram summarizing the pooled relative risk of mild hypoglycemia in MDI versus CSII interventions among adults with type 2 diabetes. The diagram displays the relative risk, 95% confidence interval, number of events of mild hypoglycemia on CSII, number of patients on CSII, number of events on MDI and number of patients on MDI. The included RCTs are Raskin 2003 with a relative risk of 0.91 and 95% confidence interval of 0.67 to 1.25 and Herman 2005 with a relative risk of 0.89 and 95% confidence interval of 0.77 to 1.04. Their combined relative risk is 0.90 with a 95% confidence interval of 0.78 to 1.03. Both RCTs favor CSII.

##### Nocturnal Hypoglycemia

In a single study, nocturnal hypoglycemia (occurring between midnight and 6 a.m.) was more common between 8 and 24 weeks in the MDI arm compared with CSII arm (percentage of patients with nocturnal hypoglycemia, 22 percent vs. 16 percent; statistical significance not reported).36 The authors described the rates of nocturnal hypoglycemia as similar between arms but did not report on statistical significance.36

##### Severe Hypoglycemia

Three RCTs reported on rates of severe hypoglycemia among patients with type 2 diabetes treated with MDI or CSII.36 37 69 In one study, no participants in either treatment group experienced severe hypoglycemia (defined by glucose less than 50 mg/dL and severe central nervous system dysfunction necessitating outside assistance or parenteral treatment).36 In the other two studies, the combined relative risk of severe hypoglycemia was 0.76 (95% CI, 0.26 to 2.19; P=0.61; Figure 19) for CSII compared with MDI treatment.37 69 We did not find statistical evidence of heterogeneity for this meta-analysis. The availability of only two studies precluded the use of Egger's test to evaluate for publication bias. Both studies were small and showed effects that were not significant (Figure 19).

Figure 19 Pooled relative risk of severe hypoglycemia in CSII versus MDI interventions among adults with type 2 diabetes

CI = confidence interval; CSII = continuous subcutaneous insulin infusion; MDI = multiple daily injections; RR = relative risk

Boxes indicate individual study point estimates. The box size denotes the weight of the study, with larger boxes contributing more to the pooled estimate. The width of the horizontal lines represents the 95% confidence intervals for each study. The diamond at the bottom of the graph indicates the 95% confidence interval for the random-effects pooled estimate.

Test for heterogeneity: Q = 0.94 with 1 degree of freedom (p = 0.33)

Figure 19 is a forest plot type diagram summarizing the pooled relative risk of severe hypoglycemia in MDI versus CSII interventions among adults with type 2 diabetes. The diagram displays the relative risk, 95% confidence interval, number of events of mild hypoglycemia on CSII, number of patients on CSII, number of events on MDI and number of patients on MDI. RCTs are Herman 2005 with a relative risk of 0.51 and 95% confidence interval of 0.13 to 1.93, Wainstein 2005 with a relative risk of 1.50 and a 95% confidence interval of 0.26 to 8.50, and Raskin 2003, which was excluded. Their combined relative risk is 0.76 with a 95% confidence interval of 0.26 to 2.19. Herman 2005 favors CSII and Wainstein 2005 favors MDI.

##### Hyperglycemia

Two studies reported hyperglycemia outcomes based on SMBG in patients with type 2 diabetes randomized to CSII or MDI.36 71 In one study, mean postprandial glucose (90 minutes after breakfast) was 167 mg/dL in the CSII arm and 192 mg/dL in the MDI arm at 24 weeks (mean between-group difference, -25 mg/dL; P=0.019).36 The authors reported that glucose measurements from the other time points were similar between treatment groups at the end of the study.36 The incidence of blood glucose greater than 350 mg/dL was higher in the MDI compared with CSII arm (26 versus six events) effecting 18 percent and 5 percent of participants in the MDI and CSII arms, respectively.36 The authors reported no treatment group differences in mean pre- (P=0.88) or post-prandial glucose (P=0.59) over 12 months in the other study.71 We did not combine the two studies reporting on hyperglycemia because one study did not provide quantitative results aside from P values.71

##### Weight

Two studies36 69 evaluated weight gain experienced by participants in MDI and CSII groups (Table 15) and did not find a significant effect of the treatments on weight gain (combined between-group difference in weight change from baseline for CSII versus MDI, -0.49 kg; 95% CI, -1.25 to 0.26 kg; P=0.20; Figure 20). We did not find statistical evidence of heterogeneity, and the availability of only two studies precluded the use of Egger's test to evaluate for publication bias.

Table 15 Weight gain in CSII versus MDI interventions among adults with type 2 diabetes

Author, Year | MDI, N | CSII, N | Timepoint (Weeks) | Weight Gain – MDI | Weight Gain – CSII | CSII Effect on Weight Gain Vs. MDI (kg) | P Value
Raskin, 2003^36^ | 61 | 66 | 24 | 0.7 | 1.7 | 1.0 | NS
Herman, 2005^69^ | 54 | 53 | 12 | 2.6 | 2.1 | -0.5 | 0.7

CSII = continuous subcutaneous injections; kg = kilograms; MDI = multiple daily injections; NS = not significant

Figure 20 Between-group difference between CSII and MDI in how weight changed from baseline among adults with type 2 diabetes

CI = confidence interval; CSII = continuous subcutaneous insulin infusion; kg = kilograms; MDI = multiple daily injections

Boxes indicate individual study point estimates. The box size denotes the weight of the study, with larger boxes contributing more to the pooled estimate. The width of the horizontal lines represents the 95% confidence intervals for each study. The diamond at the bottom of the graph indicates the 95% confidence interval for the random-effects pooled estimate.

Test for heterogeneity: Q = 0.07 with 1 degree of freedom (p = 0.79)

Figure 20 is a forest plot type diagram summarizing the between-group difference between MDI and CSII in how weight in kilograms changed among adults with type 1 diabetes. The included RCTs are Raskin 2003 and Herman 2005. The combined mean between-group difference is -0.49 with a 95% confidence interval of -1.25 to 0.26 with a p value of 0.788 and I-squared value of 0%. Raskin 2003 favors MDI while Herman 2005 favors CSII.

##### Quality of Life, Including General, Diabetes-Specific, and Treatment-Related

Two studies examined the comparative effectiveness of CSII versus MDI on general, diabetesspecific, and diabetes treatment-related QOL in adults with type 2 diabetes. One study examined general QOL using the SF-36v2 and diabetes-specific QOL using the Diabetes QOL Clinical Trials Questionnaire in 98 adults (48 in the CSII group and 50 in the MDI group) and found no difference in either QOL measure between the two groups.69 Another study used the Phase V Outcomes System Diabetes Treatment Satisfaction Questionnaire.36 This study included 127 CSII-naïve men and women over 35 years of age (66 in the CSII group and 61 in the MDI group).36 At the end of 24 weeks, there was an improvement diabetes treatment satisfaction favoring CSII.

##### Study Quality

All studies were of poor or fair quality (see Appendix E, Table 5).36 37 69 70 Our assessment of the risk of bias was limited by a lack of reporting on most quality items. Only one study reported an appropriate randomization sequence generation,36 and only one study reported appropriate allocation concealment.69 One study reported the use of an open-label design,36 and none of the studies reported if outcome assessors were masked to the intervention assignment.36 37 69 70 Two studies did not use appropriate methods for handling missing data,36 37 and two studies reported commercial support.36 69 These items were not reported in the other studies.

#### Strength of Evidence

The strength of evidence examining the comparative effectiveness of CSII versus MDI in patients with type 2 diabetes was moderate for HbA_1c_ and mild hypoglycemia but was low for severe hypoglycemia, hyperglycemia, and weight outcomes (Table 16). The evidence was insufficient for mortality, nocturnal hypoglycemia, and QOL. All included studies were RCTs, and the risk of bias was medium to high for all outcomes. We found a moderate benefit of CSII over MDI for diabetes treatment-specific QOL. Otherwise, we were unable to determine the magnitude of or found no relative effect of the interventions. The small number of studies affected our assessment of the overall strength of the evidence for the outcomes for the comparative effectiveness of CSII versus MDI in adults with type 2 diabetes.

Table 16 Numbers of studies and subjects, strength of evidence domains, magnitude of effect, and overall strength of evidence for CSII versus MDI in adults with type 2 diabetes

Outcome | Number of Studies (Participants) | Domains Pertaining to Strength of Evidence | | | | | Magnitude of Effect and Strength of Evidence
Outcome | Number of Studies (Participants) | Risk of Bias: Design/ Quality | Consistency | Directness | Precision | Publication Bias | Magnitude of Effect and Strength of Evidence
Mortality | 1 (107) | Medium | Unknown | Direct | Imprecise | Uncertain | Magnitude of effect: Unable to determine Strength of evidence: Insufficient
Microvascular outcomes | 0 | NA | NA | NA | NA | NA | Strength of evidence: Insufficient
Macrovascular outcomes | 0 | NA | NA | NA | NA | NA | Strength of evidence: Insufficient
HbA_1c_ | 4 (338) | Medium | Consistent | Direct | Precise | None | Magnitude of effect: No effect Strength of evidence: Moderate
Hyperglycemia | 2 (205) | Medium | Inconsistent | Direct | Imprecise | Uncertain | Magnitude of effect: Unable to determine Strength of evidence: Low
Mild hypoglycemia | 3 (279) | Medium | Consistent | Direct | Precise | Uncertain | Magnitude of effect: No effect Strength of evidence: Moderate
Nocturnal hypoglycemia | 1 (127) | Medium | Unknown | Direct | Imprecise | Uncertain | Magnitude of effect: Unable to determine Strength of evidence: Insufficient
Severe hypoglycemia | 3 (279) | Medium | Consistent | Direct | Imprecise | Uncertain | Magnitude of effect: No effect Strength of evidence: Low
Weight | 2 (239) | Medium | Consistent | Direct | Precise | Uncertain | Magnitude of effect: No effect Strength of evidence: Low
Ratio of basal to bolus insulin | 0 | NA | NA | NA | NA | NA | Strength of evidence: Insufficient
Frequency of adjusting insulin therapy | 0 | NA | NA | NA | NA | NA | Strength of evidence: Insufficient
Adherence to insulin therapy | 0 | NA | NA | NA | NA | NA | Strength of evidence: Insufficient
Frequency of professional or allied health visits | 0 | NA | NA | NA | NA | NA | Strength of evidence: Insufficient
General QOL | 1 (98) | High | Unknown | Direct | Imprecise | Uncertain | Magnitude of effect: No effect Strength of evidence: Insufficient
Diabetes-specific QOL | 1 (98) | High | Unknown | Direct | Imprecise | Uncertain | Magnitude of effect: No effect Strength of evidence: Insufficient
Diabetes treatment-related QOL | 1 (127) | High | Unknown | Direct | Imprecise | Uncertain | Magnitude of effect: Moderate Strength of evidence: Insufficient

HbA_1c_ = hemoglobin A_1c_; NA = not applicable; QOL = quality of life

The strength of the evidence was defined as follows: High = High confidence that the evidence reflects the true effect. Further research is unlikely to change our confidence in the estimate of the effect. Moderate = Moderate confidence that the evidence reflects the true effect. Further research may change our confidence in the estimate of the effect and may change the estimate. Low = Low confidence that the evidence reflects the true effect. Further research is likely to change our confidence in the estimate of the effect and is likely to change the estimate. Insufficient = Evidence is unavailable, does not permit a conclusion, or consists of only one study with high risk of bias.

#### Applicability

Few studies compared the effect of CSII with MDI in patients with type 2 diabetes. The evidence was insufficient to make definitive conclusions about the relative effects of these therapies on hyperglycemia and weight. Existing studies were small, of fair or poor quality, and did not report on most quality items of interest.

Studies did not generally report on items of interest in determining the applicability of the literature to the general population with type 2 diabetes. Most study participants were white when this characteristic was reported, and a single study focused on participants 60 years of age and older. Study setting was described in two of the trials, which took place in outpatient clinics. Studies lasted between 18 weeks and 12 months. The mean baseline HbA_1c_ was approximately 8 to 9 percent across the studies. The duration of diabetes at enrollment was greater than 10 years in the two studies reporting this. All studies required a history of insulin treatment prior to enrollment, and a single study reported training on insulin pump use.

### Comparative Effectiveness of CSII Versus MDI in Pregnant Women With Pre-Existing Type 1 Diabetes

#### Key Points and Evidence Grades

Six observational studies evaluated CSII versus MDI therapy in pregnant women with type 1 diabetes. Two were prospective studies,72 73 and four were retrospective cohort studies.74-77

- The strength of evidence was low comparing CSII with MDI for HbA_1c_. Six studies, all observational, reported an improvement in HbA_1c_ in both the CSII and MDI groups during pregnancy without any significant difference between groups in HbA_1c_ in any of the trimesters. The mean between-group difference in third trimester HbA_1c_ values were 0.2 (95% CI, -0.3 to 0.7),75 -0.4 (95% CI, -0.8 to 0.04),74 0.6 (95% CI, -0.7 to 1.9),72 -0,3 (95% CI, -0.6 to -0.03),76 0.2 (95% CI, -0.2 to 0.6),73 and 0.4 (95% CI, -0.9 to 1.7).77
- The strength of the evidence comparing CSII with MDI among pregnant women with pre-existing diabetes was insufficient for all other maternal and neonatal outcomes.
- Meta-analysis of four retrospective studies for rate of cesarean section showed a pooled RR of 1.01 (95% CI, 0.86 to 1.20) which was not significant.74-77
- Meta-analysis of three retrospective studies for rate of severe hypoglycemia showed a pooled RR of 0.78 which was not significant (95% CI, 0.23 to 2.65).75-77
- There was no difference in weight gain between the CSII and MDI intervention groups in the three studies that examined this outcome. The mean between-group difference in weight gain was 1.9 kg (95% CI, -0.9 to 4.7 kg) in one study75 and 0.1 kg (95% CI, -2.4 to 2.6 kg) in another study.73 The third study reported a median weight gain of 13.5 kg in the CSII group and 13.9 kg in the MDI group.77
- Gestational age at delivery ranged from 36.6 weeks to 37.5 weeks for MDI and from 36.3 weeks to 36.6 weeks for CSII, and there was no significant difference between the MDI and CSII groups.72 74-76
- Meta-analysis of four retrospective cohort studies for frequency of neonatal hypoglycemia showed a pooled RR of 1.10 (95% CI, 0.86 to 1.20).74-77
- Meta-analysis of three retrospective cohort studies showed a pooled mean between-group difference in birth weight of 107.2g which was not significant (95% CI, -86.6 to 295.9 g).74-76
- Meta-analysis for only two retrospective cohort studies for major congenital anomalies showed a pooled RR of 2.12 favoring MDI that was not significant (95% CI, 0.38 to 11.77).76 77
- Three studies found no difference in minor congenital anomalies between the MDI and CSII groups. There were no minor congenital anomalies in either group in two studies,72 75 and rates of minor congenital anomalies and pregnancy termination rates were 2.3 percent (2/86 patients) in the MDI group and 13 percent (4/30 patients) in the CSII group (P=0.05).74
- Meta-analysis on two retrospective cohort studies for admission to the neonatal intensive care unit showed a pooled RR of 0.84 that was not significant (95% CI, 0.43 to 1.68).75 76
- Meta-analysis of four retrospective cohort studies for preterm delivery showed a pooled relative risk of 0.98 that was not significant (95% CI, 0.67 to 1.43).74-77
- Four studies reported on stillbirth rates. Three reported that there were no stillbirths in either group,72 75 77 and one study reported having one stillbirth in MDI group.74
- Three studies reported on neonatal mortality rate. Each group had one neonatal death in one study,74 no neonatal deaths in either group in another,72 and a 0 percent neonatal mortality rate in the MDI group and 2.7 percent rate in the CSII group in a third study.77
- In one study, the perinatal mortality rate was 3 percent in the CSII group and 4 percent in the MDI group.73 Another study reported a 0 percent perinatal mortality rate in MDI group and a 2.7 percent rate in CSII group.77
- We did not find any studies in pregnant women with type 1 diabetes mellitus that evaluated maternal mortality, microvascular or macrovascular disease, quality of life, or any of the process measures, or birth trauma. The strength of evidence is insufficient for these outcomes.

#### Study Design

All six studies evaluating CSII versus MDI therapy in pregnant women with pre-existing type 1 diabetes were observational (see Appendix E, Table 1).72-77 Four were retrospective followup studies.74-77 One study enrolled patients from an outpatient clinic,75 and another study enrolled patients from a university clinic.74 No studies were conducted in the U.S. Studies were conducted in Italy,75 76 Poland,74 U.K.,72 France,73 and Spain.77 Women were given the choice to select either MDI or CSII in one study.72 In all six studies, women were followed throughout the pregnancy either prospectively or retrospectively. Some relevant details of study designs were not uniformly reported in these studies.

#### Population Characteristics

The number of participants per arm ranged from 18 to 86 pregnant women (see Appendix E, Table 2).72-77 Two studies reported having 100 percent Caucasian women.74 75 All these patients were pregnant women with pre-existing type 1 diabetes and they entered the study at various stages of pregnancy. One study reported having one of 17 pregnant women with pre-existing type 2 diabetes in CSII arm and one of 23 with type 2 diabetes in MDI arm.72 Two studies reported that CSII was started 6 months before participants became pregnant.75 76 Two studies reported enrolling some of the study participants on CSII before pregnancy.73 74 The mean age of the study populations ranged from 26 to 31 years. The mean HbA_1c_ during the first trimester ranged from 6.9 to 7.8 percent72-77 and the mean BMI, reported in five studies, ranged from 21.8 to 23.7 kg/m^2^. There is no statistically significant difference between groups on baseline weight.73-76 The duration of diabetes was reported in four studies and ranged from 7.7 to 16.5 years, with some in the CSII arm having a significantly longer duration of diabetes.73-76 None of the studies reported whether participants withdrew.

#### Interventions

The CSII arm varied across studies. Four studies reported that insulin lispro was used primarily for CSII arm,72 74 76 77 while the type of insulin was not specified in one study.73 One study reported that insulin lispro was used in 90 percent of the CSII group and in 30 percent of the MDI group, human insulin was used in the rest of the subjects in the MDI arm and everyone in the MDI group used neutral protamine Hagedorn (NPH) insulin.74 In the MDI groups, NPH insulin was used in three studies74 75 77 and long-acting insulin was used in two other studies.72 76 Three studies reported using four or more insulin injections daily in the MDI arms.72 73 75 One study reported having a total of four arms, two in each group (MDI and CSII). That study included a regular insulin treated arm and lispro treated arm in each group. We have included only subjects treated with lispro in each arm for further analysis to be consistent with other included studies.77 Four studies reported providing training prior to initiating insulin pump therapy in the CSII treated group.72 73 75 77 The mean duration of therapy was reported in three studies and it ranged from 36 to 40 weeks.72 74 75

Reported glycemic targets varied across studies. One study specified a HbA_1c_ target of 6.5 percent,72 one study specified a pre-prandial blood glucose target of 90 mg/dL and a post-prandial blood glucose target of 130 mg/dL,75 and another study specified a pre-prandial blood glucose target of 59.4 to 90 mg/dL.74 Only one study reported having guidelines regarding management of blood sugar between visits.72 One study reported calculating insulin requirement based on blood glucose levels before and after meals and at bed time.77 Four studies reported starting CSII prenatally in all participants75 76 or a portion of their participants (66 percent73 and 46 percent74).

#### Maternal Outcomes

Details of the outcomes are reported in Appendix E, Table 4. The included studies reported on the following maternal outcomes: HbA_1c_, cesarean sections, hypoglycemia, and weight gain. We did not find any studies of pregnant women with type 1 diabetes mellitus that evaluated maternal mortality, microvascular or macrovascular disease, quality of life, or any of the process measures.

##### HbA_1c_

All six studies reported an improvement in HbA_1c_ in both the CSII and MDI arms during pregnancy from the first to third trimesters. However, the studies reported no statistically significant difference between groups in HbA_1c_ in any of the trimesters (Table 17).72-77 We did not perform meta-analysis because only two studies reported baseline HbA_1c_. One was a retrospective study and the other was a prospective study.

Table 17 Differences in HbA_1c_ by trimester in the CSII and MDI arms in women with pre-existing type 1 diabetes

Author, year | Intervention Arms, N | HbA_1c_ (%) First Trimester | HbA_1c_ (%) Second Trimester | HbA_1c_ (%) Third Trimester | Statistical Difference Between Groups
Volpe, 2010^75^ | MDI, 22 | 7.4 | - | 6.1 | NS
Volpe, 2010^75^ | CSII, 20 | 6.9 | - | 6.3 | NS
Cypryk, 2008^74^ | MDI, 86 | 7.8 | 6.7 | 6.8 | NS
Cypryk, 2008^74^ | CSII, 30 | 7.4 | 6.5 | 6.4 | NS
Kernaghan, 2008^72^ | MDI, 18 | 7.3 | 6.6 | 6.44 | NS
Kernaghan, 2008^72^ | CSII, 24 | 6.95 | 6.3 | 6.63 | NS
Hieronimus, 2005^73^ | MDI, 23 | 7.6 | 6.6 | 6.4 | NS
Hieronimus, 2005^73^ | CSII, 33 | 7.5 | 6.34 | 6.6 | NS
Bruttomesso 2011^76^ | MDI, 44 | 7.2 | 6.7 | 6.5 | NS
Bruttomesso 2011^76^ | CSII, 100 | 6.6 | 6.1 | 6.2 | NS
Chico, 2011^77^ | MDI, 16 | 6.1 | 5.8 | 5.9 | NS
Chico, 2011^77^ | CSII, 59 | 6.3 | 6.0 | 6.3 | NS

CSII = continuous subcutaneous injections; HbA_1c_ = hemoglobin A_1c_; MDI = multiple daily injections; NS = not significant

##### Rate of Cesarean Sections

Five studies reported on the rate of cesarean section in the CSII and MDI arms (Table 18). Three studies showed no difference in the rates of cesarean sections between groups.74-76 and two studies showed a significantly higher rate of cesarean section in CSII compared with the MDI group.73 77 Another study reported a high rate of cesarean section in women in CSII arm compared with women in MDI arm, but the study did not report further calculations between groups.77

Table 18 Rates of cesarean section between CSII and MDI arms in women with pre-existing type 1 diabetes

Author, Year | MDI | CSII | Statistical Significance
Volpe, 2010^75^ | 94% | 95% | NS
Cypryk, 2008^74^ | 46% | 69.2% | 0.235
Hieronimus, 2005^73^ | 34.6% | 70% | 0.016
Bruttomesso 2011^76^ | 73.2% | 77.4% | NS
Chico, 2011^77^ | 38.5% | 67.6% | -

CSII = continuous subcutaneous insulin infusion; MDI = multiple daily injections; NS = not significant

We performed meta-analysis for four retrospective cohort studies that reported on the rate of cesarean section and it showed a pooled RR of 1.02 that was not significant (95% CI, 0.86 to 1.20) (see Figure 21).74-77 There was no evidence of statistical heterogeneity, and no single study significantly influenced results. We did not find any evidence of publication bias. One study was not included in this meta-analysis because it was a prospective cohort study.73This study showed a significantly higher rate of cesarean sections in the CSII group compared with the MDI group.

Figure 21 Pooled relative risk of cesarean delivery in CSII versus MDI interventions among pregnant women with pre-existing type 1 diabetes

CI = confidence interval; CSII = continuous subcutaneous insulin infusion; MDI = multiple daily injections; RR = relative risk

Boxes indicate individual study point estimates. The box size denotes the weight of the study, with larger boxes contributing more to the pooled estimate. The width of the horizontal lines represents the 95% confidence intervals for each study. The diamond at the bottom of the graph indicates the 95% confidence interval for the random-effects pooled estimate.

Test for heterogeneity: Q = 4.53 with 3 degrees of freedom (p = 0.21)

Figure 21 is a forest plot type diagram summarizing the pooled relative risk of cesarean delivery in MDI versus CSII interventions among pregnant women with pre-existing type 1 diabetes. The included publications are Cypryk 2008, Chico 2010, Volpe 2010, and Bruttomesso 2011. The table shows the relative risk and 95 percent confidence interval, the number of events for CSII, the n value for CSII, the number of events for MDI, and the n value for MDI. Cypryk 2008 favors CSII, while Chico 2010 and Bruttomesso favor MDI and Volpe 2010 is at 1. The overall relative risk is 1.02 with a 95 percent confidence interval of 0.86 to 1.20.

##### Maternal Hypoglycemia

Three studies reported that the severe hypoglycemia rates did not differ between the MDI and CSII arms.73 75 76 We performed meta-analysis for four retrospective cohort studies for maternal hypoglycemia and it showed a pooled RR of 0.78 that was not significant (95% CI, 0.23 to 2.65) (Figure 22).74-77 There was no evidence of statistical heterogeneity, and no single study influenced the results. Analysis of the funnel plot suggested that there may be some publication bias. One study was excluded from the meta-analysis because it was a prospective cohort study.78 This study did not define hypoglycemia, but reported rates of 9 percent in each group.

Figure 22 Pooled relative risk of severe maternal hypoglycemia in CSII versus MDI interventions among pregnant women with pre-existing type 1 diabetes

CI = confidence interval; CSII = continuous subcutaneous insulin infusion; MDI = multiple daily injections; RR = relative risk

Boxes indicate individual study point estimates. The box size denotes the weight of the study, with larger boxes contributing more to the pooled estimate. The width of the horizontal lines represents the 95% confidence intervals for each study. The diamond at the bottom of the graph indicates the 95% confidence interval for the random-effects pooled estimate.

Test for heterogeneity: Q = 0.10 with 2 degrees of freedom (p = 0.95)

Figure 22 is a forest plot type diagram summarizing the pooled relative risk of sever maternal hypoglycemia in MDI versus CSII interventions among pregnant women with pre-existing type 1 diabetes. The studies included in the analysis are Volpe 2010, Bruttomesso 2011, Chico 2010, and. Cypryk 2008. The table shows the relative risk and 95 percent confidence interval, the number of events for CSII, the n value for CSII, the number of events for MDI, and the n value for MDI. Cypryk 2008 was excluded, Volpe 2010 favors MDI, and Bruttomesso 2011 and Chico 2010 favor CSII. The overall relative risk is 0.78 with a 95 percent confidence interval of 0.23 to 2.65.

##### Maternal Weight Gain

Three studies measured weight gain in pregnant women with pre-existing diabetes treated with MDI and CSII.73 75 77 The difference in weight gain between the CSII and MDI treatment arms was not statistically significant in all three studies.73 75 77 We did not perform meta-analysis because only three studies reported this outcome, two were retrospective cohort studies and one was a prospective study.

#### Neonatal Outcomes

Details of the outcomes are reported in Appendix E, Table 4. The included studies reported on the following neonatal outcomes: gestational age at delivery, neonatal hypoglycemia, major and minor congenital anomalies, preterm delivery, admission to a neonatal intensive care unit, stillbirth, neonatal and perinatal mortality. None of the studies reported on birth trauma.

##### Gestational Age at Delivery

Four studies reported gestational age at delivery, with no difference in gestational age at delivery between the MDI and CSII groups.72 74-76 Gestational ages at delivery for MDI versus CSII were 36.3 versus 36.3 weeks,75 36.3 versus 36.6 weeks (P=0.58),74 37.5 versus 36.5 weeks (P=0.28),72 and 36.6 versus 36.7 weeks.76

##### Frequency of Neonatal Hypoglycemia

Three studies reported rates of neonatal hypoglycemia with no difference between the CSII and MDI groups.74-76 Neonatal hypoglycemia was defined as a blood glucose less than 40 mg/dL in three studies,74 76 79 and was not defined in another study.75 We performed meta-analysis for four retrospective cohort studies for frequency of hypoglycemia and it showed a pooled RR of 1.10 which was not significant (95% CI, 0.86 to 1.20) (see Figure 23).74-77 There was no evidence of statistical heterogeneity, and no single study significantly influenced results. We did not detect publication bias.

Figure 23 Pooled relative risk of neonatal hypoglycemia in CSII versus MDI interventions among infants born to women with pre-existing type 1 diabetes

CI = confidence interval; CSII = continuous subcutaneous insulin infusion; MDI = multiple daily injections; RR = relative risk

Boxes indicate individual study point estimates. The box size denotes the weight of the study, with larger boxes contributing more to the pooled estimate. The width of the horizontal lines represents the 95% confidence intervals for each study. The diamond at the bottom of the graph indicates the 95% confidence interval for the random-effects pooled estimate.

Test for heterogeneity: Q = 0.27 with 3 degrees of freedom (p = 0.97)

Figure 23 is a forest plot type diagram summarizing the pooled relative risk of neonatal hypoglycemia in MDI versus CSII interventions among infants born to women with pre-existing type 1 diabetes. The studies included for analyses are Cypryk 2008, Chico 2010, Volpe 2010, and Bruttomesso 2011. The table shows the relative risk and 95 percent confidence interval, the number of events for CSII, the n value for CSII, the number of events for MDI, and the n value for MDI. All but Volpe 2010 favor MDI. The overall relative risk is 1.10 with a 95 percent confidence interval of 0.63 to 1.92.

##### Birth Weight

Four studies reported mean birth weight, which ranged from 3101 to 3767 grams, in the two intervention arms.73-76 One study reported a significantly higher birth weight with CSII compared with MDI,73 while two other studies found no difference between the two groups (Table 19).74 76 We performed meta-analysis for three retrospective cohort studies for birth weight and it showed a pooled mean between-group difference of 107.18 g which was not significant (95% CI, -81.6 to 295.9 g) (Figure 24).74-76 There was no evidence of statistical heterogeneity, and no single study significantly influenced results. Publication bias was not detected. We excluded one study from the meta-analysis because it was a prospective cohort study.73 This study reported a significantly higher mean birth weight with CSII compared with MDI.

Table 19 Neonatal birth weights in the CSII and MDI arms in women with pre-existing type 1 diabetes

Author, Year | Weight MDI (g) | Weight CSII (g) | P Value
Volpe, 2010^75^ | 3,101 | 3,295 | Not reported
Cypryk, 2008^74^ | 3,270 | 3,191 | 0.86
Hieronimus, 2005^73^ | 3,384 | 3,767 | 0.036
Bruttomesso 2011^76^ | 3,243 | 3,390 | NS

CSII = continuous subcutaneous insulin infusion; g = grams; MDI = multiple daily injections; NS = not significant

Figure 24 Between-group difference between CSII and MDI in birthweight among infants born to women with pre-existing type 1 diabetes

CI = confidence interval; CSII = continuous subcutaneous insulin infusion; g = gram; MDI = multiple daily injections

Boxes indicate individual study point estimates. The box size denotes the weight of the study, with larger boxes contributing more to the pooled estimate. The width of the horizontal lines represents the 95% confidence intervals for each study. The diamond at the bottom of the graph indicates the 95% confidence interval for the random-effects pooled estimate.

Test for heterogeneity: Q = 0.27 with 3 degrees of freedom (p = 0.97)

Figure 24 is a forest plot type diagram summarizing the between-group difference between MDI and CSII in birthweight among infancts born to women with pre-existing type 1 diabetes. The studies included for analysis are Cypryk 2008, Volpe 2010, and Bruttomesso 2011. All but Cypryk 2008 favor MDI. The overall mean difference is 107.18 with a 95 percent confidence interval of -81.56 to 295.91, an I-squared value of 0 and a p value of 0.587.

##### Major Congenital Anomalies

Four studies reported on major congenital anomalies in pregnant women treated with CSII versus MDI.73 75-77 We performed meta-analysis for two retrospective cohort studies and it showed a pooled RR for major congenital anomalies of 2.12 favoring MDI that was not significant (95% CI, 0.38 to 11.77) (Figure 25).76 77 We did not find evidence of statistical heterogeneity, and the availability of only two studies precluded the use of Egger's test to evaluate for publication bias. One study was not included in the meta-analysis because there were no major congenital anomalies in either intervention arm.75 The other study was not included because it was a prospective cohort study.73 This study reported no difference in major congenital anomalies between treatment arms (12 percent in the CSII arm vs. 13 percent in the MDI arm).73

Figure 25 Pooled relative risk of major congenital anomalies in CSII versus MDI interventions among infants born to women with pre-existing type 1 diabetes

CI = confidence interval; CSII = continuous subcutaneous insulin infusion; MDI = multiple daily injections; RR = relative risk

Boxes indicate individual study point estimates. The box size denotes the weight of the study, with larger boxes contributing more to the pooled estimate. The width of the horizontal lines represents the 95% confidence intervals for each study. The diamond at the bottom of the graph indicates the 95% confidence interval for the random-effects pooled estimate.

Test for heterogeneity: Q = 0.00 with 1 degree of freedom (p = 0.96)

Figure 25 is a forest type plot summarizing the pooled relative risk of major congential anomalies in MDI versus CSII interventions among infants bornto women with pre-existing type 1 diabetes. The table shows the relative risk and 95 percent confidence interval, the number of events for CSII, the n for CSII, the number of events for MDI, and the n for MDI. Volpe 2010 was excluded, and both Chico 2010 and Bruttomesso 2011 favor MDI. The overall relative risk is 2.12 with a 95 percent confidence interval of 0.38 to 11.77.

##### Minor Congenital Anomalies

Three studies reported information about minor congenital anomalies. Two studies reported that there were no minor congenital anomalies in either intervention arm.72 75 One study reported minor congenital anomalies plus terminated pregnancy rates of 2.3 percent (2 out of 86 patients) in the MDI arm and 13 percent (four out of 30 patients) in the CSII arm (P=0.05).74

##### Neonatal Intensive Care Unit Admissions

Three studies reported on neonatal intensive care unit admissions.73 75 76 We performed meta-analysis for two retrospective cohort studies for neonatal intensive care unit admissions and it showed a pooled RR of 0.84 that was not significant (95% CI, 0.43 to 1.68) (Figure 26).75 76 There was not evidence of statistical heterogeneity, and the availability of only two studies precluded the use of Egger's test to evaluate for publication bias. One study was not included the in the meta-analysis because it was a prospective cohort study.73 This study reported neonatal intensive care unit admission rates of 35 percent in the MDI group and 33 percent in the CSII group.73

Figure 26 Pooled relative risk of NICU admission in CSII versus MDI interventions among infants born to women with pre-existing type 1 diabetes

CI = confidence interval; CSII = continuous subcutaneous insulin infusion; MDI = multiple daily injections; NICU = neonatal intensive care unit; RR = relative risk

Boxes indicate individual study point estimates. The box size denotes the weight of the study, with larger boxes contributing more to the pooled estimate. The width of the horizontal lines represents the 95% confidence intervals for each study. The diamond at the bottom of the graph indicates the 95% confidence interval for the random-effects pooled estimate.

Test for heterogeneity: Q = 0.14 with 1 degree of freedom (p = 0.71)

Figure 26 is a forest plot type diagram summarizing the pooled relative risk of NICU admission in MDI versus CSII interventions among infants born to women with pre-existing type 1 diabetes. The two studies included in the analysis are Volpe 2010 and Bruttomesso 2011. The table shows the relative risk and 95 percent confidence interval, the number of events for CSII, the n for CSII, the number of events for MDI, and the n for MDI. The overall relative risk is 0.84 with a 95 percent confidence interval of 0.43 to 1.68.

##### Preterm Delivery Rate

Preterm delivery rate was reported in five studies (Table 20).73-77 The definition of preterm delivery was not reported uniformly. We performed meta-analysis for four retrospective cohort studies for preterm delivery rate and it showed a pooled RR of 0.98 that was not significant (95% CI, 0.67 to 1.43) (Figure 27).74-77 There was no evidence of statistical heterogeneity, and no single study substantially influenced the results. We excluded one study from the meta-analysis because it was a prospective cohort study.73 This study reported no significant difference between the treatment groups.73

Table 20 Rates of preterm delivery between CSII and MDI arms in women with pre-existing type 1 diabetes

Author, Year | MDI Group | CSII Group | Statistical Difference Between Groups
Volpe, 2010^75^ | 40 | 33 | NS
Cypryk, 2008^74^ | 21.8 | 24 | NS
Hieronimus, 2005^73^ | 17.4 | 18 | NS
Bruttomesso, 2011^76^ | 34.2 | 32.3 | NS
Chico, 2011^77^ | 7.7 | 13.5 | -

CSII = continuous subcutaneous insulin infusion; MDI = multiple daily injections; NS = not significant

Figure 27 Pooled relative risk of preterm delivery in CSII versus MDI interventions among pregnant women with pre-existing type 1 diabetes

CI = confidence interval; CSII = continuous subcutaneous insulin infusion; MDI = multiple daily injections; RR = relative risk

Boxes indicate individual study point estimates. The box size denotes the weight of the study, with larger boxes contributing more to the pooled estimate. The width of the horizontal lines represents the 95% confidence intervals for each study. The diamond at the bottom of the graph indicates the 95% confidence interval for the random-effects pooled estimate.

Test for heterogeneity: Q = 0.82 with 3 degrees of freedom (p = 0.85)

Figure 27 is a forest plot type diagram summarizing the pooled relative risk of preterm delivery in MDI versus CSII interventions among pregnant women with pre-existing type 1 diabetes. The included studies are Cypryk 2008, Volpe 2010, Chico 2010, and Bruttomesso 2011. The table shows the relative risk and 95 percent confidence interval, the number of events for CSII, the n for CSII, the number of events for MDI, and the n for MDI. Cypryk 2008 and Chico 2010 favor MDI while Volpe 2010 and Bruttomesso 2011 favor CSII. The overall relative risk is 0.98 with a 95 percent confidence interval of 0.68 to 1.43.

##### Stillbirth Rate

Four studies reported on stillbirth rate. One study reported only one stillbirth in the MDI group74 and three studies reported no stillbirths in either group.72 75 77

##### Neonatal Mortality

Three studies reported on neonatal mortality rate. Each group had one neonatal death in one study,74 no neonatal deaths in either group in another,72 and a 0 percent neonatal mortality rate in the MDI group and 2.7 percent rate in the CSII group in a third study.77

##### Perinatal Mortality Rate

Two studies reported on perinatal mortality rate. In one study, perinatal mortality was 3 percent in the CSII group and 4 percent in the MDI group.73 Another study reported a 0 percent perinatal mortality rate in the MDI group and 2.7 percent in the CSII group.77

##### Study Quality

All studies were of poor to fair quality (see Appendix E, Table 6).72-77 Most studies had incomplete descriptions of study setting, population, intervention, followup, and outcomes. One study did not report eligibility criteria.73 Three studies reported providing training prior to starting insulin pump therapy in CSII treated group. None of the studies described details of loss to followup.

#### Strength of Evidence

The strength of evidence examining the comparative effectiveness of CSII versus MDI in women with pre-existing type 1 diabetes was low for the outcome of HbA_1c_ and insufficient for the other outcomes (Table 21). Because all studies were observational and there were no RCTs, the risk of bias was medium to high. For outcomes examined, data were insufficient to determine the precision of effect estimates.

Table 21 Number of studies and subjects, strength of evidence domains, magnitude of effect, and overall strength of evidence for CSII versus MDI in pregnant women with pre-existing type 1 diabetes

Outcome | Number of Studies (Participants) | Domains Pertaining to Strength of Evidence | | | | | Magnitude of Effect and Strength of Evidence
Outcome | Number of Studies (Participants) | Risk of Bias: Design/ Quality | Consistency | Directness | Precision | Publication Bias | Magnitude of Effect and Strength of Evidence
HbA_1c_ | 6 (475) | Medium to High | Consistent | Direct | Cannot determine | Uncertain | Magnitude of effect: Small Strength of evidence: Low
Rate of cesarean section | 5 (435) | Medium to High | Consistent | Direct | Precise | Uncertain | Magnitude of effect: Unable to determine Strength of evidence: Insufficient
Maternal hypoglycemia | 4 (229) | Medium to High | Consistent | Direct | Imprecise | Uncertain | Magnitude of effect: Unable to determine Strength of evidence: Insufficient
Maternal weight gain | 3 (185) | Medium to High | Consistent | Direct | Cannot determine | Uncertain | Magnitude of effect: Unable to determine Strength of evidence: Insufficient
Gestational age at delivery | 4 (336) | Medium to High | Consistent | Direct | Cannot determine | Uncertain | Magnitude of effect: Unable to determine Strength of evidence: Insufficient
Birth weight | 4 (360) | Medium to High | Unknown | Direct | Cannot determine | Uncertain | Magnitude of effect: Unable to determine Strength of evidence: Insufficient
Frequency of neonatal hypoglycemia | 4 (379) | Medium to high | Consistent | Direct | Imprecise | Uncertain | Magnitude of effect: Unable to determine Strength of evidence: Insufficient
Minor congenital anomalies | 3 (192) | Medium to High | Unknown | Direct | Cannot determine | Uncertain | Magnitude of effect: Unable to determine Strength of evidence: Insufficient
Major congenital anomalies | 4 (319) | Medium to High | Unknown | Direct | Imprecise | Uncertain | Magnitude of effect: Unable to determine Strength of evidence: Insufficient
NICU admissions | 3 (244) | Medium to High | Unknown | Direct | Imprecise | Uncertain | Magnitude of effect: Unable to determine Strength of evidence: Insufficient
Preterm delivery | 4 (465) | Medium to High | Unknown | Direct | Imprecise | Uncertain | Magnitude of effect: Unable to determine Strength of evidence: Insufficient
Stillbirths | 4 (277) | Medium to High | Unknown | Direct | Cannot determine | Uncertain | Magnitude of effect: Unable to determine Strength of evidence: Insufficient
Neonatal mortality | 3 (233) | Medium to High | Unknown | Direct | Cannot determine | Uncertain | Magnitude of effect: Unable to determine Strength of evidence: Insufficient
Perinatal mortality | 2 (131) | Medium to High | Unknown | Direct | Cannot determine | Uncertain | Magnitude of effect: Unable to determine Strength of evidence: Insufficient

HbA_1c_ = hemoglobin A_1c_; NICU = neonatal intensive care unit

The strength of the evidence was defined as follows: High = High confidence that the evidence reflects the true effect. Further research is unlikely to change our confidence in the estimate of the effect. Moderate = Moderate confidence that the evidence reflects the true effect. Further research may change our confidence in the estimate of the effect and may change the estimate. Low = Low confidence that the evidence reflects the true effect. Further research is likely to change our confidence in the estimate of the effect and is likely to change the estimate. Insufficient = Evidence is unavailable, does not permit a conclusion, or consists of only one study with high risk of bias.

#### Applicability

All studies were observational with limited descriptions of study methodology, study populations, intervention, and outcomes. They were all small studies done in the U.K., Poland, France, Spain, and Italy. Two studies in Italy did not report on inclusion of non-Caucasian participants. The mean age of study participants was 26 to 31 years with most participants in the CSII group being enrolled into the studies prior to becoming pregnant. Most participants had diabetes duration of 7.7 to 13.9 years, with participants in the CSII groups having the longest duration of diabetes. There was a lack of consistency in reporting of the glycemic targets among the studies.

## Key Question 2 In patients receiving intensive insulin therapy (MDI or CSII), does the type of glucose monitoring (rt-CGM vs. SMBG) have a differential effect on process measures, intermediate outcomes, and clinical outcomes in patients with diabetes mellitus?

### Comparative Effects of rt-CGM and SMBG Among Patients With Type 1 Diabetes

#### Key Points and Evidence Grades

- The strength of evidence was high favoring rt-CGM over SMBG for their effects on HbA_1c_. Mean between-group difference in how HbA_1c_ changed from baseline was -0.30 percent (95% CI, -0.37 to -0.22 percent, P<0.001). In the sensitivity analysis that only included studies with more than 60 percent of compliance rate (seven estimates) there was a greater HbA_1c_ reduction (mean between-group difference from baseline, -0.36 percent; 95% CI, -0.44 to -0.27 percent). A meta-analysis of four studies in children and adolescents age 18 years or younger showed a significant combined mean between-group difference in how HbA_1c_ changed from baseline of -0.26 percent favoring rt-CGM (95% CI, -0.46 to -0.06 percent).
- The strength of evidence was moderate comparing rt-CGM with SMBG for nonsevere hypoglycemia. A meta-analysis of 4 studies (6 estimates) showed no difference between the rt-CGM and SMBG groups in time spent in the hypoglycemic range, defined by glucose level less than 70 mg/dL. The mean between-group difference was -2.11 minutes/day (95% CI, -5.66 to 1.44 minutes/day).
- The strength of evidence was low suggesting no difference in severe hypoglycemia rates between the rt-CGM and SMBG intervention groups (pooled RR, 0.95; 95% CI, 0.53 to 1.69). Two of these trials reported severe hypoglycemia data specifically in pediatric populations. In one study, severe hypoglycemia was less common in pediatric patients using rt-CGM than pediatric patients using SMBG alone (SMBG 4/78 vs. rt-CGM 0/76, P=0.046).80 In contrast, the pediatric subgroup (ages 8-14 years) of another study showed a similar incidence of severe hypoglycemia in both arms (SMBG 6/58 vs. rt-CGM 4/56, P=0.74).27
- The strength of the evidence comparing rt-CGM with SMBG for hyperglycemia was moderate. A meta-analysis of 4 studies (6 estimates) indicated a significant reduction in time spent in hyperglycemic range, defined by glucose level greater than 180 mg/dL, with the mean between-group difference of -68.56 minutes/day favoring rt-CGM (95% CI, -101.17 to -35.96).
- The strength of the evidence comparing rt-CGM with SMBG was low for the ratio of basal to bolus insulin. One study reported that the basal rate was a higher proportion of the total daily insulin dose in the rt-CGM compared with the SMBG intervention group (mean between-group difference in final basal rate, 4.3 percent; 95% CI, 0.8 to 7.8 percent).80 In contrast, a second study reported a higher percentage of insulin delivered as bolus in the rt-CGM group compared with the SMBG group (mean between-group difference in final percentage of insulin delivered as bolus, -4.0 percent; 95% CI, -9.3 to 1.3 percent).81
- The strength of evidence was low comparing rt-CGM with SMBG for general QOL. One study found no difference in parental satisfaction between the two intervention arms (mean between-group difference in change from baseline in World Health Organization Well Being Index-5 mother's well-being score, -2.7; 95% CI, -14.2 to 8.8) at 12 months.80 The other study assessed general QOL using the Short Form-12 and found an improvement on the Physical Component Score favoring rt-CGM (mean between-group difference in chage from baseline, 1.4; 95% CI, -1.5 to 4.3) but no difference between the intervention groups on the Mental Component Score (mean between-group difference in change from baseline, -1.6; 95% CI, -5.9 to 2.7) at 26 weeks.82
- The strength of evidence was low comparing rt-CGM with SMBG for diabetes-specific QOL. There was no difference in diabetes-specific QOL between the rt-CGM and SMBG intervention arms in either study (mean between-group difference in the change from baseline in Problem Areas in Diabetes score, -0.9; 95% CI, -7.9 to 6.1 at 26 weeks82 and mean difference between-group difference in the change from baseline Diabetes Quality of Life score, -3.0; 95% CI, -6.6 to 0.6).83
- The strength of the evidence comparing rt-CGM with SMBG for diabetes treatment-related QOL was insufficient. There was a lower fear of hypoglycemia favoring rt-CGM (mean between-group difference in change from baseline score, -2.3; 95% CI, -8.2 to 3.6).82
- There was insufficient strength of evidence evaluating the effects of rt-CGM vs. SMBG in terms of mortality, microvascular or macrovascular disease, weight, or any other process measure, as we found no studies reporting on these outcomes.

#### Study Design

Nine studies evaluated rt-CGM versus SMBG in children and adults with type 1 diabetes (see Appendix E, Table 1).27 80 81 83-88 They were conducted in diverse countries, including three in the U.S.,27 84 86 four in multiple countries,80 83 87 88 one in France,81 and one in Australia.85 Studies varied in their sources of support—seven received industry support,80 81 84-88 and three received other sources of support.27 83 85 None received government funding.

Of the nine studies, eight were parallel arm RCTs27 80 81 84-88 and one was a randomized cross-over trial.83 Four studies included a run-in period,27 84 86 88 and five did not.80 81 83 85 87 Enrollment in five studies started and ended after 2006,^27^ 80 81 84 88 but other studies did not report the dates of enrollment period.83 85-87 The median followup time for all studies was 24 weeks, with a range of 12 to 52 weeks. Six studies reported the number of patients screened.80 81 85-88 These studies enrolled over half of the patients that they screened with a median of 132 patients (range 13 to 322). The number of patients screened was not reported for three studies.27 83 84 Patients were recruited from referral clinics in two studies.81 85 No studies reported excluding pregnant patients specifically. Most studies had entry criteria based on HbA_1c_: some studies excluded patients based on HbA_1c_ greater than 7 percent,84 greater than 7.5 percent,86 88 greater than 8.1 percent,87 greater than 8.5 percent,85 or less than 8 percent.81 One study enrolled patients with HbA_1c_ between 7 and 10 percent.27 Patients were excluded from certain studies if they had ever used an insulin pump for less than 3 months85 or less than 1 year,83 or had ever used rt-CGM in the past 6 months,27 86 or 4 weeks.88

#### Population Characteristics

The mean age of participants in the RCTs was 24.0 years (range, 8.5 to 41.2 years) and 25.0 years (range, 9.1 to 44.6 years) in the rt-CGM and SMBG groups, respectively (see Appendix E, Table 2). The age of the participants was not reported for four studies.81 83 85 87 Males represented 47 percent and 46 percent of the study populations, respectively, for the rt-CGM and SMBG groups. Two studies did not report gender distribution.83 87 Six studies did not report the racial composition of their study populations. In other studies, more than 90 percent of the participants were Caucasians.

The mean baseline HbA_1c_ in the RCTs was 8.3 percent in both the rt-CGM and SMBG groups. In the three studies that reported baseline BMI, the means in the rt-CGM groups were 23.5 kg/m^2^,81 26.9 kg/m^2^,57 and 22.4 kg/m^2^,88 and in the SMBG groups the means were 22.5 kg/m^2^,81 26.3 kg/m^2^,57 and 22 kg/m^2^.88

#### Interventions

In the rt-CGM arm, four studies used Minimed Paradigm,80 81 85 86 two used Minimed Guardian rt-CGM,83 87 one study used Abbott FreeStyle Navigator,88 and two studies used three models27 84 including the Abbott Freestyle Navigator, Dexcom STS, and Minimed Paradigm (see Appendix E, Table 3). In five studies, participants were asked to wear monitors continuously; three studies required rt-CGM to be used more than 70 percent of time;81 85 88 and one study did not specify the time requirement.86 Eight studies reported sensor compliance.27 80 81 83-86 88 The range of compliance was wide and depended on the subpopulation studied. Four studies reported on sensor compliance by age category.27 81 84 88 In each of these studies, compliance was highest in individuals greater than 25 years of age (range, 74.9 to 83 percent) and lowest in those 15 to 24 years of age (range, 30 to 53 percent). Frequency of adjusting insulin therapy and frequency of professional or allied health visits were not reported in the available studies.

Five studies used CSII with or without rt-CGM,80 81 83 85 86 four studies used either MDI or CSII with or without rt-CGM.27 84 87 88 Four studies required participants to perform glucose monitoring four or more times daily;27 80 84 85 one required monitoring at least three times per day;81 and four studies did not report the frequency of monitoring.83 86-88 Four studies reported glycemic targets: HbA_1c_ less than 7.5 percent;86 pre-prandial glucose 90 to 144 mg/dL, 2-hour post-prandial glucose less than 180 mg/dL, bedtime glycemic target 122 to 182 mg/dL and overnight glycemic target 82 to 164 mg/dL;80 pre-prandial glucose 70 to 133 mg/dL, 2-hour post-prandial glucose less than 180 mg/dL, and bedtime or overnight target 100 to 150 mg/dL;27 preprandial target 70 to 130 mg/dL with peak postprandial values below 180 mg/dL.88 Two studies provided guideline for between-visit titration.27 81

#### Outcomes

Details of the outcomes are reported in Appendix E, Table 4. The included studies evaluated the effects of rt-CGM vs. SMBG in terms of HbA_1c_, hyperglycemia, nonsevere and severe hypoglycemia, ratio of basal to bolus insulin, and quality of life. None of the studies evaluated mortality, microvascular or macrovascular disease, weight, or any other process measure.

##### HbA_1c_

Nine trials examined the comparative effectiveness of rt-CGM versus SMBG on HbA_1c_. Five studies showed significant differences in end of study HbA_1c_ between the rt-CGM and SMBG groups favoring rt-CGM,27 84 85 87 88 except for the subgroup 24 years of age or younger in one study.27 The remaining studies showed no significant difference in the change from baseline HbA_1c_ between the two groups,27 80 81 83 86 including the subgroup 24 years of age or younger in the study that stratified by age.27

Meta-analysis of seven trials (nine estimates) of at least 12 weeks duration showed a significant difference in HbA_1c_ between the rt-CGM and SMBG groups favoring rt-CGM (combined mean between-group difference from baseline, -0.30 percent; 95% CI, -0.37 to -0.22 percent; see Figure 28). The analysis suggested statistical heterogeneity (I^2^, 64.6 percent, P=0.004), but no single study influenced results substantially. Egger's test (P=0.65) and funnel plot did not suggest publication bias.

Figure 28 Between-group difference between rt-CGM and SMBG in how HbA_1c_ changed from baseline among adults with type 1 diabetes

CI = confidence interval; HbA_1c_ = hemoglobin A_1c_; rt-CGM = real-time continuous glucose monitor; SMBG = self-monitoring of blood glucose

Boxes indicate individual study point estimates. The box size denotes the weight of the study, with larger boxes contributing more to the pooled estimate. The width of the horizontal lines represents the 95% confidence intervals for each study. The diamond at the bottom of the graph indicates the 95% confidence interval for the random-effects pooled estimate.

Test for heterogeneity: Q = 22.59 with 8 degrees of freedom (p = 0.004)

Figure 28 is a forest plot type diagram summarizing the between-group difference between SMBG and rt-CGM in how HbA1c changed from baseline among adults and children with type 1 diabetes. The included trials in the plot are: Deiss 2006, Hirsch 2008, Tamborlane 2008, which includes the strata of 8 to 14 year olds, 15 to 24 year olds, and those older than 25 years, O'Connell 2009, the JDRF CGM study group 2009, and Raccah 2009. All trials favored rt-CGM except for the Tamborlane 2008 strata of 15 to 24 year olds. The combined mean between-group difference from baseline for the eight trials is -0.30 and a 95% confidence interval of -0.37 to -0.22, with an I-squared value of 64.6% and p value of 0.004.

Four studies used either CSII or MDI in the study. Two studies reported HbA_1c_ changes were similar in MDI and CSII users,27 84 while the other two trials did not report results separately.87 88

In a post-hoc analysis, we found that the heterogeneity was explained in part by percent of sensor compliance. In the meta-regression, sensor compliance was significantly associated with the degree of HbA_1c_ reduction (see Figure 29; r=-0.8258; P=0.0221). In the sensitivity analysis that only included studies with more than a 60 percent rate of compliance with the sensor use (seven estimates), rt-CGM had an even greater effect on reducing HbA_1c_ as compared with SMBG (combined mean between-group difference from baseline, -0.36 percent; 95% CI, -0.44 to -0.27 percent; Figure 30).

Figure 29 Compliance with sensor and mean between-group difference between rt-CGM and SMBG in how HbA_1c_ (%) changed from baseline

HbA_1c_ = hemoglobin A_1c_; rt-CGM = real-time continuous glucose monitoring; SMBG = self monitoring of blood glucose

Figure 29 is a scatter plot with a fitted line. The figure summarizes the compliance with sensor and mean between-group difference between SMBG rt-CGM in how HbA1c changed from baseline. The x axis plots compliance in percentage, and the Y axis plots mean between-group differencing in HbA1c. The fitted line has a roughly 45 degree angle in a negative trend.

Figure 30 Between-group difference between rt-CGM and SMBG in how HbA_1c_ changed from baseline among adults with type 1 diabetes in studies where compliance was greater than 60%

CI = confidence interval; HbA_1c_ = hemoglobin A_1c_; rt-CGM = real-time continuous glucose monitor; SMBG = self-monitoring of blood glucose

Boxes indicate individual study point estimates. The box size denotes the weight of the study, with larger boxes contributing more to the pooled estimate. The width of the horizontal lines represents the 95% confidence intervals for each study. The diamond at the bottom of the graph indicates the 95% confidence interval for the random-effects pooled estimate.

Test for heterogeneity: Q = 10.14 with 6 degrees of freedom (p = 0.12)

Figure 30 is a forest plot type diagram summarizing the between-group difference between SMBG and rt-CGM in how HbA1c changed from baseline among adults with type 1 diabetes in studies where compliance was greater than 60%. The included studies are Deiss 2006, Hirsch 2008, Tamborlane 2008 strata of greater than 25 years of age, O'Connell 2009, the JDRF CGM study group 2009, Raccah 2009, and Battelino 2011. All favored rt-CGM, with an overall mean difference of -0.36 and 95 percent confidence interval of -0.44 to -0.27, an I-squared value of 40.8%, and p value of 0.119.

##### Studies in Younger Age Groups

Four studies reported data separately for younger age groups. One study reported a significant effect of rt-CGM as compared with SMBG for individuals 8 to 18 years of age (personal communication). The other three trials showed no significant reduction in HbA_1c_ favoring rt-CGM (personal communication).86 88 Meta-analysis of four studies in age 18 or younger showed a significant mean between-group difference in how HbA_1c_ changed from baseline, favoring rt-CGM (combined mean between-group difference from baseline, -0.26 percent, 95% CI, -0.46 to -0.06 percent) (Figure 31). Egger's test (P=0.75) and funnel plot did not suggest publication bias.

Figure 31 Between-group difference between rt-CGM and SMBG in how HbA_1c_ changed from baseline among children and adolescents with type 1 diabetes

CI = confidence interval; HbA_1c_ = hemoglobin A_1c_; rt-CGM = real-time continuous glucose monitor; SMBG = self-monitoring of blood glucose

^*^Unpublished results.

Boxes indicate individual study point estimates. The box size denotes the weight of the study, with larger boxes contributing more to the pooled estimate. The width of the horizontal lines represents the 95% confidence intervals for each study. The diamond at the bottom of the graph indicates the 95% confidence interval for the random-effects pooled estimate.

Test for heterogeneity: Q = 4.12 with 3 degrees of freedom (p = 0.25)

Figure 31 is a forest plot type diagram summarizing the between-group difference between SMBG and rt-CGM in how HbA1c changed from baseline among children and adolescents with type 1 diabetes. The included studies are Deiss 2006 with an eight to less than 19 year old strata, Hirsch 2008 with a 12 to 18 year old age strata, Tamborlane 2008 with an 18 to 14 year old strata and a 15 to 24 year old strata, and Battelino 2011 with a 10-17 year old population. The combined mean between-group difference is -0.26 with a 95% confidence interval of --0.46 to -0.06, and an I-squared value of 27.2% and a p value of 0.248. All favor rt-CGM.

##### Nonsevere Hypoglycemia

Seven studies evaluated the incidence of nonsevere hypoglycemia with rt-CGM compared with SMBG (see Table 22).27 81 83-86 88 The definitions of nonsevere hypoglycemia varied between studies and several studies reported multiple endpoints. The results were mixed. Three studies showed no difference in nonsevere hypoglycemia between the rt-CGM and SMBG interventions.27 81 85 Three studies showed evidence of a benefit of rt-CGM on the duration of nonsevere hypoglycemia. In a RCT of patients with well-controlled type 1 diabetes,84 the rt-CGM group spent less time with nonsevere hypoglycemia compared with the SMBG group (all P<0.05) regardless of the hypoglycemia cut-point used. In another RCT in patients with type 1 diabetes ages 12 to 72 years,86 those in the SMBG only arm had an increase in the duration of time spent with glucose less than or equal to 70 mg/dL, whereas those in the rt-CGM arm had no change in duration of time spent with glucose less than or equal to 70 mg/dL, resulting in a statistically significant between-group difference (P=0.0002). In an RCT of patients with HbA_1c_ greater than or equal to7.5 percent, the time per day spent in hypoglycemia was significantly shorter in the rt-CGM group than the control group.88 In the seventh study,83 rt-CGM use was associated with a significant reduction in the number of SMBG readings less than 60 mg/dL, whereas no difference was observed in the SMBG-only group; however, the between-condition comparison was not statistically significant. Similar trends that were not significant were observed when the number of patients with hypoglycemia (glucose less than 60 mg/dL) was used as the endpoint. A meta-analysis including 4 studies (6 estimates) showed no difference in time spent in hypoglycemic range, defined by glucose level less than 70 mg/dL.27 81 85 88 The mean between group difference was -2.11 minutes/day (95% CI, -5.66 to 1.44) (see Figure 32). There was no evidence of statistical heterogeneity or publication bias, using Egger's test and the funnel plot.

Table 22 Nonsevere hypoglycemia in the rt-CGM and SMBG interventions among patients with type 1 diabetes

Author, Year | Definition | Significant Effect Favoring rt-CGM
Radermecker, 2010^83^ | Events <60 mg/dL in preceding 14 days | Yes (within-arm)
Raccah, 2009^81^ | Change in glucose <70 /mg/dL hours per day Change in hypoglycemia AUC (mg/dL/day) Change in the number of hypoglycemia episodes | No
JDRF, 2009^84^ | Minutes per day spent with glucose level ≤ 50 mg/dL Minutes per day spent with glucose level ≤ 60 mg/dL Minutes per day spent with glucose level ≤ 70 mg/dL | Yes
O'Connell, 2009^85^ | Time spent with glucose ≤ 70.2 mg/dL | No
Tamborlane, 2008^27^ | Minutes per day spent with glucose level ≤ 50 mg/dL Minutes per day spent with glucose level ≤ 70 mg/dL | No
Hirsch, 2008^86^ | Time spent <70 mg/dL | Yes
Battelino, 2011^88^ | Hours per day with glucose level < 63 mg/dL Hours per day with glucose level < 55 mg/dL Hours per day with glucose < 70 mg/dL | Yes Borderline, P=0.05 Yes

AUC = area under the curve; JDRF = Juvenile Diabetes Research Foundation; mg/dL = milligrams per deciliter; rt-CGM = real-time continuous glucose monitor; SMBG = self monitoring of blood glucose

Figure 32 Between-group difference between rt-CGM and SMBG in how time spent in hypoglycemic range changed from baseline among patients with type 1 diabetes

CI = confidence interval; rt-CGM = real-time continuous glucose monitor; SMBG = self-monitoring of blood glucose

Boxes indicate individual study point estimates. The box size denotes the weight of the study, with larger boxes contributing more to the pooled estimate. The width of the horizontal lines represents the 95% confidence intervals for each study. The diamond at the bottom of the graph indicates the 95% confidence interval for the random-effects pooled estimate.

Test for heterogeneity: Q = 4.24 with 5 degrees of freedom (p = 0.52)

Figure 32 is a forest plot type diagram summarizing the between-group difference between SMBG and rt-CGM in how time spent in hypoglycemic range changed from baseline among patients with type 1 diabetes. The studies included in the analysis include Tamborlane 2008 (with the three strata of 8 to 14 years old, 15 to 24 years old, and older than 25 years old), O'Connell 2009, Raccah 2009, and Battelino 2011. The overall mean difference is -2.11 with a 95 percent confidence interval of -5.66 to 1.44.

##### Severe Hypoglycemia

Eight studies reported the incidence of severe hypoglycemia over the study interval using variable definitions (see Table 23).27 80 81 84-88 One study reported data stratified by age and we treated these groups as distinct populations.27 A meta-analysis of six of these studies (eight separate study populations) indicated no difference in the incidence of severe hypoglycemia with rt-CGM compared with SMBG treatment (pooled RR, 0.95; 95% CI, 0.53 to 1.69, P=0.86) (see Figure 33). Two of the studies were excluded from meta-analysis because of zero events in both arms.85 88 Another study was excluded from the meta-analysis because its randomized crossover design differed from the other studies.83 In this study, no severe hypoglycemic events were observed.

Table 23 Definition of severe hypoglycemia in the studies of rt-CGM and SMBG in type 1 diabetes

Author, Year | Definition of Hypoglycemia
Kordonouri, 2010^80^ | Not further specified
Raccah, 2009^81^ | Not further specified
Beck, JDRF, 2009^84^ | Event that required assistance from another person to administer carbohydrate, glucagon, or other resuscitative actions
O'Connell, 2009^85^ | Episode of hypoglycemia resulting in seizure or coma or requiring third-party assistance or the use of glucagon or intravenous glucose for recovery
Tamborlane, JDRF, 2009^27^ | Event that required assistance from another person to administer oral carbohydrate, glucagon, or other resuscitative actions
Hirsch, 2008^86^ | Clinical episode of hypoglycemia resulting in seizure or coma, requiring hospitalization or intravenous glucose or glucagon, or any hypoglycemia requiring assistance from another person
Deiss, 2006^90^ | Not further specified
Battelino, 2011^88^ | Not further speficied

JDRF = Juvenile Diabetes Research Foundation; rt-CGM = real-time continuous glucose monitor; SMBG = self monitoring of blood glucose

Figure 33 Pooled relative risk of severe hypoglycemia in rt-CGM versus SMBG interventions among patients with type 1 diabetes

CI = confidence interval; RR = relative risk; rt-CGM = real-time continuous glucose monitor; SMBG = self monitoring of blood glucose

Boxes indicate individual study point estimates. The box size denotes the weight of the study, with larger boxes contributing more to the pooled estimate. The width of the horizontal lines represents the 95% confidence intervals for each study. The diamond at the bottom of the graph indicates the 95% confidence interval for the random-effects pooled estimate.

Test for heterogeneity: Q = 7.91 with 7 degrees of freedom (p = 0.34)

I-squared = 12 percent

Figure 33 is a forest plot type diagram summarizing the pooled relative risk of severe hypoglycemia in SMBG versus rt-CGM interventions among patients with type 1 diabetes. The far left column identifies the author and year, which are: Deiss 2006, Hirsch 2008, Tamborlane 2008, which includes the strata of 8 to 14 year olds, 15 to 24 year olds, and those older than 25 years, JDRF CGM study group 2009, Raccah 2009, Kordonouri 2010, O'Connell 2009, and Battelino 2011. The left columns show relative risk and 95% confidence interval, number of events of severe hypoglycemia on rt=CGM, number of patients on rt-CGM, number of events of severe hypoglycemia on SMBG and number of patients on SMBG. The overall pooled relative risk is 0.95 with a 95% confidence interval of 0.53 to 1.69. Deiss 2006, Tamborlane 2008 strata of 8 to 14 year olds and 15 to 24 year olds, and the JDRF CGM study group 2009, and Kordonouri 2010 favored rt-CGM. Hirsch 2008, Raccah 2008, and the Tamborlane 2008 over 25 years strata favored SMBG. O'Connell 2009 and Battelino 2011 were excluded.

Two of these trials reported severe hypoglycemia data specifically in a pediatric population.80 86 In one study,80 severe hypoglycemia was less common in those using rt-CGM than those using SMBG alone (four out of 78 patients with SMBG vs. 0 out of 76 patients with rt-CGM; P=0.046). In contrast, the pediatric subgroup (ages 8 to 14 years) of another study27 showed a similar incidence of severe hypoglycemia in both arms (six out of 58 patients with SMBG vs. four out of 56 patients with rt-CGM; P=0.74).

In the six studies included in the meta-analysis, the duration of intervention ranged from 12 to 52 weeks. There was no evidence of statistical heterogeneity or publication bias, using Egger's test and the funnel plot. As a sensitivity analysis, we conducted a fixed-effects meta-analysis using the treatment-arm continuity correction (0 cells were replaced by the reciprical of the other treatment arm).89 The treatment-arm continuity correction provided a similar result (odds ratio, 0.94; 95% CI, 0.54 to 1.61).

##### Hyperglycemia

Six studies evaluated the comparative effectiveness of rt-CGM versus SMBG on change in hyperglycemia (Table 24).27 81 84-86 88 The definitions of hyperglycemia varied between studies and several studies reported multiple different endpoints. Two studies85 86 showed no difference between the rt-CGM and SMBG arms. Two studies84 88 showed non-statistically significant trends toward less time with hyperglycemia in the rt-CGM arm compared with the SMBG arm. In another study the effect differed by the age of the population.27 In those 25 years of age and older, subjects with rt-CGM had significantly less hyperglycemia compared with those with SMBG alone; this effect was not observed in the two other age groups investigated (age 8 to 14 years and age 15 to 24 years). The fifth study showed significant improvements in hyperglycemia in the rt-CGM group compared with the SMBG group.81 A meta-analysis of four studies (six estimates) indicated a significant reduction in time spent in hyperglycemic range, defined by glucose level less than 180 mg/dL, with the mean between-group difference of -68.56 minutes/day (95% CI, -101.17 to -35.96) (Figure 34).27 81 85 88 There was no evidence of statistical heterogeneity or publication bias, using Egger's test and the funnel plot.

Table 24 Hyperglycemia in the rt-CGM and SMBG interventions among patients with type 1 diabetes

Author, Year | Definition | Significant Effect Favoring rt-CGM
Raccah, 2009^81^ | Change in glucose >190 /mg/dL hours per day Change in hyperglycemia AUC (mg/dL/day) | Yes
JDRF, 2009^84^ | Minutes per day spent with glucose level > 180 mg/dL Minutes per day spent with glucose level >250 mg/dL | No (trend)
O'Connell, 2009^85^ | Time spent with glucose > 180 mg/dL | No
Tamborlane, 2008^27^ | Minutes per day spent with glucose level > 180 mg/dL Minutes per day spent with glucose level > 250 mg/dL | Yes, in individuals 25 years of age and older. No, in other age groups
Hirsch, 2008^86^ | Hyperglycemia (> 180 mg/dL) AUC | No (improvement in both arms, no between group differences)
Battelino, 2011^88^ | Hours per day with glucose level>180 mg/dL Hours per day with glucose level >250 md/dL | No, but favor rt-CGM No, but favor rt-CGM

AUC = area under the curve; JDRF = Juvenile Diabetes Research Foundation; mg/dL = milligrams per deciliter; rt-CGM = real-time continuous glucose monitor; SMBG = self monitoring of blood glucose

Figure 34 Between-group difference between rt-CGM and SMBG in how time spent in hyperglycemic range changed from baseline among patients with type 1 diabetes

CI = confidence interval; rt-CGM = real-time continuous glucose monitor; SMBG = self-monitoring of blood glucose

Boxes indicate individual study point estimates. The box size denotes the weight of the study, with larger boxes contributing more to the pooled estimate. The width of the horizontal lines represents the 95% confidence intervals for each study. The diamond at the bottom of the graph indicates the 95% confidence interval for the random-effects pooled estimate.

Test for heterogeneity: Q = 5.80 with 5 degrees of freedom (p = 0.33)

Figure 34 is a forest plot type diagram summarizing the between-group difference between SMBG and rt-CGM in how time spent in hyperglycemic range changed from baselin among patients with type 1 diabetes. The studies included in the analysis are Tamborlane 2008 (with the three strata of 8 to 14 years old, 15 to 24 years old, and older than 25 years old), O'Connell 2009, Raccah 2009, and Battelino 2011. All favor rt-CGM. The overall mean difference is -68.56 with a 95 percent confidence interval of -101.17 to -35.96, an I-squared value of 13.8%, and p value of 0.326.

##### Ratio of Basal to Bolus Insulin

We sought to compare rt-CGM with SMBG on four different process measures: ratio of basal to bolus insulin, frequency of adjusting insulin therapy, adherence to sensor use, and frequency of professional or allied health visits. Among these outcomes, only ratio of basal to bolus insulin (or its equivalent) was reported. One study80 reported that after 52 weeks, the basal rate was a higher proportion of the total daily insulin dose in the rt-CGM group compared with SMBG (34 percent; SD, 11.8 percent vs. 29.7 percent; SD, 10.4 percent, P=0.021). In contrast, a second study reported a higher percentage of insulin delivered as bolus in the rt-CGM group compared with the SMBG group (53.8 percent; SD, 10 percent vs. 49.8 percent; SD, 15.8 percent; P not reported).81

##### Quality of Life, Including General, Diabetes-Specific, and Treatment-Related

Three studies examined the comparative effectiveness of rt-CGM versus SMBG on general, diabetes specific, and diabetes treatment-related QOL (see Table 25).80 82 83 One study assessed the well-being of the patients' mothers using the World Health Organization-5 and found no difference in parental satisfaction between the two intervention arms.80 The other study assessed general QOL using the Short Form-12 and found an improvement on the Physical Component Score favoring rt-CGM but no difference between the intervention arms on the Mental Component Score.82

Table 25 Quality of life in the rt-CGM and SMBG interventions among patients with type 1 diabetes

QOL Domain | Author, Year | N by Intervention Group | Comparison | Population | Difference in QOL Between Comparison and Baseline Groups | Group Favored for QOL Measure
WHO-5^*^ (mother's well-being) | Kordonouri, 2010^80^ | 76 rt-CGM, 78 SMBG | rt-CGM vs. SMBG | 154 children (aged 1-16 years, mean ± SD: 8.7 ± 4.4 years; 47.5 percent girls) | At 12 months, 62.7±18.9 in rt-CGM versus 60.8±19.in SMBG | Neither
SF-12^*^ | Beck, 2010^82^ | 120 rt-CGM, 106 SMBG | rt-CGM vs. SMBG | 226 children and adults with type 1 diabetes | PCS: At 26 weeks, 55.5 ± 4.9 in rt-CGM versus 54.1 ± 6.9 in SMBG (P=0.03) MCS: At 26 weeks, 48.4 ±10.1 in rt-CGM versus 48.7 ± 9.6 in SMBG (P=0.35) | PCS: rt-CGM MCS: neither
PAID^†^ | Beck, 2010^82^ | 120 rt-CGM, 106 SMBG | rt-CGM vs. SMBG | 226 children and adults with type 1 diabetes | At 26 weeks, 18.1 ± 14.1 in rt-CGM versus 18.2 ± 14.6 in SMBG (P=0.50) | Neither
DQOL^†^ | Radermecker, 2010^83^ | 13 (crossover study) | rt-CGM vs. SMBG | Thirteen adults with type 1 diabetes (diabetes duration: 25+/-15 years; CSII duration: 5.5+/-7.0 years) | Mean difference in the rt-CGM group from baseline was -2.3 ± 5.3 (95% CI, -6.4 to 1.7); in the SMBG group, 0.7 ± 4.1 (95% CI, 2.5 to 3.8) | Neither
Hypoglycemia Fear Survey^‡^ | Beck, 2010^82^ | 120 rt-CGM, 106 SMBG | rt-CGM vs. SMBG | 226 children and adults with type 1 diabetes | At 26 weeks, 33.3 ± 11.5 in rt-CGM versus 36.0 ± 15.6 in SMBG (P=0.04) | rt-CGM

CI = confidence interval; DQOL = Diabetes Quality of Life; MCS = Mental Component Score; PAID = Problem Areas in Diabetes; PCS = Physical Component Score; QOL = quality of life; rt-CGM = real-time continuous glucose monitor; SD = standard deviation; SF-12 = Short Form-12; SMBG = self monitoring of blood glucose; WHO-5 = World Health Organization-5

* General QOL. Total scores for the World Health Organization-5 range from 0 to 100, with higher scores indicating better well-being. Total scores for the Short Form-12 range from 0 to 100, with higher scores indicating higher levels of health.

† Diabetes-specific QOL. Total scores for the Problem Areas in Diabetes range from 0 to 100, with higher scores indicating more serious problems. Total scores for the Diabetes Quality of Life questionnaire range from 0 to 100, with higher scores indicating better quality of life.

‡ Diabetes treatment-related QOL. Total scores for the Hypoglycemia Fear Survey range from 0 to 92, with higher scores indicating higher levels of fear.

Two studies examined diabetes-specific QOL—one using the Problem Area in Diabetes in children and adolescents82 and one using the Diabetes Quality of Life (DQOL) in adults83 (see Table 25). There was no difference in DQOL between the two intervention arms in either study.

One study examined diabetes treatment-related QOL using the Hypoglycemia Fear Survey in children and adults and found lower fear of hypoglycemia favoring rt-CGM.82

#### Study Quality

Four studies were rated with good quality80 84-86 and five studies were rated with fair quality (see Appendix E, Table 5).27 81 83 87 88 Those studies rated as fair were not clear in reporting allocation concealment. However, all trials were open-labeled because of the nature of the interventions.

#### Strength of Evidence

The strength of evidence examining the comparative effectiveness of rt-CGM versus SMBG was high for HbA_1c_, moderate for hyperglycemia, and mild hypoglycemia, and low for severe hypoglycemia, ratio of basal to bolus insulin and QOL (Table 26). No study reported on weight gain as an outcome. The magnitude of effect of rt-CGM versus SMBG was small but significant for the HbA_1c_ outcome (-0.3 percent, P<0.001), favoring rt-CGM, but there was no effect on severe hypoglycemia. Risk of bias was low for the outcomes of HbA_1c_ and severe hypoglycemia, medium for hyperglycemia and mild hypoglycemia, and high for ratio of basal to bolus insulin and QOL.

Table 26 Numbers of studies and subjects, strength of evidence domains, magnitude of effect, and overall strength of evidence for rt-CGM versus SMBG in children and adults with type 1 diabetes

Outcome | Number of Studies (Participants) | Domains Pertaining to Strength of Evidence | | | | | Magnitude of Effect and Strength of Evidence
Outcome | Number of Studies (Participants) | Risk of Bias: Design/ Quality | Consistency | Directness | Precision | Publication Bias | Magnitude of Effect and Strength of Evidence
Mortality | 0 | NA | NA | NA | NA | NA | Strength of evidence: Insufficient
Microvascular outcomes | 0 | NA | NA | NA | NA | NA | Strength of evidence: Insufficient
Macrovascular outcomes | 0 | NA | NA | NA | NA | NA | Strength of evidence: Insufficient
HbA_1c_ | 9 (1215) | Low | Consistent | Direct | Precise | No | Magnitude of effect: Small Strength of evidence: High
Hyperglycemia | 6 (886) | Medium | Inconsistent | Direct | Imprecise | No | Magnitude of effect: Moderate Strength of evidence: Moderate
Mild hypoglycemia | 7 (899) | Medium | Inconsistent | Direct | Precise | No | Magnitude of effect: No effect Strength of evidence: Moderate
Severe hypoglycemia | 8 (1202) | Low | Inconsistent | Direct | Imprecise | No | Magnitude of effect: No effect Strength of evidence: Low
Weight | 0 | NA | NA | NA | NA | NA | Strength of evidence: Insufficient
Ratio of basal to bolus insulin | 2 (482) | High | Inconsistent | Direct | Precise | Uncertain | Magnitude of effect: Unable to determine Strength of evidence: Low
Frequency of adjusting insulin therapy | 0 | NA | NA | NA | NA | NA | Strength of evidence: Insufficient
Adherence to insulin therapy | 0 | NA | NA | NA | NA | NA | Strength of evidence: Insufficient
Frequency of professional or allied health visits | 0 | NA | NA | NA | NA | NA | Strength of evidence: Insufficient
Quality of life | 2 (380) | Low | Inconsistent | Indirect | Precise | Uncertain | Magnitude of effect: Small Strength of evidence: Low
Diabetes-specific QOL | 2 (239) | Moderate | Consistent | Direct | Precise | Uncertain | Magnitude of effect: Small Strength of evidence: Low
Diabetes treatment-related QOL | 1 (226) | High | Unknown | Direct | Precise | Uncertain | Magnitude of effect: Small Strength of evidence: Insufficient

HbA_1c_ = hemoglobin A_1c_; NA = not applicable; QOL = quality of life

The strength of the evidence was defined as follows: High = High confidence that the evidence reflects the true effect. Further research is unlikely to change our confidence in the estimate of the effect. Moderate = Moderate confidence that the evidence reflects the true effect. Further research may change our confidence in the estimate of the effect and may change the estimate. Low = Low confidence that the evidence reflects the true effect. Further research is likely to change our confidence in the estimate of the effect and is likely to change the estimate. Insufficient = Evidence is unavailable, does not permit a conclusion, or consists of only one study with high risk of bias.

#### Applicability

Most studies in type 1 diabetes had small sample sizes, with the largest clinical trial including 322 participants.48 Most RCTs were good or fair quality. The majority of studies were performed in both children and adults without stratification by age. Studies generally did not report race but based on the countries in which they were conducted (more than half were outside of the U.S. or involved multiple countries), most studies included Caucasian participants, consistent with the demographics of type 1 diabetes. Participants generally had poor glycemic control at study entry (mean HbA_1c_ 8.5 percent), were treated in the intervention groups for an average of 24 weeks, and had diabetes for 11.5 years prior to study entry.

### Comparative Effects of rt-CGM and SMBG Among Patients With Type 2 Diabetes or Pregnant Women With Pre-Existing Diabetes

#### Key Points and Evidence Grades

- There was insufficient strength of evidence evaluating the effects of rt-CGM vs. SMBG among patients with type 2 diabetes or pregnant women with pre-existing diabetes, as we found no studies conducted in these populations.

### Effectiveness of Sensor-Augmented Pumps Compared With MDI/SMBG Among Patients With Type 1 Diabetes

#### Key Points and Evidence Grades

- The strength of evidence was moderate favoring sensor-augmented pumps over MDI/SMBG for their effects on HbA_1c_ (mean between-group difference in how HbA_1c_ changed was -0.68 percent; 95% CI, -0.81 to -0.54 percent).
- The strength of the evidence comparing sensor-augmented pumps and MDI/SMBG for nonsevere hypoglycemia was moderate. There was no difference in time spent with nonsevere hypoglycemia between the sensor-augmented pump and MDI/SMBG intervention groups.
- The strength of evidence was moderate suggesting no difference in severe hypoglycemia incidence between the sensor-augmented pump and MDI/SMBG intervention groups (RR, 1.2; 95% CI, 0.7 to 2.3;^91^ 0 events for sensor-augmented pump vs. three events for MDI/SMBG;92 0 events in eight patients in sensor-augmented pump group versus one event in eight patients in the MDI/SMBG group;93 and RR, 3.5; 95% CI, 0.4 to 304).94
- The strength of the evidence comparing sensor-augmented pumps with MDI/SMBG was moderate for hyperglycemia. Two trials suggested time spent with hyperglycemia was significantly less in the sensor-augmented pump compared with the MDI/SMBG intervention group (P<0.001).
- The strength of the evidence comparing sensor-augmented pumps with MDI/SMBG was low for weight. In one study91 there was no significant difference in weight gain between the sensor-augmented pump and MDI/SMBG intervention groups favoring MDI/SMBG (2.4 kg vs. 1.8 kg; P=0.19). In another study, weight increased 0.7 kg in the sensor-augmented pump group and 2.0 kg in the MDI/SMBG group but the difference was not significant (mean between-group difference, 1.3 kg; 95% CI, -21.2 to 23.8 kg).92
- The strength of the evidence comparing sensor-augmented pumps with MDI/SMBG was low for diabetes treatment-related QOL. User acceptance and overall diabetes treatment satisfaction were greater in the sensor-augmented pump arm compared with the MDI/SMBG arm. Blood Glucose Monitoring System Rating Questionnaire scores were 83.3±21.7 for sensor-augmented pump versus 33.3±22.6 for MDI/SMBG (mean between-group difference in final scores, 50.0; 95% CI, 33.6 to 66.4).92
- There was insufficient strength of evidence evaluating the effects of sensor-augmented pumps vs. MDI/SMBG in terms of mortality, microvascular or macrovascular disease, or any of the process measures, as we found no studies reporting on these outcomes.

#### Study Design

Four studies evaluated a sensor-augmented pump versus MDI/SMBG in children and adults with type 1 diabetes (see Appendix E, Table 1).91-94 Two studies were multicenter trials in North America.91 93 The third study did not specify the location and number of the study sites.92 The fourth study was a multi-center trial in Europe.94 Two studies reported receiving industry support,91 92 and the other two studies did not specify the sources of support.93 94 None of the studies reported receiving government funding.

All four studies were parallel-arm RCTs.91-94 Two studies described a run-in period91 93 and two did not.92 94 Of the four studies, two described the dates of the enrollment period.91 94 The followup time for the studies were 15, 16, 26, and 52 weeks. One study reported the number of patients screened.91 One study reported the exclusion of pregnant patients specifically.91

All four studies enrolled suboptimally controlled patients with HbA_1c_ between 7.4 and 9.5 percent;91 greater than or equal to 7.5 percent;93 or HbA_1c_ greater than or equal to 8.2 percent.94 The other study mentioned excluding patients with “optimal” glycemic control but did not point out the HbA_1c_ criteria specifically.92

Certain studies excluded patients if they had ever used an insulin pump within the past 3 years91 or anytime in the past (i.e., CSII-naïve).92 93 One trial included current MDI users only, but did not specify exclusion criteria based on having ever used an insulin pump.94

#### Population Characteristics

Three studies included only adults92 94 95 and one study enrolled both adults and children (see Appendix E, Table 2).91 Two of these studies reported the mean age of participants (47.2 years92 and 45.9 years).93 Two reported mean age stratified by treatment group (32.2 years in the sensor-augmented pump group vs. 31.5 years in the MDI/SMBG group91 and 39.3 in sensor-augmented pump group vs. 37.3 in the MDI/SMBG group).94 In the study that included both adults and children,91 32 percent of the sample were children and the mean ages of the children were 11.7 years in the sensor-augmented pump group versus 12.7 years in the MDI/SMBG group. Two studies described the gender distribution by treatment arm (57 percent males in sensor-augmented pump group vs. 56 percent males in the MDI/SMBG group91 and 50 percent males in sensor-augmented pump vs. 53.8 percent males in MDI/SMBG group).94 And two studies described combined treatment arms (46 percent males92 and 50 percent males).93 The majority of participants in two studies were white (92 percent91 and 79 percent).92 Two studies did not report the racial composition of the population.93 94

The mean baseline HbA_1c_ in the RCTs was similar in all four studies (median, 8.6 percent; range, 8.3 to 9.5 percent). One study reported the baseline BMI by treatment arm (sensor-augmented pump 25.3 kg/m^2^ vs. MDI/SMBG 25.6 kg/m^2^),91 one study reported the baseline BMI in the combined sample (mean, 27.0 kg/m^2^)92 and two studies did not report baseline body mass index.93 94

#### Interventions

All four studies used the MiniMed Paradigm REALTime system and provided training in the use of the device (see Appendix E, Table 3). The frequency and intensity of the followup visits, however, differed between studies. In the longest study,91 patients assigned to the sensor-augmented pump arm underwent initial pump training, followed by pump initiation. Two weeks later, following on-line and in-person training sessions, researchers introduced the rt-CGM. Clinicians saw patients at 3-month intervals during which they reviewed glucose data and adjusted insulin therapy. Clinicians also saw patients assigned to continue MDI/SMBG at 3-month intervals and made insulin adjustments. In the MDI/SMBG group, patients wore a blinded rt-CGM device for 1-week periods at baseline, 6 months, and 12 months, so continuous glucose profiles could be compared between the study groups at the end of the study. Both arms of the study received the same instruction in intensive diabetes management and carbohydrate counting.

In a 15-week randomized trial,93 patients assigned to a sensor-augmented pump initiated CSII and rt-CGM in a step-wise fashion over a 3-week period. Use of the rt-CGM started 2 weeks after CSII initiation. The patients in the sensor-augmented pump arm were also seen at weeks 3, 5, and 15. Clinicians saw patients randomized to continue MDI/SMBG at baseline and weeks 2, 5, and 15. In both arms, clinicians reviewed glucose data and adjusted insulin. Participants in both arms of the study received the same instruction in intensive diabetes management and carbohydrate counting.

In a 16-week randomized trial,92 both arms received diabetes education and those randomized to a sensor-augmented pump received additional one-time instructions regarding the use of the device. The trial did not specify additional followup visits in either arm until the end of study visit at week 16. Clinicians did not make insulin adjustments as part of the study protocol.

In the most recent trial,94 clinicians trained patients to use the device within 2 weeks after randomization and to change both the insulin catheter and glucose sensor every 3 days. At 13 and 26 weeks, patients visited the investigating center and clinicians downloaded data from the sensor. Clinicians made therapy adjustments when necessary based on the downloaded data. They provided no specific instructions to the patients with regard to insulin dosing or other device specific adjustments other than during the training phase and at 13- and 26-week visits. In the second part of the trial (between 13 and 26 weeks) patients in the sensor-augmented insulin pump and MDI groups were to receive the same amount of study staff attention. Only one study reported the frequency of rt-CGM use91 and 67 percent of patients used the rt-CGM more than 60 percent of the time; 23 percent reported using the rt-CGM more than 80 percent of the time.

#### Outcomes

Details of the outcomes are reported in Appendix E, Table 4. The included studies evaluated the effects of sensor-augmented pumps vs. MDI/SMBG in terms of HbA_1c_, nonsevere and severe hypoglycemia, hyperglycemia, weight, and quality of life. None of the studies reported on mortality, microvascular or macrovascular disease, or any of the process measures.

##### HbA_1c_

All four studies assessed the effect on HbA_1c_.91-94 Three studies found a significant difference in end of study HbA_1c_ between the sensor-augmented pump and MDI/SMBG groups, favoring sensor-augmented pump.91 92 94 One study did not show a statistically significant difference in HbA_1c_ between the two groups.93 A meta-analysis of all four studies showed a significant difference in the reduction from baseline HbA_1c_ between the sensor-augmented pump and MDI/SMBG groups, favoring the sensor-augmented pump (combined mean between-group difference in change from baseline, -0.68 percent; 95% CI, -0.81 to -0.54 percent, P<0.001; see Figure 35). We did not find statistical heterogeneity (P=0.09) and no one study influenced results substantially. Egger's test (P=0.08) and funnel plot did not suggest publication bias.

Figure 35 Between-group difference between sensor-augmented pumps and MDI/SMBG in how HbA_1c_ changed from baseline among patients with type 1 diabetes

CI = confidence interval; HbA_1c_ = hemoglobin A_1c_; MDI/SMBG = multiple daily injections and self monitoring of blood glucose

Boxes indicate individual study point estimates. The box size denotes the weight of the study, with larger boxes contributing more to the pooled estimate. The width of the horizontal lines represents the 95% confidence intervals for each study. The diamond at the bottom of the graph indicates the 95% confidence interval for the random-effects pooled estimate.

Test for heterogeneity: Q = 6.48 with 3 degrees of freedom (p = 0.09)

Figure 35 is a forest plot type diagram summarizing the between-group difference between MDI/SMBG and sensor-augmented pumps in how HbA1c changed from baseline among patients with type 1 diabetes. The four studies assessed are Lee 2007, Peyrot 2009, Bergenstal 2010, and Hermanides 2011. The combined mean between-group difference from baseline is -1.10% with a 95% confidence interval of -1.46 to -0.74% with an I-squared value of 53.7% a p value of 0.091. All four studies favor sensor-augmented pumps.

##### Nonsevere Hypoglycemia

Two studies assessed the time spent with nonsevere hypoglycemia.91 94 The first trial calculated the area under the curve for two different cutpoints (less than 70 mg/dL and less than 50 mg/dL). The study arms had no differences in these measures during the study interval. The second trial calculated the percentage of time in hypoglycemia and number of nonsevere hypoglycemic events and showed no significance difference between the arms.

##### Severe Hypoglycemia

All four studies reported on the incidence of severe hypoglycemia. In the largest study,91 severe hypoglycemia was defined as an episode requiring assistance and confirmed by the documentation of a blood glucose less than 50 mg/dL or recovery with restoration of plasma glucose. In the study, hypoglycemia occurred in a similar number of patients in the sensor-augmented pump arm and the MDI/SMBG group (21 out of 247 patients vs. 17 out of 248 patients, P=0.58). In another trial,92 three hypoglycemic events occurred in the MDI/SMBG group (N = 14), whereas no events occurred in the sensor-augmented pump group (N = 14). The number of patients who experienced events was not specified. The definition of severe hypoglycemia was not reported. In the third trial,93 one unspecified hypoglycemic event occurred in the eight patients randomized to continue MDI/SMBG, and no events occurred in the eight patients randomized to a sensor-augmented pump. In the fourth trial,94 there was no significant difference in the occurrence of severe hypoglycemia, with four episodes in the sensor-augmented pump group and one episode in the MDI/SMBG group (9 percent vs. 3 percent, P=0.21, i.e., 19 episodes /100 person-years in the sensor-augmented pump group and six episodes ⁄100 person-years in the MDI/SMBG group).

##### Hyperglycemia

Two studies assessed the time spent with hyperglycemia.91 94 The first trial calculated the area under the curve in both arms. The studies used two different outcomes, greater than 250 mg/dL and greater than 180 mg/dL. In the entire study population, when stratified by age (adults 19 to 70 years, and children 7 to 18 years of age), those randomized to a sensor-augmented pump had significantly less hyperglycemia compared with those continuing MDI/SMBG (all P<0.001), using either hyperglycemic threshold. The second trial found the percentage of time in hyperglycemia was significantly reduced in the sensor-augmented pump group vs. the MDI/SMBG group (-17.3 percent, 95% CI, -25.1 percent to -9.5 percent). However, the number of hypoglycemic events was not different (P=0.50).94

##### Weight

Two studies reported the change in weight. One study,91 only reported the change in weight in adults, and showed no significant difference in weight gain between the sensor-augmented pump and MDI/SMBG arms favoring MDI/SMBG (2.4 kg vs. 1.8 kg, P=0.19). In a second study,92 mean weight increased 0.7 kg in the sensor-augmented pump arm and 2.0 kg in the MDI/SMBG arm; however, the between-arm difference was not statistically significant (P=0.31).

##### Quality of Life, Including General, Diabetes-Specific, and Treatment-Related

One study examined diabetes treatment-related QOL using the User Acceptance Questionnaire and the Blood Glucose Monitoring System Rating Questionnaire in 28 CSII-naïve adults with type 1 diabetes.92 At 16 weeks, user acceptance and overall satisfaction was greater in the sensor-augmented pump arm compared with MDI/SMBG.92 One study examined disease treatment-related QOL using the Diabetes Treatment Satisfaction Questionnaire in 83 CSII-naïve adults with type 1 diabetes.94 At 26 weeks, satisfaction was greater in the sensor-augmented pump arm compared with MDI/SMBG.94 In addition, the same study examined diabetes-specific QOL using the Hypoglycemia Fear Survey and the Problem Areas in Diabetes instrument. The study found no significant difference between the study arms at 26 weeks.94 Regarding generic QOL, there was no difference in the physical domains of the Short Form-36; one mental domain, emotional role, showed improvement at 26 weeks in the sensor-augmented pump arm.94

One study of children with type 1 diabetes found no significant difference at 52 weeks between the sensor-augmented pump and MDI/SMBG arms in caregiver (parent) generic QOL, measured by the World Health Organization-5 scale, or in patient generic QOL, measured by KIDSCREEN-27.^96^

#### Study Quality

Two studies were rated as “good,”91 94 while the other two studies were rated as “poor” to “fair”92 93 (see Appendix E, Table 5).

#### Strength of Evidence

The strength of evidence examining the comparative effectiveness of a sensor-augmented pump versus MDI/SMBG was moderate for HbA_1c_ because study quality was poor to good but low for the outcomes of hypoglycemia, weight gain, and hyperglycemia, and insufficient for QOL (Table 27). Risk of bias was medium for HbA_1c_ and severe hypoglycemia outcomes, and high for all other outcomes.

Table 27 Numbers of studies and subjects, strength of evidence domains, magnitude of effect, and overall strength of evidence for sensor-augmented pumps

Outcome | Number of Studies (Participants) | Domains Pertaining to Strength of Evidence | | | | | Magnitude of Effect and Strength of Evidence
Outcome | Number of Studies (Participants) | Risk of Bias: Design/ Quality | Consistency | Directness | Precision | Publication Bias | Magnitude of Effect and Strength of Evidence
Mortality | 0 | NA | NA | NA | NA | NA | Strength of evidence: Insufficient
Microvascular outcomes | 0 | NA | NA | NA | NA | NA | Strength of evidence: Insufficient
Macrovascular outcomes | 0 | NA | NA | NA | NA | NA | Strength of evidence: Insufficient
HbA_1c_ | 4 (612) | Medium | Consistent | Direct | Precise | No | Magnitude of effect: Large Strength of evidence: Moderate
Hyperglycemia | 2 (568) | High | Consistent | Direct | Precise | Uncertain | Magnitude of effect: High Strength of evidence: Moderate
Mild hypoglycemia | 2 (568) | Medium | Consistent | Direct | Cannot determine | Uncertain | Magnitude of effect: No effect Strength of evidence: Moderate
Severe hypoglycemia | 4 (612) | Medium | Inconsistent | Direct | Cannot determine | Uncertain | Magnitude of effect: No effect Strength of evidence: Moderate
Weight | 2 (513) | High | Consistent | Direct | Cannot determine | Uncertain | Magnitude of effect: No effect Strength of evidence: Low
Ratio of basal to bolus insulin | 0 | NA | NA | NA | NA | NA | Strength of evidence: Insufficient
Frequency of adjusting insulin therapy | 0 | NA | NA | NA | NA | NA | Strength of evidence: Insufficient
Adherence to insulin therapy | 0 | NA | NA | NA | NA | NA | Strength of evidence: Insufficient
Frequency of professional or allied health visits | 0 | NA | NA | NA | NA | NA | Strength of evidence: Insufficient
Diabetes treatment-related QOL | 2 (111) | High | Consistent | Direct | Precise | Uncertain | Magnitude of effect: Low Strength of evidence: Low
Diabetes-specific QOL | 1 (83) | Medium | Unknown | Direct | Precise | Uncertain | Magnitude of effect: No effect Strength of evidence: Low
Generic QOL | 3 (237) | Medium | Consistent | Direct | Precise | Uncertain | Magnitude of effect: Low Strength of evidence: Low

HbA_1c_ = hemoglobin A_1c_; NA = not applicable; QOL = quality of life

The strength of the evidence was defined as follows: High = High confidence that the evidence reflects the true effect. Further research is unlikely to change our confidence in the estimate of the effect. Moderate = Moderate confidence that the evidence reflects the true effect. Further research may change our confidence in the estimate of the effect and may change the estimate. Low = Low confidence that the evidence reflects the true effect. Further research is likely to change our confidence in the estimate of the effect and is likely to change the estimate. Insufficient = Evidence is unavailable, does not permit a conclusion, or consists of only one study with high risk of bias.

#### Applicability

The largest clinical trial had 485 participants91 and the other three trials had less than 80 participants.92-94 Only one study included individuals 20 years of age or younger.91 Two studies reported the majority of participants were Caucasian,91 92 while the other two trials did not report race distribution.93 94 Participants had poor glycemic control at study entry (mean HbA_1c_, 8 to 9 percent); clinicians treated the intervention groups for 15 weeks to one year. One study reported a long duration of diabetes with a mean of 15 years.91

### Effectiveness of Sensor-Augmented Pumps Compared With MDI/SMBG Among Patients With Type 2 Diabetes or Pregnant Women With Pre-Existing Diabetes

#### Key Points and Evidence Grades

- There was insufficient strength of evidence evaluating the effects of sensor-augmented pumps vs. MDI/SMBG among patients with type 2 diabetes or pregnant women with pre-existing diabetes, as we found no studies conducted in these populations.