# References

1 Anon. Diagnosis and classification of diabetes mellitus. Diabetes Care. Suppl 1. 2010;33:S62-9. [pmid: 20042775].
2 Cowie CC, Rust KF, Ford ES, et al. Full accounting of diabetes and pre-diabetes in the U.S. population in 1988-1994 and 2005-2006. Diabetes Care. 2009;32(2):287-94. [pmid: 19017771].
3 Anon. CDC 's Diabetes Program - Data & Trends - Prevalence of Diabetes - Crude and Age-Adjusted Prevalence of Diagnosed Diabetes per 100 Population, United States, 1980-2007. www.cdc.gov/diabetes/statistics/prev/national/figage.htm.
4 Engelgau MM, Geiss LS, Saaddine JB, et al. The evolving diabetes burden in the United States. Ann Intern Med. 2004;140(11):945-50. [pmid: 15172919].
5 Bell RA, Mayer-Davis EJ, Beyer JW, et al. Diabetes in non-Hispanic white youth: prevalence, incidence, and clinical characteristics: the SEARCH for Diabetes in Youth Study. Diabetes Care. Suppl 2. 2009;32:S102-11. [pmid: 19246575].
6 Dabelea D, DeGroat J, Sorrelman C, et al. Diabetes in Navajo youth: prevalence, incidence, and clinical characteristics: the SEARCH for Diabetes in Youth Study. Diabetes Care. Suppl 2. 2009;32:S141-7. [pmid: 19246579].
7 Mayer-Davis EJ, Beyer J, Bell RA, et al. Diabetes in African American youth: prevalence, incidence, and clinical characteristics: the SEARCH for Diabetes in Youth Study. Diabetes Care. Suppl 2. 2009;32:S112-22. [pmid: 19246576].
8 Lawrence JM, Mayer-Davis EJ, Reynolds K, et al. Diabetes in Hispanic American youth: prevalence, incidence, demographics, and clinical characteristics: the SEARCH for Diabetes in Youth Study. Diabetes Care. Suppl 2. 2009;32:S123-32. [pmid: 19246577].
9 Liu LL, Yi JP, Beyer J, et al. Type 1 and Type 2 diabetes in Asian and Pacific Islander U.S. youth: the SEARCH for Diabetes in Youth Study. Diabetes Care. Suppl 2. 2009;32:S133-40. [pmid: 19246578].
10 Centers for Disease Control and Prevention. National Diabetes Fact Sheet. CDC. 2011.
11 Anon. Intensive blood-glucose control with sulphonylureas or insulin compared with conventional treatment and risk of complications in patients with type 2 diabetes (UKPDS 33). UK Prospective Diabetes Study (UKPDS) Group. Lancet. 1998;352(9131):837-53. [pmid: 9742976].
12 Holman RR, Paul SK, Bethel MA, et al. 10-year follow-up of intensive glucose control in type 2 diabetes. N Engl J Med. 2008;359(15):1577-89. [pmid: 18784090].
13 Anon. The effect of intensive treatment of diabetes on the development and progression of long-term complications in insulin-dependent diabetes mellitus. The Diabetes Control and Complications Trial Research Group. N Engl J Med. 1993;329(14):977-86. [pmid: 8366922].
14 Nathan DM, Cleary PA, Backlund JY, et al. Intensive diabetes treatment and cardiovascular disease in patients with type 1 diabetes. N Engl J Med. 2005;353(25):2643-53. [pmid: 16371630].
15 Kitzmiller JL, Block JM, Brown FM, et al. Managing preexisting diabetes for pregnancy: summary of evidence and consensus recommendations for care. Diabetes Care. 2008;31(5):1060-79. [pmid: 18445730].
16 American Diabetes Association (ADA). Executive Summary: Standards of Medical Care in Diabetes—2011. Diabetes Care. 2011;34:S4-S10. [pmid: 21193627].
17 Cryer PE, Davis SN, Shamoon H. Hypoglycemia in diabetes. Diabetes Care. 2003;26(6):1902-12. [pmid: 12766131].
18 Anon. Weight gain associated with intensive therapy in the diabetes control and complications trial. The DCCT Research Group. Diabetes Care. 1988;11(7):567-73. [pmid: 2904881].
19 Henry RR, Gumbiner B, Ditzler T, et al. Intensive conventional insulin therapy for type II diabetes. Metabolic effects during a 6-mo outpatient trial. Diabetes Care. 1993;16(1):21-31. [pmid: 8422777].
20 Anon. Standards of medical care in diabetes--2011. Diabetes Care. Suppl 1. 2011;34:S11-61. [pmid: 21193625].
21 Selvin E, Crainiceanu CM, Brancati FL, et al. Short-term variability in measures of glycemia and implications for the classification of diabetes. Arch Intern Med. 2007;167(14):1545-51. [pmid: 17646610].
22 ACOG Practice Bulletin. Clinical Management Guidelines for Obstetrician-Gynecologists. Number 60, March 2005. Pregestational diabetes mellitus. Obstet Gynecol. 2005;105(3):675-85. [pmid: 15738045].
23 Welschen LM, Bloemendal E, Nijpels G, et al. Self-monitoring of blood glucose in patients with type 2 diabetes who are not using insulin: a systematic review. Diabetes Care. 2005;28(6):1510-7. [pmid: 15920083].
24 Blevins TC, Bode BW, Garg SK, et al. Statement by the American Association of Clinical Endocrinologists Consensus Panel on continuous glucose monitoring. Endocr Pract. 2010;16(5):730-45. [pmid: 21356637].
25 Hirsch IB, Armstrong D, Bergenstal RM, et al. Clinical application of emerging sensor technologies in diabetes management: consensus guidelines for continuous glucose monitoring (CGM). Diabetes Technol Ther. 2008;10(4):232-44. quiz 245-6. [pmid: 18699743].
26 Wolpert HA. Continuous Glucose Monitoring -- Coming of Age. N Engl J Med. 2010;363(4):383-4. [pmid: 20587584].
27 Tamborlane WV, Beck RW, Bode BW, et al. Continuous glucose monitoring and intensive treatment of type 1 diabetes. N Engl J Med. 2008;359(14):1464-76. [pmid: 18779236].
28 Pickup JC, Renard E. Long-acting insulin analogs versus insulin pump therapy for the treatment of type 1 and type 2 diabetes. Diabetes Care. Suppl 2. 2008;31:S140-5. [pmid: 18227475].
29 Grunberger G, Bailey TS, Cohen AJ, et al. Statement by the American Association of Clinical Endocrinologists Consensus Panel on insulin pump management. Endocr Pract. 2010;16(5):746-62. [pmid: 21356638].
30 Pickup JC, Sutton AJ. Severe hypoglycaemia and glycaemic control in Type 1 diabetes: meta-analysis of multiple daily insulin injections compared with continuous subcutaneous insulin infusion. Diabet Med. 2008;25(7):765-74. [pmid: 18644063].
31 Jeitler K, Horvath K, Berghold A, et al. Continuous subcutaneous insulin infusion versus multiple daily insulin injections in patients with diabetes mellitus: systematic review and meta-analysis. Diabetologia. 2008;51(6):941-51. [pmid: 18351320].
32 Misso ML, Egberts KJ, Page M, et al. Continuous subcutaneous insulin infusion (CSII) versus multiple insulin injections for type 1 diabetes mellitus. Cochrane Database Syst Rev. 2010;(1):CD005103. [pmid: 20091571].
33 Monami M, Lamanna C, Marchionni N, et al. Continuous subcutaneous insulin infusion versus multiple daily insulin injections in type 1 diabetes: a meta-analysis. Acta Diabetol. 2009. [pmid: 19504039].
34 Pickup JC, Freeman SC, Sutton AJ. Glycaemic control in type 1 diabetes during real time continuous glucose monitoring compared with self monitoring of blood glucose: meta-analysis of randomised controlled trials using individual patient data. BMJ. 2011;343:d3805. [pmid: 21737469].
35 Monami M, Lamanna C, Marchionni N, et al. Continuous subcutaneous insulin infusion versus multiple daily insulin injections in type 2 diabetes: A meta-analysis. Exp. Clin. Endocrinol. Diabetes. 2009;117(5):220-2.
36 Raskin P, Bode BW, Marks JB, et al. Continuous subcutaneous insulin infusion and multiple daily injection therapy are equally effective in type 2 diabetes: a randomized, parallel-group, 24-week study. Diabetes Care. 2003;26(9):2598-603. [pmid: 12941725].
37 Wainstein J, Metzger M, Boaz M, et al. Insulin pump therapy vs. multiple daily injections in obese Type 2 diabetic patients. Diabet Med. 2005;22(8):1037-46. [pmid: 16026370].
38 Berthe E, Lireux B, Coffin C, et al. Effectiveness of intensive insulin therapy by multiple daily injections and continuous subcutaneous infusion: a comparison study in type 2 diabetes with conventional insulin regimen failure. Horm Metab Res. 2007;39(3):224-9. [pmid: 17373639].
39 Farrar D, Tuffnell DJ, West J. Continuous subcutaneous insulin infusion versus multiple daily injections of insulin for pregnant women with diabetes. Cochrane Database Syst Rev. 2007;(3):CD005542. [pmid: 17636806].
40 Higgins J. Cochrane Handbook for Systematic Reviews of Interventions Version 5.1.0. The Cochrane Collaboration. 2011. Available at: http://www.cochrane.org/training/cochrane-handbook.
41 Agency for Healthcare Research and Quality. Methods Guide for Effectiveness and Comparative Effectiveness Reviews. Rockville, MD. Agency for Healthcare Research and Quality. March. 2011. AHRQ Publication No. 10(11)-EHC063-EF. Chapters available at: www.effectivehealthcare.ahrq.gov/methodsguide.cfm.
42 Downs SH, Black N. The feasibility of creating a checklist for the assessment of the methodological quality both of randomised and non-randomised studies of health care interventions. J Epidemiol Community Health. 1998;52(6):377-84. [pmid: 9764259].
43 DerSimonian R, Laird N. Meta-analysis in clinical trials. Control Clin Trials. 1986;7(3):177-88. [pmid: 3802833].
44 Higgins JP, Thompson SG, Deeks JJ, Altman DG. Measuring inconsistency in meta-analyses. BMJ. 2003;327(7414):557-60. [pmid: 12958120].
45 Begg CB, Mazumdar M. Operating characteristics of a rank correlation test for publication bias. Biometrics. 1994;50(4):1088-101. [pmid: 7786990].
46 Egger M, Davey Smith G, Schneider M, et al. Bias in meta-analysis detected by a simple, graphical test. BMJ. 1997;315(7109):629-34. [pmid: 9310563].
47 Owens DK, Lohr KN, Atkins D, et al. AHRQ series paper 5: grading the strength of a body of evidence when comparing medical interventions--agency for healthcare research and quality and the effective health-care program. J Clin Epidemiol. 2010;63(5):513-23. [pmid: 19595577].
48 Skogsberg L, Fors H, Hanas R, et al. Improved treatment satisfaction but no difference in metabolic control when using continuous subcutaneous insulin infusion vs. multiple daily injections in children at onset of type 1 diabetes mellitus. Pediatr Diabetes. 2008;9(5):472-9. [pmid: 18721168].
49 Opipari-Arrigan L, Fredericks EM, Burkhart N, et al. Continuous subcutaneous insulin infusion benefits quality of life in preschool-age children with type 1 diabetes mellitus. Pediatr Diabetes. 2007;8(6):377-83. [pmid: 18036064].
50 Cohen D, Weintrob N, Benzaquen H, et al. Continuous subcutaneous insulin infusion versus multiple daily injections in adolescents with type I diabetes mellitus: a randomized open crossover trial. J Pediatr Endocrinol Metab. 2003;16(7):1047-50. [pmid: 14513883].
51 Doyle EA, Weinzimer SA, Steffen AT, et al. A randomized, prospective trial comparing the efficacy of continuous subcutaneous insulin infusion with multiple daily injections using insulin glargine. Diabetes Care. 2004;27(7):1554-8. [pmid: 15220227].
52 Weintrob N, Benzaquen H, Galatzer A, et al. Comparison of continuous subcutaneous insulin infusion and multiple daily injection regimens in children with type 1 diabetes: a randomized open crossover trial. Pediatrics. 2003;112(3 Pt 1):559-64. [pmid: 12949284].
53 Garcia-Garcia E, Galera R, Aguilera P, et al. Long-term use of continuous subcutaneous insulin infusion compared with multiple daily injections of glargine in pediatric patients. J Pediatr Endocrinol Metab. 2007;20(1):37-40. [pmid: 17315527].
54 Nuboer R, Borsboom GJ, Zoethout JA, et al. Effects of insulin pump vs. injection treatment on quality of life and impact of disease in children with type 1 diabetes mellitus in a randomized, prospective comparison. Pediatr Diabetes. 2008;9(4 Pt 1):291-6. [pmid: 18466210].
55 Schiaffini R, Patera PI, Bizzarri C, et al. Basal insulin supplementation in Type 1 diabetic children: a long-term comparative observational study between continuous subcutaneous insulin infusion and glargine insulin. J Endocrinol Invest. 2007;30(7):572-7. [pmid: 17848840].
56 Bin-Abbas B, Al-Ashwal A, Sakati N. Continuous subcutaneous insulin infusion in type 1 diabetic Saudi children: a comparison with multiple daily insulin injections. Ann Saudi Med. 2006;26(4):327-8. [pmid: 16891848].
57 Pozzilli P, Crino A, Schiaffini R, et al. A 2-year pilot trial of continuous subcutaneous insulin infusion versus intensive insulin therapy in patients with newly diagnosed type 1 diabetes (IMDIAB 8). Diabetes Technol Ther. 2003;5(6):965-74. [pmid: 14709198].
58 Kordonouri O, von Schutz W, Meyer N, et al. Type 1 diabetes in children and adolescents--new strategies in management and treatment. Med Monatsschr Pharm. 2008;31(6):200-6. quiz 207-8. [pmid: 18661909].
59 Hirsch IB, Bode BW, Garg S, et al. Continuous subcutaneous insulin infusion (CSII) of insulin aspart versus multiple daily injection of insulin aspart/insulin glargine in type 1 diabetic patients previously treated with CSII. Diabetes Care. 2005;28(3):533-8. [pmid: 15735183].
60 Bolli GB, Kerr D, Thomas R, et al. Comparison of a multiple daily insulin injection regimen (basal once-daily glargine plus mealtime lispro) and continuous subcutaneous insulin infusion (lispro) in type 1 diabetes: a randomized open parallel multicenter study. Diabetes Care. 2009;32(7):1170-6. [pmid: 19389820].
61 Thomas RM, Aldibbiat A, Griffin W, et al. A randomized pilot study in Type 1 diabetes complicated by severe hypoglycaemia, comparing rigorous hypoglycaemia avoidance with insulin analogue therapy, CSII or education alone. Diabet Med. 2007;24(7):778-83. [pmid: 17535290].
62 Tsui E, Barnie A, Ross S, et al. Intensive insulin therapy with insulin lispro: a randomized trial of continuous subcutaneous insulin infusion versus multiple daily insulin injection. Diabetes Care. 2001;24(10):1722-7. [pmid: 11574432].
63 Hoogma RP, Hammond PJ, Gomis R, et al. Comparison of the effects of continuous subcutaneous insulin infusion (CSII) and NPH-based multiple daily insulin injections (MDI) on glycaemic control and quality of life: results of the 5-nations trial. Diabet Med. 2006;23(2):141-7. [pmid: 16433711].
64 Hanaire-Broutin H, Melki V, Bessieres-Lacombe S, et al. Comparison of continuous subcutaneous insulin infusion and multiple daily injection regimens using insulin lispro in type 1 diabetic patients on intensified treatment: a randomized study. The Study Group for the Development of Pump Therapy in Diabetes. Diabetes Care. 2000;23(9):1232-5. [pmid: 10977011].
65 Bruttomesso D, Crazzolara D, Maran A, et al. In Type 1 diabetic patients with good glycaemic control, blood glucose variability is lower during continuous subcutaneous insulin infusion than during multiple daily injections with insulin glargine. Diabet Med. 2008;25(3):326-32. [pmid: 18307459].
66 DeVries JH, Snoek FJ, Kostense PJ, et al. A randomized trial of continuous subcutaneous insulin infusion and intensive injection therapy in type 1 diabetes for patients with long-standing poor glycemic control. Diabetes Care. 2002;25(11):2074-80. [pmid: 12401759].
67 Lepore G, Dodesini AR, Nosari I, et al. Both continuous subcutaneous insulin infusion and a multiple daily insulin injection regimen with glargine as basal insulin are equally better than traditional multiple daily insulin injection treatment. Diabetes Care. 2003;26(4):1321-2. [pmid: 12663625].
68 Stewart CE. New trends in diabetes management. Emerg Med Serv. 2001;30(11):80-8. [pmid: 11715797].
69 Herman WH, Ilag LL, Johnson SL, et al. A clinical trial of continuous subcutaneous insulin infusion versus multiple daily injections in older adults with type 2 diabetes. Diabetes Care. 2005;28(7):1568-73. [pmid: 15983302].
70 Derosa G, Maffioli P, D'Angelo A, et al. Effects of insulin therapy with continuous subcutaneous insulin infusion (CSII) in diabetic patients: comparison with multi-daily insulin injections therapy (MDI). Endocr J. 2009;56(4):571-8. [pmid: 19352055].
71 Johnson SL, McEwen LN, Newton CA, et al. The impact of continuous subcutaneous insulin infusion and multiple daily injections of insulin on glucose variability in older adults with type 2 diabetes. J Diabetes Complications. 2011;25(4):211-5. [pmid: 21062674].
72 Kernaghan D, Farrell T, Hammond P, et al. Fetal growth in women managed with insulin pump therapy compared to conventional insulin. Eur J Obstet Gynecol Reprod Biol. 2008;137(1):47-9. [pmid: 18006209].
73 Hieronimus S, Cupelli C, Bongain A, et al. Pregnancy in type 1 diabetes: insulin pump versus intensified conventional therapy. Gynecol Obstet Fertil. 2005;33(6):389-94. [pmid: 15927506].
74 Cypryk K, Kosinski M, Kaminska P, et al. Diabetes control and pregnancy outcomes in women with type 1 diabetes treated during pregnancy with continuous subcutaneous insulin infusion or multiple daily insulin injections. Pol Arch Med Wewn. 2008;118(6):339-44. [pmid: 18619188].
75 Volpe L, Pancani F, Aragona M, et al. Continuous subcutaneous insulin infusion and multiple dose insulin injections in Type 1 diabetic pregnant women: a case-control study. Gynecol Endocrinol. 2010;26(3):193-6. [pmid: 19728190].
76 Bruttomesso D, Bonomo M, Costa S, et al. Type 1 diabetes control and pregnancy outcomes in women treated with continuous subcutaneous insulin infusion (CSII) or with insulin glargine and multiple daily injections of rapid-acting insulin analogues (glargine-MDI). Diabetes Metab. 2011. [pmid: 21474360].
77 Chico A, Saigi I, Garcia-Patterson A, et al. Glycemic control and perinatal outcomes of pregnancies complicated by type 1 diabetes: influence of continuous subcutaneous insulin infusion and lispro insulin. Diabetes Technol Ther. 2010;12(12):937-45. [pmid: 21128840].
78 Wolf DE. Diabetes: novel therapeutic developments. 21-22 September 1999, London, UK. IDrugs. 1999;2(12):1292-4. [pmid: 16113961].
79 Zisser HC, Biersmith MA, Jovanovic LB, et al. Fetal risk assessment in pregnancies complicated by diabetes mellitus. J Diabetes Sci Technol. 2010;4(6):1368-73. [pmid: 21129331].
80 Kordonouri O, Pankowska E, Rami B, et al. Sensor-augmented pump therapy from the diagnosis of childhood type 1 diabetes: results of the Paediatric Onset Study (ONSET) after 12 months of treatment. Diabetologia. 2010;53(12):2487-95. [pmid: 20711715].
81 Raccah D, Sulmont V, Reznik Y, et al. Incremental value of continuous glucose monitoring when starting pump therapy in patients with poorly controlled type 1 diabetes: the RealTrend study. Diabetes Care. 2009;32(12):2245-50. [pmid: 19767384].
82 Beck RW, Lawrence JM, Laffel L, et al. Quality-of-life measures in children and adults with type 1 diabetes: Juvenile Diabetes Research Foundation Continuous Glucose Monitoring randomized trial. Diabetes Care. 2010;33(10):2175-7. [pmid: 20696865].
83 Radermecker RP, Saint Remy A, Scheen AJ, et al. Continuous glucose monitoring reduces both hypoglycaemia and HbA(1c) in hypoglycaemia-prone type 1 diabetic patients treated with a portable pump. Diabetes Metab. 2010. [pmid: 20864372].
84 The effect of continuous glucose monitoring in well-controlled type 1 diabetes. Diabetes Care. 2009;32(8):1378-83. [pmid: 19429875].
85 O'Connell MA, Donath S, O'Neal DN, et al. Glycaemic impact of patient-led use of sensor-guided pump therapy in type 1 diabetes: a randomised controlled trial. Diabetologia. 2009;52(7):1250-7. [pmid: 19396424].
86 Hirsch IB, Abelseth J, Bode BW, et al. Sensor-augmented insulin pump therapy: results of the first randomized treat-to-target study. Diabetes Technol Ther. 2008;10(5):377-83. [pmid: 18715214].
87 Deiss D, Bolinder J, Riveline JP, et al. Improved glycemic control in poorly controlled patients with type 1 diabetes using real-time continuous glucose monitoring. Diabetes Care. 2006;29(12):2730-2. [pmid: 17130215].
88 Battelino T, Phillip M, Bratina N, et al. Effect of continuous glucose monitoring on hypoglycemia in type 1 diabetes. Diabetes Care. 2011;34(4):795-800. [pmid: 21335621].
89 Sweeting MJ, Sutton AJ, Lambert PC. What to add to nothing? Use and avoidance of continuity corrections in meta-analysis of sparse data. Stat Med. 2004;23(9):1351-75. [pmid: 15116347].
90 Garg S, Jovanovic L. Relationship of fasting and hourly blood glucose levels to HbA1c values: safety, accuracy, and improvements in glucose profiles obtained using a 7-day continuous glucose sensor. Diabetes Care. 2006;29(12):2644-9. [pmid: 17130198].
91 Bergenstal RM, Tamborlane WV, Ahmann A, et al. Effectiveness of sensor-augmented insulin-pump therapy in type 1 diabetes. N Engl J Med. 2010;363(4):311-20. [pmid: 20587585].
92 Peyrot M, Rubin RR. Patient-reported outcomes for an integrated real-time continuous glucose monitoring/insulin pump system. Diabetes Technol Ther. 2009;11(1):57-62. [pmid: 19132857].
93 Lee SW, Sweeney T, Clausen D, et al. Combined insulin pump therapy with real-time continuous glucose monitoring significantly improves glycemic control compared to multiple daily injection therapy in pump naive patients with type 1 diabetes; single center pilot study experience. J Diabetes Sci Technol. 2007;1(3):400-4. [pmid: 19885096].
94 Hermanides J, Norgaard K, Bruttomesso D, et al. Sensor-augmented pump therapy lowers HbA(1c) in suboptimally controlled Type 1 diabetes; a randomized controlled trial. Diabet Med. 2011;28(10):1158-67. [pmid: 21294770].
95 Pickup JC, Harris A. Assessing quality of life for new diabetes treatments and technologies: a simple patient-centered score. J Diabetes Sci Technol. 2007;1(3):394-9. [pmid: 19885095].
96 Kapellen T, Kordonouri O, Pankowska E, et al. Sensor-augmented pump therapy from the onset of type 1 diabetes in children and adolescents - Results of the Pediatric ONSET Study after 12 months of treatment. Horm. Res. Paediatr. 2010;74:58.
97 Pankowska E, Blazik M, Dziechciarz P, et al. Continuous subcutaneous insulin infusion vs. multiple daily injections in children with type 1 diabetes: a systematic review and meta-analysis of randomized control trials. Pediatr Diabetes. 2009;10(1):52-8. [pmid: 18761648].
98 Fatourechi MM, Kudva YC, Murad MH, et al. Clinical review: Hypoglycemia with intensive insulin therapy: a systematic review and meta-analyses of randomized trials of continuous subcutaneous insulin infusion versus multiple daily injections. J Clin Endocrinol Metab. 2009;94(3):729-40. [pmid: 19088167].
99 Cummins E, Royle P, Snaith A, et al. Clinical effectiveness and cost-effectiveness of continuous subcutaneous insulin infusion for diabetes: systematic review and economic evaluation. Health Technol Assess. 2010;14(11):iii-iv. xi. xvi. 1. 181. [pmid: 20223123].
100 Klonoff DC, Buckingham B, Christiansen JS, et al. Continuous glucose monitoring: an endocrine society clinical practice guideline. J Clin Endocrinol Metab. 2011;96(10):2968-79. [pmid: 21976745].
101 Olsovsky J, Beranek M. The influence of long-term therapy with the insulin pump (CSII) in patients with type 1 diabetes mellitus on metabolic compensation and on the incidence of hypoglycaemia. Comparison with intensified conventional insulin therapy (MDI). Vnitr Lek. 2007;53(6):637-45. [pmid: 17702123].
102 Yoo HJ, An HG, Park SY, et al. Use of a real time continuous glucose monitoring system as a motivational device for poorly controlled type 2 diabetes. Diabetes Res Clin Pract. 2008;82(1):73-9. [pmid: 18701183].
103 Defining and reporting hypoglycemia in diabetes: a report from the American Diabetes Association Workgroup on Hypoglycemia. Diabetes Care. 2005;28(5):1245-9. [pmid: 15855602].
104 Centers for Disease Control and Prevention. CDC's Diabetes Program - Data & Trends - Prevalence of Diabetes. April. 2011. www.cdc.gov/diabetes/statistics/prev/national/figraceethsex.htm. July 2011.
105 Rigla M, Hernando ME, Gomez EJ, et al. Real-time continuous glucose monitoring together with telemedical assistance improves glycemic control and glucose stability in pump-treated patients. Diabetes Technol Ther. 2008;10(3):194-9. [pmid: 18473693].