# Peer Reviewers

Kelly Acton, M.D., M.P.H.

Health and Human Services

San Francisco, CA

Dorothy Becker, M.B.B.Ch.

Children’s Hospital of Pittsburgh

Pittsburgh, PA

Michael Freemark, M.D.

Duke University School of Medicine

Durham, NC

John M. Eisenberg Center for Clinical Decisions and Communications Science

Baylor College of Medicine

Houston, TX

Leonard Pogach, M.D., M.B.A

Veterans Affairs New Jersey Health Care System

East Orange, NJ

Philip Raskin, M.D.

UT Southwestern Medical Center

Dallas, TX

Robert Ratner, M.D.

Medstar Health Research Institute

Washington, DC

Marie Russell, M.D., M.P.H.

Phoenix Indian Medical Center

Phoenix, AZ

Phillip Zeitler, M.D.

Children’s Hospital Colorado

Aurora, CO