# Methods

Members of the health care community nominated this topic via the Agency for Healthcare Research and Quality's (AHRQ) Web site. Our Evidence-based Practice Center (EPC) established a team and a work plan to develop the evidence report. The project involved recruiting Key Informants, formulating and refining the questions, developing a protocol, recruiting Technical Experts, performing a comprehensive literature search, summarizing the state of the literature, constructing evidence tables, synthesizing the evidence, and submitting the report for peer review.

## Topic Development

Our panel of Key Informants gave input on key steps including the selection and refinement of the questions to be examined. The Key Informants included an internal expert from the Johns Hopkins University with expertise in diabetes management, and external experts, including a pediatric endocrinologist, an internist, and an obstetrician-gynecologist and perinatal epidemiologist. We posted our draft Key Questions on AHRQ's Web site in October of 2010 for public comment.

With the Key Informants, representatives of AHRQ, and public comments, we developed the Key Questions that are presented in the Scope and Key Questions section of the Introduction. The Key Questions focus on the comparative effectiveness and safety of insulin delivery (i.e., continuous subcutaneous insulin infusion [CSII] versus multiple daily injections [MDI]) and glucose monitoring methods (i.e., real-time continuous glucose monitoring [rt-CGM] versus self-monitoring of blood glucose [SMBG]) in patients with diabetes mellitus, and how these effects may differ by type of diabetes (i.e., type 1 diabetes or type 2 diabetes), age (i.e., very young children, adolescents, adults, and elderly), and pregnancy status (i.e., pregnant women with pre-existing type 1 or type 2 diabetes).

## Technical Expert Panel

We drafted a protocol to address the Key Questions. Our Key Informants also served as our Technical Expert Panel. The Technical Expert Panel reviewed our protocol, and provided feedback on the Key Questions and proposed methods. With the feedback from the Technical Expert Panel and AHRQ representatives, we finalized the protocol and posted it on AHRQ's website.

## Search Strategy

We searched the following databases for primary studies for the periods in parentheses: MEDLINE^®^ (1966 to July 2011), Embase^®^ (1974 to July 2011), and the Cochrane Central Register of Controlled Trials (1966 to July 2011). We developed a search strategy for MEDLINE, accessed via PubMed, based on an analysis of the medical subject headings (MeSH) terms and text words of key articles identified a priori (Appendix A).

We downloaded the results of the searches and imported into ProCite^®^ version 5 (ISI ResearchSoft, Carlsbad, CA). We scanned for exact article duplicates, author/title duplicates, and title duplicates using the duplication check feature in ProCite®. We uploaded the articles from ProCite to DistillerSR (Evidence Partners, Ottawa, Ontario, Canada), a Web-based software package developed for systematic review data management. We used this database to track the search results at the levels of title review, abstract review, article inclusion/exclusion, and data abstraction.

## Study Selection

Two independent reviewers conducted title scans in parallel. Both reviewers had to indicate that the title was ineligible for it to be eliminated at this level. If they disagreed, they promoted the article to the next level (Appendix B, Title Review Form). We designed the title review to capture as many studies as possible that reported on the efficacy or safety of insulin delivery or glucose monitoring methods.

Two investigators reviewed abstracts independently, and excluded an article if both investigators agreed it met one or more of the exclusion criteria (see inclusion and exclusion criteria listed in Table 2 and the Abstract Review Form in Appendix B). The team resolved differences between investigators regarding abstract eligibility through consensus adjudication.

Table 2 Inclusion and exclusion criteria

Population and condition of interest | All studies included human subjects exclusively. We included studies of adults, adolescents, and children with a formal diagnosis of diabetes mellitus and pregnant women with pre-existing diabetes. Acceptable diagnoses included type 1 diabetes and type 2 diabetes. We considered patients with latent autoimmune or pancreatomy to have type 1 diabetes. We considered patients with steroid-induced or transplant-induced diabetes to have type 2 diabetes. We excluded pregnant women with gestational diabetes. We excluded patients with maturity onset diabetes of the young, as the diagnosis is difficult to make without genetic testing and intensive insulin therapy is often not required.
Interventions | We included studies that evaluated CSII and rt-CGM (see Appendix C for list of devices). We excluded implantable insulin pumps as they are no longer used clinically and retrospective CGM devices, as the current clinical practice is to use rt-CGM. We excluded studies in which regular insulin was used in the insulin pump as this is not consistent with current clinical practice. We excluded studies evaluating the GlucoWatch CGM, as it is no longer used in the US.
Comparisons of interest | We included studies that compared CSII with MDI (i.e., at least 3 injections per day). We included studies using long and rapid-acting analog and/or NPH and regular insulin in the MDI arms because both regimens are still used in clinical practice. We included studies that compared rt-CGM with SMBG (i.e., at least 3 fingersticks per day). We excluded studies of premixed insulin, because patients who use a premixed insulin are rarely considered for intensive insulin therapy with CSII. We excluded studies that do not have a concurrent comparison group.
Outcomes | We included studies that evaluate one of the following outcomes: Process measures Ratio of basal to bolus insulin^*^ Frequency of adjusting insulin therapy Adherence to insulin therapy/sensor use Frequency of professional or allied health visits Intermediate outcomes HbA_1c_ Hyperglycemia Weight gain Hypoglycemia frequency Clinical outcomes Objective assessments of microvascular outcomes (nephropathy, retinopathy, and neuropathy) and macrovascular outcomes (coronary heart disease, cerebrovascular disease, and peripheral arterial disease) Severe hypoglycemia Quality of life (validated measures) Mortality Fetal outcomes (gestational age, birth weight, frequency of neonatal hypoglycemia, birth trauma, major and minor anomalies, admission to a neonatal intensive care unit) Maternal pregnancy outcomes (cesarean section rates)
Type of study | We excluded articles with no original data (reviews, editorials, and commentaries) or studies published in abstract form only. We excluded case reports, case series, and cross-sectional studies. We included both RCTs and observational studies that evaluated microvascular, macrovascular, maternal, or fetal outcomes. For all other outcomes, we included only RCTs. We did not place any restrictions on sample size or language. Because we excluded studies of outdated technologies, we excluded studies published before 1994, the 1st year that insulin analogues were used.
Timing and setting | We excluded studies in which patients used an insulin delivery or glucose monitoring device for less than 24 hours. We excluded studies that were not conducted in an outpatient setting.

CSII = continuous subcutaneous insulin infusion; HbA_1c_ = hemoglobin A_1c_; MDI = multiple daily injections; NPH = neutral protamine Hagedorn; RCT = randomized controlled trial; rt-CGM = real-time continuous glucose monitoring

* The optimal distribution of the total daily insulin dose is 40-50% administered as basal insulin and the remaining 50-60% as bolus insulin divided over each meal. This prevents patients from being over-insulinized with basal insulin, increasing risk for hypoglycemia.

Two reviewers performed another independent parallel full-text review of articles promoted on the basis of abstract review to determine if we should include these articles for data abstraction (Appendix B, Article Review Form). We resolved differences regarding article inclusion through consensus adjudication.

## Data Abstraction

We used a systematic approach to extract all data to minimize the risk of bias in this process. We created and pilot tested standardized forms for data extraction. By creating standardized forms for data extraction, we sought to maximize consistency in identifying all pertinent data available for synthesis.

The study investigators performed double data abstraction on each article. The second reviewer confirmed the first reviewer's abstracted data for completeness and accuracy. We formed reviewer pairs that included personnel with both clinical and methodological expertise. We did not hide from the reviewers the identity of the authors of the articles, their respective institutions, or the journals in which their articles were published.

For all articles, the reviewers extracted information on general study characteristics (e.g., study design, study period, and followup), study participants (e.g., age, gender, race, baseline HbA_1c_, weight, type of diabetes, duration of diabetes), eligibility criteria, interventions (including device model, type of insulin, MDI schedule, rt-CGM alarm threshold, length of use of current technology, changes in the type of insulin used, and training of patients/staff), adherence to wearing a treatment device, outcome measures, definitions, and the results of each outcome, including measures of variability. For the outcome of hypoglycemia, we differentiated between biochemical and symptomatic hypoglycemia. For the outcome of cesarean delivery, we abstracted information regarding the indication for cesarean delivery. For studies evaluating maternal and fetal outcomes, we abstracted information about when CSII or MDI was initiated in relation to the pregnancy (i.e., prenatal, 1st trimester, or 2nd trimester).

For this report, we classified quality of life measures into the following categories: general health-related quality of life (global, non-specific measures), disease-specific quality of life (quality of life and health status associated with diabetes) and treatment-specific quality of life (associated with carrying out treatment for diabetes). In each category we included only studies which used validated measures.

The individual completing the review entered all information from the article review process into a DistillerSR database (Evidence Partners Inc., Ottawa, Canada). Reviewers entered comments into the system whenever applicable. We used the DistillerSR database to maintain the data and to create detailed evidence tables and summary tables.

## Quality Assessment

We used different quality assessment tools for randomized controlled trials (RCTs) and observational studies. For RCTs, we based the dual, independent review of article quality on the Cochrane Collaboration's Risk of Bias Tool40 and supplemented with items from the Methods Guide for Effectiveness and Comparative Effectiveness Reviews.41 The quality assessment for RCTs included items on (1) adequate allocation sequence generation, (2) adequate allocation concealment, (3) blinding, (4) incomplete outcome data, (5) pharmaceutical support, (6) company involvement in the design, conduct, or reporting of the study, (7) loss to followup, and (8) an overall rating of the quality assessment. We assessed the overall study quality as:

- Good (low risk of bias). These studies had the least bias, and we considered the results valid. These studies adhered to the commonly held concepts of high quality, including the following: a clear description of the population, setting, interventions, and comparison groups; appropriate measurement of outcomes; appropriate statistical and analytic methods and reporting; no reporting errors; a low dropout rate; and clear reporting of dropouts.
- Fair. These studies were susceptible to some bias, but not enough to invalidate the results. They did not meet all the criteria required for a rating of good quality because they had some deficiencies, but no flaw was likely to cause major bias. The study may have been missing information, making it difficult to assess limitations and potential problems.
- Poor (high risk of bias). These studies had significant flaws that might have invalidated the results. They had serious errors in design, analysis, or reporting; large amounts of missing information; or discrepancies in reporting.41

For observational studies, we selected items from the Downs and Black quality checklist42 and supplemented with items from the Methods Guide for Effectiveness and Comparative Effectiveness Reviews.41 We assessed the quality of observational studies on: (1) clear description of the setting, (2) clear description of inclusion/exclusion criteria, (3) clear description of key characteristics on the enrolled subjects, (4) recruitment of the different intervention groups from the same population, (5) adequate adjustment for confounding, and (6) description of loss to followup.

We presented both the primary and secondary reviewers' responses in the appendix. We used our study quality assessment to help us understand differences in results between studies.

## Applicability

We assessed the applicability of studies in terms of how typical the study population (age, race, sex, and baseline HbA_1c_), interventions (titration schedule), outcomes, and settings (followup interval) were for the treatment of individuals with diabetes who are receiving treatment in a usual care setting. We limited the interventions in the review to those that are most applicable to the current population of patients with diabetes (i.e., those interventions that are currently used in the U.S. population).

## Data Analysis and Synthesis

For each Key Question, we created a set of detailed evidence tables containing all information extracted from eligible studies. We conducted meta-analyses when there were sufficient data (at least two trials) and studies were sufficiently homogenous with respect to key variables (population characteristics and study duration).

For continuous outcomes, we calculated a weighted mean difference between groups in the change scores by using a random-effects model with the DerSimonian and Laird formula.43 We recorded the mean difference in outcome between groups, along with its measure of dispersion. If the study did not report this information, we calculated the point estimate of the mean difference in outcome using the mean difference from baseline for each group or the baseline and final values for each group. We derived measures of dispersion using standard methods.40

We analyzed the outcome of severe hypoglycemia using two strategies. If studies reported the incidence of severe hypoglycemia (i.e., the number of patients who experienced severe hypoglycemia), then we calculated a pooled relative risk using the DerSimonian and Laird random effects model.43 If studies reported event rates (i.e., the number of events experienced per patient during the study period), we calculated a rate ratio in terms of the number of events per person-year using the DerSimonian and Laird random effects model.43

We tested heterogeneity among the trials in all the meta-analyses by using a standard chi-squared test with a significance level of alpha less than or equal to 0.10. We also examined heterogeneity among trials by using an I^2^ statistic, which describes the variability in effect estimates that is due to heterogeneity rather than random chance.44 We considered a value greater than 50 percent to have substantial variability. If we found substantial heterogeneity, we attempted to determine reasons for this by conducting meta-regression analyses using baseline HbA_1c_ and compliance. For all meta-analyses, we conducted formal tests for publication bias using Begg's45 and Egger's tests46 including evaluation of the asymmetry of funnel plots for each comparison of interest. All meta-analyses were conducted using STATA (Intercooled, version 9.2, StataCorp, College Station, TX).

We summarized studies not amenable to pooling qualitatively.

## Data Entry and Quality Control

After a second reviewer checked the data that had been entered into DistillerSR, he or she resubmitted adjudicated data using Web-based data collection forms. Second reviewers were generally more experienced members of the research team. Any problems with a reviewer's data abstraction were discussed at a meeting with the reviewers. In addition, research assistants used a system of random data checks to assure data abstraction accuracy.

## Rating the Body of Evidence

At the completion of our review, we graded the strength of the evidence addressing Key Questions 1 and 2 by adapting an evidence grading scheme recommended in the Methods Guide for Effectiveness and Comparative Effectiveness Reviews.47 We applied evidence grades to the bodies of evidence about each intervention comparison for each outcome. We assessed the strength of the body of best available evidence by assessing its limitations, consistency, directness, precision, publication bias, and the magnitude of the effect. We assessed the risk of bias of individual studies according to study design characteristics, such as confounding and selection and information biases. We rated the body of evidence as “consistent” if most of the studies showed the same direction of effect or if the I^2^ statistic from a meta-analysis was low. We rated the consistency of a single study as “unknown.” We rated the body of the evidence as “direct” if most of the studies evaluated the outcome directly and there were direct comparisons. We based our rating of precision on the width of the confidence intervals. For the outcomes of HbA_1c_, we rated the confidence interval as “precise” only when the width of the confidence interval was less than 0.5 percent. If a confidence interval could not be determined, then we rated precision as “cannot determine.” We based publication bias on the results of the funnel plots. If either the Egger's or Begg's tests suggested publication bias, then we rated publication bias as “yes.” If there was no meta-analysis, then we rated publication bias as “uncertain.”

We classified evidence bodies pertaining to Key Questions 1 and 2, into four basic categories: (1) “high” grade (indicating high confidence that the evidence reflects the true effect and further research is very unlikely to change our confidence in the estimate of the effect); (2) “moderate” grade (indicating moderate confidence that the evidence reflects the true effect and further research may change our confidence in the estimate of the effect and may change the estimate); (3) “low” grade (indicating low confidence that the evidence reflects the true effect and further research is likely to change our confidence in the estimate of the effect and is likely to change the estimate); and (4) “insufficient” grade (evidence is unavailable, does not permit a conclusion, or consists of only one study with high risk of bias).

## Peer Review and Public Commentary

Experts in adult and pediatric endocrinology and internal medicine and individuals representing stakeholder and user communities were invited to provide external peer review of this comparative effectiveness review; AHRQ and an associate editor also provided comments. The draft report was posted on the AHRQ Web site for 4 weeks to elicit public comment. We addressed all reviewer comments, revising the text as appropriate, and documented everything in a “disposition of comments report” that will be made available 3 months after AHRQ posts the final comparative effectiveness review on the AHRQ Web site.