# Introduction

## Burden of Diabetes and Its Classification

Diabetes mellitus is defined as a group of metabolic diseases characterized by hyperglycemia resulting from: defects in insulin secretion from the pancreatic beta cells; resistance to insulin action at the level of skeletal muscle, liver, and fat; or both. The resultant hyperglycemia, if untreated, can lead to long-term complications, including microvascular complications (e.g., retinopathy, nephropathy, and peripheral and autonomic neuropathy) and macrovascular complications (e.g., coronary heart disease, cerebrovascular disease, and peripheral arterial disease).1 The prevalence of diagnosed diabetes in the United States is currently 7.7 percent and is expected to increase to nearly 10 percent by 2050, at which time an estimated 39 million people will have diabetes in the United States.2-4 Therefore the already large number of people who require glucose-lowering therapies to maintain normal glucose levels (normoglycemia) and prevent diabetes complications, will likely only increase.

### Type 1 Diabetes Mellitus

Type 1 diabetes, which accounts for 5 to 10 percent of all diabetes cases, is characterized by autoimmune destruction of pancreatic islet cells that results in an inability to produce insulin and a need for daily insulin administration to sustain life.1 Individuals with type 1 diabetes require insulin to prevent life-threatening ketosis, to maintain normoglycemia without inducing significant hypoglycemia, and to maintain normal body weight and promote normal growth and development in children.1 The prevalence and incidence of type 1 diabetes is highest among non-Hispanic whites5 and lowest among Navajo Indians.6 African-American and Hispanic children have a similar incidence of type 1 diabetes,7 8 which is higher than in Asian American and Pacific Islander children.9

### Type 2 Diabetes Mellitus

Type 2 diabetes is the result of a combination of insulin resistance and impaired insulin secretion by the beta cells of the endocrine pancreas.1 Typically, insulin resistance predominates early, and insulin secretion decreases over time. However, the relative contribution of each of these factors to the disease course varies by patient. Eventually, the impairment in insulin resulting from beta cell dysfunction can lead to insulin deficiency, necessitating insulin therapy. Type 2 diabetes accounts for 90 to 95 percent of diabetes cases in the United States.1 Among adults, 20 years of age and older, the prevalences of diagnosed diabetes are 7.1 percent in non-Hispanic whites, 8.4 percent in Asian Americans, 11.8 percent in Hispanic Americans (primarily those of Mexican and Puerto Rican descent), and 12.6 percent in non-Hispanic blacks.10 The prevalence of diabetes increases with age and approximately 26.9 percent of adults 65 years of age and older have diagnosed and undiagnosed diabetes, the majority of which is type 2 diabetes.10

### Diabetes Mellitus in Pregnancy

In pregnant women with pre-existing type 1 or type 2 diabetes, poor glycemic control is associated with poorer pregnancy outcomes. Hyperglycemia early in pregnancy is associated with fetal anomalies, and hyperglycemia later in pregnancy can be associated with macrosomia, delivery complications, stillbirth, and neonatal hypoglycemia. The majority of pregnant women with pre-existing diabetes have type 1 diabetes.

## Importance of Tight Glycemic Control and Associated Risks in Diabetes

Evidence has shown that tight glycemic control with intensive insulin therapy reduces the risk of the microvascular and macrovascular complications of diabetes.11-14 Throughout the duration of pregnancy, physicians recommend tight glycemic control to avoid maternal, fetal, and neonatal complications.15 The role of tight glycemic control in older adults with diabetes is less well-established and physicians only recommend it for those who are functional, cognitively intact, and have a significant life expectancy.16 For older adults with advanced complications, life-limiting comorbidity, or significant functional or cognitive impairments, physicians recommend less intensive glycemic goals to avoid the adverse effects of hypoglycemia.16

While tight glycemic control lowers the risk of diabetic complications, it can increase the risk of hypoglycemia.13 Severe hypoglycemia, which can be life threatening, is an episode that requires another person to assist in treatment to resolve symptoms. Nonsevere hypoglycemia may be symptomatic, but individuals are able to correct it without assistance from others. Both types of hypoglycemic episodes can be a source of significant distress and anxiety to patients and a barrier to achieving tight glycemic control. Unawareness of hypoglycemia can be a factor in patients with long-standing diabetes complicated by recurrent hypoglycemia, putting patients at risk for severe hypoglycemic episodes.17 Finally, intensive insulin therapy can also lead to weight gain, due to more efficient fuel utilization and/or overtreatment of hypoglycemic episodes.18 19

### Measurement of Glycemic Control

The recommended method for assessing long-term glycemic control over the previous 2 to 3 months in patients with type 1 and type 2 diabetes is to measure glycosylated hemoglobin, specifically hemoglobin A_1c_ (HbA_1c_).20 The recommended method for assessing short-term glycemic control for patients using multiple insulin injections or insulin pump therapy is self-monitoring of blood glucose (SMBG) three or more times daily. This can also assist patients and their physicians in making short-term adjustments in insulin therapy.21 The role of SMBG is less clear for patients using less-frequent insulin injections, noninsulin therapies, or medical nutrition therapy.16 With pregnant women with diabetes, physicians make clinical management decisions on a weekly basis based on fasting and post-prandial glucose levels. They choose this method, as opposed to measuring HbA_1c_ every 3 months, because it provides the higher level of rapid feedback on glycemic control needed to prevent fetal complications.22

## Methods To Achieve Tight Glycemic Control and Minimize Risk: Advances in Insulin Delivery (Conventional Vs. Intensive Insulin Therapy)

Insulin therapy has evolved over the last 25 years to more closely mimic normal pancreatic physiology. In the past, conventional insulin therapy consisted of one to two injections of intermediate-acting insulin mixed with short-acting insulin before breakfast and dinner. Because of the pharmacokinetics of these older insulins, patients had a more difficult time achieving tight control. Furthermore, these older insulins often resulted in significant hypoglycemia due to their prolonged duration of action. This difficulty led to the development of more physiological basal and mealtime (prandial) insulins that, when used together, mimic normal pancreatic function (peakless basal insulin secretion, rapid release of insulin in response to meals, and rapid resolution of the prandial insulin peak). In addition, the development of continuous subcutaneous insulin infusion (CSII) via a pump provided another means to deliver insulin in a more physiological manner. Thus today, patients receive intensive insulin therapy as three or more daily insulin injections (i.e., multiple daily injections [MDI]) or by the use of the external CSII.

## Methods To Achieve Tight Glycemic Control and Minimize Risk: Advances in Glucose Monitoring

### Self-Monitoring of Blood Glucose

Following publication of the Diabetes Control and Complications Trial, SMBG by fingerstick replaced the assessment of glucose by urine dipstick and is now the most widely used technique. SMBG allows more specific and timely feedback on hyperglycemia and allows patients to evaluate their individual response to therapy and assess whether blood glucose targets have been achieved.18 Evidence has shown that SMBG is an effective component of successful diabetes treatment, especially for patients who are being treated with insulin injection or pump therapy.20 SMBG is also useful as a guide to adjust therapy for patients not on insulin, but there are fewer data on this population. In patients with type 2 diabetes, Welschen and colleagues found SMBG usage resulted in a 0.4 percent reduction of HbA_1c_ when compared with no usage.23 As patients also were receiving diet, exercise, and health education in addition to medications, it is not entirely clear that the effect was due to use of SMBG.23 The challenges to use of SMBG include the associated pain, costs, behavioral and technical skills, required motivation, and intrusiveness that affect adherence to this technique. Therefore, continuous glucose monitoring (CGM) systems have been developed in recent years to supplement SMBG.

### Continuous Glucose Monitoring System: Retrospective and Real-Time

A CGM system is a device that records blood glucose levels throughout the day and night and significantly decreases but does not eliminate the need for fingerstick measurements. The U.S. Food and Drug Administration (FDA) approved CGM devices as an adjunct to, not a substitute for, SMBG. Patients wore the first CGM systems for 3 to 5 days. Patients were unaware of their glucose readings until their health care professional downloaded and evaluated the data. Clinicians used the data retrospectively to make adjustments to on-going medical therapy.24

“Personal” or real-time continuous glucose monitoring (rt-CGM) systems, were first approved by the FDA in 2005. This equipment consists of a transcutaneous glucose sensor that is connected to a transmitter and receiver. Patients can use CGM systems in real time, retrospectively as noted above, and prospectively.25 Some show graphical representation of glucose levels, and some have adjustable alarms for alerts of high and low glucose values. Sensor-augmented pumps are also available that combine rt-CGM technology with CSII.26 Success in lowering blood glucose levels depends on adherence to ongoing use of the device.27 These devices are useful in detecting fluctuating blood glucoses and trends in changing blood glucoses, which are important in adjusting medications. Technologies for these devices are continuously improving.

rt-CGM differs from retrospective CGM in that it provides blood glucose feedback data to the patient while he or she is wearing the device and clinicians do not need to download and evaluate the data. When using rt-CGM, patients can also set alarms for hyperglycemia, hypoglycemia, or rapid glucose changes, thereby allowing patients to intervene earlier to prevent severe glycemic excursions.24 Because of these advantages, physicians prefer rt-CGM in the clinical setting. For this reason, the focus of our review will be on studies examining rt-CGM.

## Knowledge Gaps: Comparative Effectiveness of Insulin Delivery and Glucose Monitoring in Specific Diabetic Populations

### Clinical Decisionmaking and Indications

Physicians currently recommend CSII for patients with type 1 diabetes who are not achieving glycemic goals despite an adherence to a maximal MDI regimen. This is particularly true when patients have wide and erratic glycemic excursions, frequent severe hypoglycemia and/or hypoglycemia unawareness, or marked dawn phenomenon (pre-breakfast rise in blood glucose seen when bedtime basal insulin effect diminishes).28 29 Physicians also recommend CSII for patients who are pregnant or in preconception planning. Patients with type 1 diabetes might also consider CSII if they feel pump therapy may be more suitable to their lifestyle, regardless of the level of glycemic control.29 Compared with MDI, CSII has the advantage of providing a constant delivery of basal insulin, permitting a peakless insulin profile that is adjustable throughout the day, and decreasing glycemic variability by allowing controlled delivery of small insulin doses.28 While CSII eliminates the need for multiple daily needle injections compared to MDI, it is more costly than MDI therapy, increases the patient's risk for developing diabetic ketoacidosis if there is a pump malfunction due to the absence of long-acting basal insulin, and requires significant patient involvement to manage CSII procedures.28 MDI therapy using insulin analogs can achieve more predictable and constant blood insulin levels and is cheaper, easier to use, not subject to malfunction, and requires less staff supervision than CSII.28

Physicians currently recommend rt-CGM for patients with type 1 diabetes who have hypoglycemia unawareness, frequent hypoglycemia where their HbA_1c_ is over the recommended target, or who have excess glycemic excursions. They also recommend rt-CGM for patients who are in preconception planning or pregnant.24 While SMBG requires frequent fingerstick checks that cause patient discomfort, there are some disadvantages to rt-CGM compared with SMBG. First, since FDA approves rt-CGM only as an adjunctive device to SMBG, it does not eliminate the need for fingersticks. Second, rt-CGM is not as accurate in glucose determinations as glucose meters. Finally, there is a 5-10 minute physiological lag between blood (SMBG) and interstitial space glucose (measured by rt-CGM). This lag is more pronounced when glucoses are changing rapidly, potentially leading to patient-driven insulin stacking and/or overtreatment of hypoglycemia.24

Given new technologies in insulin delivery and glucose monitoring, clinicians are now faced with determining which patient populations benefit most from the use of CSII and rt-CGM in terms of improved glycemic, clinical, and patient-reported outcomes. Because both technologies are expensive and require extensive training and oversight by health care professionals, it is critical to determine how to select patients for their use.

### Type 1 Diabetes Mellitus

#### Comparison of CSII With MDI

In prior systematic reviews, the majority of the evidence from comparisons of CSII with MDI in adult patients with type 1 diabetes indicates CSII results in better glycemic control, although its impact on other clinical outcome measures are less clear.30-33 Research is inconclusive regarding the benefit of CSII for glycemic control and clinical outcomes in children and older adults with type 1 diabetes. In all of these populations, CSII use may be linked to uncontrolled hyperglycemia, because of device malfunction, or local catheter site infections. Therefore further research is warranted in order to determine the risks and benefits and cost-effectiveness of this expensive technology. Because prior meta-analyses and systematic reviews have included studies using regular insulin in the CSII arms, they have not been able to determine the comparative effectiveness of MDI with rapid-acting analog-based CSII, which is the current practice.30-33

#### Comparison of rt-CGM With SMBG

A recent published meta-analysis comparing rt-CGM with SMBG in type 1 diabetes showed a benfit of rt-CGM in improving glycemic control with no difference in hypoglycemia frequency; however, other non-glycemic outcomes were not reported.34 Prior studies suggest that those who benefit most are adults and individuals compliant with regular sensor use,24 34 but this needs to be confirmed. Clinicians can combine rt-CGM with CSII therapy in the form of a sensor-augmented pump. However, to our knowledge, there has not been a systematic review comparing sensor-augmented pump therapy (CSII and rt-CGM) with intensive insulin therapy (CSII or MDI) and SMBG.

### Type 2 Diabetes Mellitus

#### Comparison of CSII With MDI

For individuals with type 2 diabetes, it is unclear how CSII compares with MDI in improving glycemic and other outcomes.31 35 While some studies suggest that CSII is comparable with MDI in attaining adequate glycemic control,31 36 other studies found a lower HbA_1c_ level with CSII than with MDI.37 38 One prior meta-analysis found no significant difference in HbA_1c_ and hypoglycemic episodes between the CSII and MDI groups; however, this review included studies where regular insulin was used in the CSII arms.35 This remains a relevant question for individuals with type 2 diabetes being treated with intensive insulin therapy.

#### Comparison of rt-CGM With SMBG

To our knowledge, there is no systematic review of the comparative effectiveness of rt-CGM and SMBG and sensor-augmented pumps and intensive insulin therapy with SMBG on glycemic control, hypoglycemia frequency, and other clinically relevant outcomes in individuals with type 2 diabetes.

### Diabetes in Pregnancy

#### Comparison of CSII With MDI

We found one systematic review of randomized controlled trials (RCTs) published in 2007 that compared CSII with MDI in pregnant women who had pre-existing type 1 or type 2 diabetes.39 The resulting review included only 60 women with 61 pregnancies. Mean birth weight was greater with CSII than with MDI, however, the authors did not think that was clinically significant. There were insufficient data to permit conclusions about other outcomes, such as perinatal mortality, major and minor fetal anomalies, hypoglycemia, hyperglycemia, and admission to the neonatal intensive care unit for treatment of hypoglycemia. It is, therefore, important to determine if there is a clinical benefit to using CSII in pregnancy since this is one group for which CSII is currently recommended.

The evidence base for the comparison of MDI with CSII in pregnant women with pre-existing type 2 diabetes is small. This topic is increasingly important as the prevalence of type 2 diabetes has been increasing dramatically in younger populations, including women of childbearing age.

#### Comparison of rt-CGM With SMBG

rt-CGM and sensor-augmented pumps are new technologies and the evidence is not clear as to whether pregnant women with pre-existing type 1 or type 2 diabetes would benefit from these therapies, although, the theoretical utility of this tool in improving neonatal outcomes is great.

## Scope of the Review

Our systematic review will help to address the clinically relevant question of whether the mode of intensive insulin therapy (CSII versus MDI) has a differential effect on outcomes in individuals with type 1 diabetes, type 2 diabetes, or pre-existing diabetes in pregnancy. We will also determine whether these outcomes differ by the type of strategy used for blood glucose monitoring (rt-CGM versus SMBG) in those same populations. Finally, based on the studies available in the literature, we will attempt to determine if there is an interaction between types of intensive insulin-delivery methods and blood glucose-monitoring systems on our outcomes of interest. As these effects may differ by age, we will stratify available data by the age of the study populations. Answers to these questions will facilitate clinical decisionmaking regarding appropriate modes of insulin delivery and glucose monitoring for various populations of individuals with diabetes so that therapeutic options can be selected that result in improved outcomes.

Table 1 lists the outcomes included in our review. Figure 1 graphically depicts our Key Questions.

Table 1 Summary of process measures, intermediate outcomes, and clinical outcomes relevant to studies of intensive insulin therapy and continuous glucose monitoring

Process Measures | Intermediate Outcomes | Clinical Outcomes
Ratio of basal to bolus insulin Frequency of adjusting insulin therapy Adherence to insulin therapy/sensor use Frequency of professional or allied health visits | [underlined: Primary] Hemoglobin A_1c_ [underlined: Secondary] Hyperglycemia Weight gain Hypoglycemia frequency | [underlined: Microvascular]^*^ Nephropathy Retinopathy Neuropathy [underlined: Macrovascular]^*^ Coronary heart disease Cerebrovascular disease Peripheral arterial disease [underlined: Severe hypoglycemia] [underlined: Quality of life] [underlined: Mortality] [underlined: Fetal outcomes]^†^ [underlined: Maternal pregnancy outcomes] C-section rates

* We only included objective assessments of microvascular and macrovascular outcomes (i.e., we will be excluded patient self-reported microvascular and macrovascular outcomes).

† Fetal outcomes include gestational age, birth weight, frequency of neonatal hypoglycemia, birth trauma, major and minor anomalies, admission to a neonatal intensive care unit, stillbirth, neonatal and perinatal mortality.

Figure 1 Analytic framework for multiple daily injections or insulin pump therapy with or without continuous glucose mointoring for diabetes

CSII = continuous subcutaneous insulin infusion; KQ = key question; MDI = multiple daily injections; rt-CGM = real-time continuous glucose monitoring; SMBG = self-monitoring of blood glucose

^*^Fetal outcomes include gestational age, birth weight, frequency of neonatal hypoglycemia, birth trauma, major and minor anomalies, admission to a neonatal intensive care unit, stillbirth, neonatal and perinatal mortality.

^†^Maternal outcomes include cesarean section rates.

Note: Stratifications of interest for KQ2: diabetes status (2a), age (2b), pregnancy status (2c), and glucose monitoring strategy (2d)

Figure 1 is our analytic framework that graphically displays our key questions. It starts with the population of interest, who has various options for intensive insulin therapy, which can affect 3 types of outcomes: process measures, intermediate health outcomes, and clinical outcomes. The population of interest is the diabetic population on intensive insulin therapy. Within this population, we would investigate how our results differ by: a) type 1 or type 2 diabetes status, b) age: very young children, adolescents, adults, and elderly, and c) pregnancy status: pre-existing type 1 and type 2 diabetes. Intensive insulin therapy can be described in terms of how insulin is delivered and how blood glucose is monitored. Intensive insulin therapy can be delivered either through continuous subcutaneous insulin infusion (CSII) or through multiple daily injections (MDI). There are two types of blood glucose monitoring techniques: real-time continuous glucose monitoring (rt-CGM) or self-monitoring of blood glucose (SMBG). Those who monitor their blood glucose through rt-CGM can either deliver their insulin through CSII or MDI. Process measures include: ratio of basal to bolus insulin, frequency of adjusting insulin therapy, adherence to insulin therapy or sensor use, and frequency of professional or allied health visits. Intermediate health outcomes include HbA1c (primary outcome), and quality of life, hyperglycemia, weight gain, and hypoglycemia frequency (secondary outcomes). Clinical outcomes include microvascular events (nephropathy, retinopathy, and neuropathy), macrovascular events (coronary heart disease, cerebrovascular disease, and peripheral arterial disease), severe hypoglycemia, fetal outcomes (gestational age, birth weight, frequency of neonatal hypoglycemia, birth trauma, major and minor anomalies, and neonatal intensive care unit admission), and maternal outcomes (c-section rates). In our review, we are investigating two questions: In patients receiving intensive insulin therapy, does CSII versus MDI have a differential effect on process measures and health outcomes (KQ1)? In patients receiving intensive insulin therapy, does rt-CGM versus SMBG have a differential effect on process measures and health outcomes (KQ2)? For KQ2a, b, and c, the comparison is rt-CGM/CSII + rt-CGM/MDI versus SMBGSCII + SMBGMDI. For KQ2d, the comparisons are rt-CGM/CSII versus SMBG/CSII, rt-CGM/MDI versus SMBG/MDI, and the difference between rt-CGM/CSII and SMBG/CSII compared with the difference between rt-CGM/MDI and SMBG/MDI.

## Key Questions

Key Question 1 In patients receiving intensive insulin therapy, does mode of delivery (CSII versus MDI) have a differential effect on process measures, intermediate outcomes, and clinical outcomes in patients with diabetes mellitus? Do these effects differ by:
  a. Type 1 or type 2 diabetes status?
  b. Age: very young children, adolescents, and adults, including older adults (age >65 years)?
  c. Pregnancy status: pre-existing type 1 or type 2 diabetes?
Key Question 2 In patients using intensive insulin therapy (MDI or CSII), does the type of glucose monitoring (rt-CGM versus SMBG) have a differential effect on process measures, intermediate outcomes, and clinical outcomes in patients with diabetes mellitus. Do these effects differ by:
  a. Type 1 or type 2 diabetes status?
  b. Age: very young children, adolescents, and adults, including older adults (age >65 years)?
  c. Pregnancy status: pre-existing type 1 or type 2 diabetes?
  d. Intensive insulin delivery: MDI or CSII?