# Discussion

## Summary of Key Findings

Our systematic review summarizes the current state of the evidence on the effectiveness and safety of methods for intensive insulin delivery used in clinical practice and glucose monitoring in terms of diabetes-related process measures, intermediate outcomes, and clinical outcomes in individuals with type 1 and type 2 diabetes mellitus. Although studies have reported on a number of process measures and intermediate outcomes (as summarized below), we did not find any studies comparing continuous subcutaneous insulin infusion (CSII) with multiple daily injections (MDI) or comparing real-time continuous glucose monitoring (rt-CGM) with self-monitoring of blood glucose (SMBG) for certain process measures (frequency of adjusting insulin therapy, adherence to therapy, and health visits) or for clinical outcomes (microvascular and macrovascular disease).

### Comparative Effectiveness of CSII Versus MDI (KQ1)

Randomized controlled trails (RCTs) showed no difference in the effect on hemoglobin A_1c_ (HbA_1c_) between the CSII and MDI intervention groups for children and adolescents or pregnant women with type 1 diabetes, or for adults with type 2 diabetes. In adults with type 1 diabetes, CSII showed favorable effect on glycemic control, but the result was influenced by one study66 where participants had higher HbA_1c_ values at enrollment, allowing for greater HbA_1c_ lowering compared with the other studies were participants were closer to the HbA_1c_ target at enrollment. The trials also showed no difference in rates of severe hypoglycemia between the two intervention groups for children and adolescents, or adults with type 1 diabetes, or adults with type 2 diabetes. The evidence was insufficient to draw definitive conclusions about severe hypoglycemia rates in pregnant women with type 1 diabetes.

In most studies of children, adolescents and adults with type 1 diabetes, CSII use resulted in improvement in both general and diabetes-specific quality of life (QOL) measures, when compared with MDI. The evidence was insufficient to draw definitive conclusions about QOL for pregnant women with type 1 diabetes or adults with type 2 diabetes.

In pregnant women with pre-existing type 1 diabetes, observational studies showed no difference in gestational age at delivery between the CSII and MDI intervention groups. Because of the small number of studies of fair to poor quality in this population, the evidence was insufficient to draw definitive conclusions about other maternal and fetal outcomes.

Our systematic review and meta-analysis of the comparative effectiveness of CSII and MDI on outcomes, complements and extends previously published meta-analyses by: (1) including more studies of individuals with type 2 diabetes as well as pregnant women with pre-existing type 1 diabetes,30-32 35 97 (2) only including studies using rapidly-acting insulin analogs and not regular insulin in the CSII intervention groups,30-32 35 and (3) requiring the MDI groups to be receiving at least three injections per day, the current standard for intensive insulin therapy.31 33 97 98 We believe that these latter two distinctions are extremely important since these characteristics of intensive insulin therapy best reflect current clinical practice. Unlike one of the prior meta-analyses and systematic reviews31 32 and similar to others,33 35 97 98 we excluded before and after studies and only included RCTs in our combined estimates for HbA_1c_ and severe hypoglycemia. We also examined additional nonglycemic outcomes, including weight gain, ratio of basal to bolus insulin, and QOL. Unfortunately, for some of the defined outcomes—process measures (e.g., ratio of basal to bolus insulin), weight gain, nonsevere hypoglycemia, and hyperglycemia — the evidence was insufficient to draw definitive conclusions in any population of diabetic individuals about the comparative effectiveness of CSII versus MDI or rt-CGM versus SMBG.

We found that CSII had no significant effect on lowering HbA_1c_ in children (a drop of 0.14 percent) when compared with MDI and that there was no effect in adults with type 1 diabetes. A prior meta-analysis in children with type 1 diabetes found a significant (0.24 percent) reduction in HbA_1c_ favoring CSII; however, the prior meta-analysis included studies in which there were less than three daily injections in the MDI arm.97 This may have biased the results to favor CSII since the MDI arm was less intensive than CSII. Prior meta-analyses combining RCTs in children and adults with type 1 diabetes have shown HbA_1c_ reductions of 0.21 to 0.4 percent, favoring CSII.30-33 Several, however, included studies in which regular insulin was used in the pump31 32 or the MDI arm included less than three daily injections.33 In contrast to our meta-analysis, two prior reviews did not find a difference between CSII and MDI in the effect on HbA_1c_ in adults with type 1 diabetes,98 although one systematic review did not perform a quantitative summary.99 Our results, however, were heavily influence by one study and when that study was excluded in a sensitivity analysis, CSII and MDI had a similar effect on HbA_1c_ in adults with type 1 diabetes. Our estimates are based on a larger number of RCTs using rapid-acting analogs only in the CSII arms and at least three daily injections in the MDI arms, making them comparable in intensity to CSII (total of 11—7 in children and adolescents and 4 in adults). In general, while prior meta-analyses of RCTs have shown a statistically significant reduction in HbA_1c_ favoring CSII, none reached what is considered a clinically meaningful difference of 0.5 percent.99 Prior meta-analyses that have shown larger effect sizes favoring CSII have included before and after studies which may be subject to selection bias and confounding (i.e., individuals doing poorly on MDI are more likely to be switched to CSII and then improve).30 99

Similar to a prior meta-analysis we found severe hypoglycemia rates in type 1 diabetes to be similar between the MDI and CSII groups (incidence rate ratio=0.99 in children and adolescents and 0.74 in adults).98 While two prior analyses found a significantly higher rate of severe hypoglycemia with MDI compared with CSII, one of these only included studies if individuals reported an elevated frequency of baseline severe hypoglycemic episodes, which may have resulted in a greater likelihood of improvement.30 The other included studies that used regular insulin in the CSII arms, which would be expected to result in less hypoglycemia than regular insulin with MDI due to more steady insulin delivery.32 Similar to two prior systematic reviews, there was no difference in HbA_1c_ or hypoglycemia frequency with CSII versus MDI in adults with type 2 diabetes.35 98 99 Our meta-analysis is distinct from prior reviews in that it includes additional studies not reported previously using current rapid-acting analogs in the CSII arms,35 and it provides a quantitative effect estimate.99

### Comparative Effectiveness of rt-CGM Versus SMBG (KQ2)

We only found studies of the comparative effectiveness of rt-CGM versus SMBG in children, adolescents, and adults with type 1 diabetes. While prior studies have examined the effect of retrospective continuous glucose monitoring (CGM) in pregnant women with diabetes, no studies have compared rt-CGM with SMBG in this population.24 These two glucose monitoring approaches have not been compared in individuals with type 2 diabetes.

Compared with the SMBG group, the rt-CGM group achieved a lower HbA_1c_ (-0.3 percent). A sensitivity analysis showed this effect to be greater in studies where sensor compliance was 60 percent or greater (-0.36 percent). We also found that rt-CGM was associated with a lower HbA_1c_ compared with SMBG in individuals 18 years of age or younger. These findings support recent clinical practice recommendations suggesting rt-CGM use in children and adolescents over the age of 8 years.100 The intervention groups did not differ in the rate of severe hypoglycemia; however, there was a significant reduction in the time spent in the hyperglycemic range. A few studies that evaluated QOL found no difference between general and diabetes-specific QOL between the two intervention groups.

Our systematic review and meta-analysis of the comparative effectiveness of rt-CGM and SMBG on outcomes complements and extends a recently published meta-analysis34 by including additional non-glycemic outcomes, including weight gain, ratio of basal to bolus insulin, and QOL. We also found that rt-CGM lowered HbA_1c_ more than SMBG (-0.28 percent in our study versus -0.30 percent in Pickup et al.) and that there was no difference in severe hypoglycemia in the two intervention groups.34 Although statistically significant, these differences are below the 0.5 percent HbA_1c_ difference that experts consider clinically meaningful.99 In addition, in one study that evaluated the fear of hypoglycemia, the fear was less with rt-CGM than with SMBG.82 This has important clinical implications as the goal of intensive insulin therapy is to lower HbA_1c_ without inducing severe hypoglycemia, which can cause significant patient anxiety and be a barrier to safely improving glycemic control.

### Comparative Effectiveness of Sensor-Augmented Pump Versus MDI/SMBG (KQ2)

Sensor-augmented pump use resulted in a statistically and clinically significant greater reduction in HbA_1c_ compared with MDI/SMBG use in non-pregnant individuals with type 1 diabetes (-0.61 percent). The evidence was insufficient to draw definitive conclusions about severe hypoglycemia or quality life. No previous meta-analysis examined this comparison.

## Limitations

Our systematic review highlights important weaknesses in the literature. Most RCTs examining the effect of insulin delivery and glucose monitoring devices were small, with the largest trial including 322 participants.48 The majority of studies, particularly those comparing CSII with MDI, were fair to poor quality and did not report most quality items of interest. Most studies did not report the racial and ethnic composition of the study populations; however, for those that did, the majority of participants were Caucasian. Since few studies focused on or included children 12 years of age or younger, adults 65 years of age or older, or pregnant women with pre-existing type 2 diabetes, we were unable to draw conclusions about the effectiveness of insulin delivery and glucose monitoring methods in these populations. However, this likely reflects that fact that type 1 diabetes is much rarer in minority and elderly individuals and few pregnant women have pre-existing type 2 diabetes, making it less feasible and relevant to perform studies in these sub-populations. The studies were heterogeneous in definitions of nonsevere hypoglycemia, hyperglycemia, and weight gain, preventing us from combining data to determine effect estimates for these intermediate outcomes. While the definition of severe hypoglycemia in many studies included a requirement for third party assistance, it was not explicitly stated in all studies, so we were unable to determine if other definitions, such as a uniform glucose cut-point or hypoglycemia treatment approach, correctly classified individuals as having severe hypoglycemia. In studies comparing CSII and MDI, differences in the insulin regimen in the MDI arms (NPH and regular insulin versus analog insulin-based) may have been a source of heterogeneity; however, we had inadequate power to stratify by the MDI insulin regimen. Presumably greater use of NPH and regular insulin-based MDI would have biased results to the null for glycemic and quality of life outcomes. None of the studies included data on long-term diabetes micro- and macrovascular complications. This is likely related to the fact that these complications develop over many years and the longest follow-up of our studies was 52 weeks. While data on these outcomes would be ideal, it would require a very large RCT of several years duration, which may not be feasible to perform, particularly because individuals may switch therapies over time. In the pregnancy literature, none of the studies in women with pre-existing type 1 diabetes have examined the effect of rt-CGM on maternal and fetal outcomes. Other than the rt-CGM studies, the majority of studies did not report data on treatment adherence. The high baseline HbA_1c_ values in the CSII and MDI intervention groups in many studies may indicate poor adherence to prior as well as intervention treatments which may have biased results to the null (although there is also greater room for improvement). Finally, the studies were heterogeneous in assessing and reporting QOL outcomes, which prevented us from quantifying the effects of insulin delivery and glucose monitoring methods on QOL. We found no studies examining the comparative effectiveness of CSII versus MDI on QOL in pregnant women and only one study examining the effects on QOL in type 2 diabetes.

Our systematic review and meta-analysis had several limitations. Meta-analyses in general are subject to bias based on selection criteria for articles, performing multiple comparisons, and the state of the available literature. We reviewed studies of current therapies and methods for intensive insulin therapy and glucose monitoring. We cannot exclude the possibility that publication bias affected our findings. For the meta-analyses examining the comparative effectiveness of CSII versus MDI and rt-CGM versus SMBG on HbA_1c_ and severe hypoglycemia, we did not find evidence of publication bias; however, for our other glycemic (hyperglycemia, nonsevere hypoglycemia) and non-glycemic outcomes for which we could not perform meta-analyses, we were unable to assess for publication bias. We may have not included all studies on this topic; however, our search strategy was comprehensive and included non-English language publications. There was only one article identified that we were unable to translate.101 Our meta-regression to examine potential sources of heterogeneity in the effect of rt-CGM versus SMBG on HbA_1c_ was a post hoc analysis and is hypothesis-generating as opposed to hypothesis-testing.

Our data are not generalizable to non-specialty settings or all patients with diabetes mellitus, as the initiation, instruction, monitoring, and therapeutic changes for CSII and rt-CGM use is often limited to expert settings and highly motivated patients and families. All studies of rt-CGM are subject to ascertainment bias because rt-CGM provides more hypoglycemia and hyperglycemia data than SMBG alone. Because it is not feasible to keep patients blinded in an RCT comparing CSII with MDI or in an RCT comparing rt-SGM with SMBG, studies of QOL outcomes could have been vulnerable to reporting bias if patients believed that CSII and rt-CGM were superior. Finally, all of the studies included in our review were efficacy studies (as opposed to effectiveness studies) and 19 of the 41 excluded individuals with comorbidities such as impaired liver and renal function, microvascular complications, cardiovascular disease, mental disorders, recent severe hypoglycemia, or other chronic medical conditions,36 49-51 54 57 59 60 62-66 69 70 85 94 94 102 making results less generalizable to entire population of individuals with diabetes (see Appendix E, Table 1).

## Implications

Our findings indicate that intensive insulin therapy delivered either by CSII and MDI using current rapidly-acting insulin analogs with CSII are about equally effective in lowering HbA_1c_ in several diabetic patient populations—adolescents and pregnant women with type 1 diabetes. Our findings suggest that CSII is superior to MDI in lowering HbA_1c_ in adults with type 1 diabetes, although the results were heavily influenced by one study. Intensive insulin therapy delivered by both methods resulted in similar rates of severe hypoglycemia for adolescents and adults with type 1 diabetes. However, from a patient-focused perspective, adolescents and adults with type 1 diabetes treated with CSII reported better overall QOL compared with those treated with MDI. Taken together, these data suggest that the approach to intensive insulin therapy to optimize glycemic control can be individualized to patient preference that will maximize their treatment satisfaction and QOL, as both CSII and MDI using current rapid-acting insulin analogs have similar effectiveness for glycemic control.

To our knowledge this is the first systematic review and meta-analysis to examine the comparative effectiveness of both rt-CGM versus SMBG and of sensor-augmented pump versus MDI/SMBG. Our findings indicate that rt-CGM is superior to SMBG in lowering HbA_1c_, without increasing or decreasing the risk of severe hypoglycemia, in non-pregnant individuals with type 1 diabetes, particularly those who are compliant with wearing the monitoring device (HbA_1c_ reduction 0.28 percent for all studies versus 0.37 percent in studies with greater than 60 percent sensor compliance rate). The addition of rt-CGM to CSII is superior to MDI/SMBG in lowering HbA_1c_. Thus, the addition of this monitoring method to SMBG and intensive insulin therapy can assist in achieving glycemic targets in non-pregnant individuals with type 1 diabetes. The available literature does not allow us to determine the comparative effectiveness of rt-CGM versus SMBG in patients only using CSII or only using MDI because the modes of intensive insulin therapy were mixed in the available studies.

## Future Research

Our report highlights the need for several areas of future research examining the effect of insulin delivery and glucose monitoring devices in the management of diabetes mellitus. We identified a need for well-conducted RCTs of intensive insulin therapy delivered via CSII versus MDI in young children with type 1 diabetes and in pregnant women and elderly patients with both type 1 and type 2 diabetes. Studies in the elderly are important as diabetes prevalence increases with age2 and because older individuals may be at increased risk for adverse outcomes associated with intensive insulin therapy, it is important to know which insulin delivery and glucose monitoring methods are most effective. Only a small number of studies in nonadolescent children have compared CSII with MDI on glycemic and non-glycemic outcomes and studies comparing rt-CGM with SMBG have included a mixture of children and adults without stratifications focused exclusively on the young. Current studies examining the comparative effectiveness of rt-CGM versus SMBG on outcomes have included mixed populations receiving intensive insulin therapy as CSII and/or MDI; however, they have not determined the effect of these two glucose monitoring strategies in individuals treated with only CSII or only MDI. Such a study would help to elucidate whether the observed benefit of sensor-augmented pump compared with MDI/SMBG on glycemic control is secondary to the rt-CGM technology, the mode of intensive insulin delivery, or both. To allow cross-comparisons, future RCTs should use a uniform definition of hypoglycemia, preferably that recommended by the American Diabetes Association.103 There is also a need for well-designed prospective, observational studies to determine the comparative effectiveness of CSII versus MDI and rtCGM versus SMBG on clinically relevant long-term micro- and macrovascular outcomes. Such studies would also provide guidance on effect sizes for future power calculations to determine whether it is feasible to undertake RCTs examining these outcomes. Future studies should also seek to identify and use an agreed-upon set of general and diabetes-specific and treatment-related QOL measures to allow comparisons across studies, including reporting of standard errors and confidence intervals to allow quantitative, pooled assessments. Studies should incorporate measures of adherence to treatment as adherence is important for the effectiveness of any intensive insulin therapy or glucose monitoring system. Our data and others show that rt-CGM is most effective in those compliant with wearing the sensor at least 60 percent of the time.34 84 Thus, sensor compliance may be a marker for overall treatment adherence and explain the HbA_1c_ reduction, independent of the sensor. Future studies should focus on individuals with type 2 diabetes requiring insulin to determine the most effective manner in which to delivery intensive insulin therapy and monitor blood glucose. Given the rise in prevalence of type 2 diabetes in the general population, the number of those individuals requiring insulin therapy will likely rise. Finally, studies of type 2 diabetes should include ethnically diverse populations because type 2 diabetes is more common in nonwhites104 and minority individuals are at higher risk for adverse outcome, which might be positively or negatively impacted by the approach to intensive insulin delivery and/or glucose monitoring method.