# Evidence Tables

Table 1 Study design characteristics of studies comparing insulin delivery or glucose monitoring methods for diabetes mellitus

Table 2 Study population characteristics of studies comparing insulin delivery or glucose monitoring methods for diabetes mellitus

Table 3 Interventions evaluated in studies comparing insulin delivery or glucose monitoring methods for diabetes mellitus

Table 4 Outcomes of studies comparing insulin delivery or glucose monitoring methods for diabetes mellitus

Table 5 Study quality of randomized controlled trials comparing insulin delivery or glucose monitoring methods for diabetes mellitus

Table 6 Study quality of observational studies comparing insulin delivery or glucose monitoring methods for diabetes mellitus