# List of Devices

Appendix Table A List of insulin pump models

Manufacturer | Model | Decision Date | Features
Abbott
| Insulin Pump | 12/23/05 | Insulin pumps are indicated for the continuous delivery of insulin, at set and variable rates, for the management of diabetes mellitus in persons requiring insulin.
| Aviator | 1/11/08 | The Aviator insulin pump shares the same intended use and indications for use as the predicate device, the Abbott Diabetes Care infusion pump. Both the Aviator infusion pump and the predicate pump have two microprocessors to control and monitor drug delivery. The user interface on the Aviator was enhanced as a result of user needs.
| Freestyle Aviator | 2/20/09 | Insulin pump and BGM system-insulin infusion pump (Aviator) and wireless remote controller (Aviator companion). Aviator companion provides an alternate user interface to the Aviator pump which is useful when pump is hidden under clothing.
Animas
| Model IR 1000 | 2/10/00 | Subcutaneous delivery of insulin at programmable basal and bolus rates.
| Model IR 1000 LR | 05/29/02 | Insulin infusion pump and software for histories, basal rate program, and pump settings.
| Model IR 1200 | 10/16/03 | The system will deliver a prescribed dosage of insulin as a single programmable bolus or at multiple programmable basal rates. The system will also provide set-up information, dosage history, alarms, error and warning messages, device status, and self test capabilities.
| Model IR 1250 | 12/10/04 | Insulin delivery system, basal and bolus programmable options, computer software (Mac or PC available), minor differences between this and 1200 series, including food item-insulin pairings.
Cane
| Microjet Quark model U-100 | 12-12-01 | Pump for insulin infusion therapy.
Cardiac Pacemakers, Inc.
| Betatron IV insulin infusion system | 2-23-90 | No summary information.
Deltec/Smiths Medical
| Deltec Cozmo^®^ TM Insulin Infusion Pump (Model1700) and Accessories | 8-13-02 | Compared to: MiniMed Model 508 Insulin Pump, MiniMed 3.0-ml Reservoir, Deltec CADD-Diplomat System,and MiniMed Corn-StationTM Communication System.
| Deltec Cozmo^®^ Insulin infusion pump w/ CoZmonitor^®^ Glucose monitor | 5-27-04 | Insulin infusion pump and glucose monitor.
| Deltec Cozmo^®^ Insulin Infusion Pump model 1800 w/ CoZmonitor^®^ | 12-1-06 | Insulin infusion pump and glucose monitor.
Disetronic/ Roche
| H-TRON™ V 100 insulin infusion pump | 4-12-97 | No summary information.
| H-TRON™plus V 100 insulin infusion pump | 9-15-97 | Functionally equivalent to previous model.
| DAHEDI insulin infusion pump | 6-15-99 | Basic infusion insulin pump.
| D-TRON™ insulin infusion pump | 12-30-99 | Equivalent to H-Tron Plus V100.
| D-TRON™ insulin infusion pump | 8-2-02 | Slight modifications.
| D-TRON™plus insulin pump | 9-11-02 | Slight modifications for D-TRON.
| D-TRON™plus modification | 10-29-02 | Slight modifications for D-TRONplus.
| D-TRON™plus modification | 12-1-04 | Slight modifications for D-TRONplus.
| ACCU-CHECK^®^ Spirit | 3-18-05 | Infusion insulin pump.
| ACCU-CHEK^®^ Spirit modification | 6-15-06 | Minor modifications.
Insulet
| iXL™ Diabetes management system | 12-19-03 | Equivalent to Medtronic MiniMed. Insulin pump.
| iXL™-11 DMS | 1-3-05 | Insulin pump and blood glucose measurement system.
Mendigo
| Solo™ insulin patch pump | 7-3-09 | Same as prior models, insulin pump.
| Solo™ MicroPump insulin-delivery system | 1-25-10 | Identical to prior Solo patch pump.
Medtronic Minimed
| Model 506 external insulin pump | 7-2-90 | Insulin infusion pump.
| Infusion pump Model MMT-507 | 4-30-96 | Insulin infusion pump.
| Insulin pump model 505 | 4-8-97 | Insulin infusion pump, simplified software.
| Model 507C | 8-15-97 | Slight modification to model 507.
| Model 508 | 6-8-99 | Insulin infusion pump.
| Paradigm^®^ model 512 Insulin pump and BD Paradigm link Glucose monitor | 6-17-03 | Bolus and basal insulin pump and linked glucose monitor.
| Paradigm ®Model 511 | 7-19-04 | Insulin infusion pump.
| Model MMT-712E | 1-31-06 | Insulin infusion pump.
| MMT- 512, MMT-712, MMT-515, and MMT-715 | 4-25-08 | Continuous delivery insulin pumps.
NiliMedix
| ADI | 6-6-08 | Ambulatory insulin infusion pump.
Nipro
| Glucopro infusion pump | 6-24-02 | Equivalent to Disetronic H-Tron plus v100.
| Amigo ® | 5-9-05 | Insulin infusion pump.
| Amigo ® | 12-14-07 | Equivalent to Animas IR 1250.
Pharma-Plast
| Pharma-Plast insulin infusion set | 6-21-89 | Insulin infusion pump.
Sooil
| DANA Diabecare^®^ | 8-14-00 | Insulin infusion pump (basal and bolus).
| DANA Diabecare^®^ II | 8-2-02 | Software modifications to previous DANA.
| DANA Diabecare® IIS | 2-2-07 | Slight modifications to previous II.

Appendix Table B List of continuous glucose monitors

Manufacturer | Model | Decision Date | Features
Abbott
| FreeStyle Navigator® | 3-12-08 | 18+ CGM system, alarms
| FreeStyle Navigator® supplements | 4-2-08; 5-15-08; 5-21-08; 6-2-08; 8-6-08; 8-25-08; 10-8-08; 3-6-09; 4-9-09; 4-13-09; 5-8-09; 6-24-09; 8-21-09; 9-21-09; 9-25-09; 10-29-09; 11-20-09; 1-11-10; 1-19-10; 7-9-10 | Minor modifications to original
Dexcom
| STS^®^ Continuous Glucose Monitor | 3-24-06 | Detects trends and tracks patterns in adults (18+); indicated for use as an adjunctive device to complement, not replace, standard glucose monitoring devices; aids in detection of hyperglycemia and hypoglycemia, facilitates both acute and long-term therapy adjustments
| STS^®^ supplements; Seven plus system | 5-31-07; 8-12-06; 9-1-06; 9-22-06; 12-26-06; 1-23-07; 2-26-07; 3-15-07; 4-10-07; 5-25-07; 10-22-07; 11-13-07; 1-11-08; 5-15-08; 7-16-08; 12-3-08; 2-13-09; 5-5-09; 9-17-09; 9-23-09; 12-4-09; 1-28-10; 6-9-10; 7-15-10; 8-25-10; 9-9-10 | Various updates/modifications to the STS Continuous Glucose Monitor system
Medtronic Minimed
| Continuous Glucose Monitoring System | 6-15-99 | Continuously records interstitial glucose levels; supplements, does not replace standard at home glucose monitors. Can download the information gathered through computer software
| Guardian^®^ Telemetered Glucose Monitoring system | 2-20-02; 6-25-02; 9-5-02 | Continuous Glucose Monitor
| Guardian^®^ Real Time Continuous Glucose Monitoring System | 1-7-04 | Hypo- and hyperglycemia alerts; up to 21 days stored data.
| Paradigm^®^ Real Time System | 7-18-05; 8-24-05 | No summary information.
| Guardian^®^ Real Time | 4-7-06 | Slight modifications to enable continuous glucose monitor to communicate with insulin pump directly.
| Paradigm^®^ RT | 6-14-06 | Modifications to monitor and transmitter; can manually enter calibration.
| Guardian^®^ RT | 10-16-06 | Approval for use in Puerto Rico.
| Paradigm^®^ RT and Guardian^®^ RT | 3-8-07 | Pediatric use approved (ages 7–17 years) and adults (ages 18+ years).
| Minimed RT transmitter, CGM system | 4-18-08; 8-21-09; 11-5-09; 12-1-09; 3-20-10; 4-5-10; 6-3-10; 9-9-10 | Slight modifications.
| Continuous Glucose Monitoring System | 4-23-08 | Slight modifications.
| | 7-17-08; 8-28-08; 10-2-08; 10-3-08; 11-14-08; 11-20-08; 3-16-09; 6-16-09; 6-19-09; 8-13-09; 8-21-09; 10-1-09; 10-28-09; 10-29-09; 3-26-10; 6-10-10 8-23-10 | Slight modifications.