# Forms

Title Review Form

Abstract Review Form

Article Review Form

Study Design Form

Population Characteristics Form

Intervention Characteristics Form

Outcomes Form

Quality Form for RCTs

Quality Form for Observational Trials