# Detailed Electronic Database Search Strategies

PubMed Strategy

Terms | Returns
((“Diabetes Mellitus”[mh] OR Diabet*[tiab] OR hyperglycem*[tiab] OR hyperglycaem*[tiab]) AND (“Insulin Infusion Systems”[mh] OR “continuous subcutaneous insulin”[tiab] OR CSII[tiab] OR “insulin pump”[tiab] OR “insulin pumps”[tiab] OR “pump therapy”[tiab] OR “pump treatment”[tiab] OR “artificial pancreas”[tiab] OR (“Monitoring, Ambulatory”[mh] AND (glucose[tiab] OR insulin[tiab] OR glycem*[tiab] OR glycaem*[tiab])) OR “CGM”[tiab] OR (“continuous glucose”[tiab] AND (monitor*[tiab] OR sensing[tiab] OR sensor*[tiab])))) NOT (animal[mh] NOT human [mh]) | 4768

Embase Strategy

((‘diabetes mellitus’/exp OR diabet*:ti,ab OR hyperglycem*:ti,ab OR hyperglycaem*:ti,ab) AND (‘insulin pump’/de OR “continuous subcutaneous insulin”:ti,ab OR CSII:ti,ab OR “insulin pump”:ti,ab OR “insulin pumps”:ti,ab OR “pump therapy”:ti,ab OR “pump treatment”:ti,ab OR “artificial pancreas”:ti,ab OR (‘blood glucose monitoring’/exp AND (continu*:ti,ab OR real-time:ti,ab)) OR CGM:ti,ab OR (“continuous glucose”:ti,ab AND (monitor*:ti,ab OR sensing:ti,ab OR sensor*:ti,ab)))) NOT ([animals]/lim NOT [humans]/lim) | 5942

The Cochrane Central Register of Controlled Trials (CENTRAL)

((Diabet*:ti,ab,kw OR hyperglycem*:ti,ab,kw OR hyperglycaem*:ti,ab,kw) AND ( “continuous subcutaneous insulin”:ti,ab,kw OR CSII:ti,ab,kw OR “insulin pump”:ti,ab,kw OR “insulin pumps”:ti,ab,kw OR “pump therapy”:ti,ab,kw OR “pump treatment”:ti,ab,kw OR “artificial pancreas”:ti,ab,kw OR “CGM”:ti,ab,kw OR (“continuous glucose”:ti,ab,kw AND (monitor*:ti,ab,kw OR sensing:ti,ab,kw OR sensor*:ti,ab,kw)))) | 233 from Clinical Trials