# Acknowledgments

The Evidence-based Practice Center thanks Dr. Felicia Hill-Briggs for her guidance on the quality-of-life synthesis, Drs. Elie Donath and Ghanshyam Palamaner Subash Shantha for their assistance with reviewing articles, and Eric Vohr for his assistance in editing the report. We also wish to thank the Key Informants, Technical Expert Panel, Peer Reviewers, and Task Order Officer.