# Abbreviations

AHRQ: Agency for Healthcare Research and Quality
AUC: area under the curve
BMI: body mass index
CENTRAL: Central Register of Controlled Trials
CGM: continuous glucose monitoring
CI: confidence interval
C-section: Cesarean section
CSII: continuous subcutaneous insulin infusion
dL: deciliter
DQOL: Diabetes Quality of Life
DQOLCTQ: Diabetes Quality of Life Clinical Trials Questionnaire
DQOL-Y: Diabetes Quality of Life-Youth
DTSQ: Diabetes-Treatment Specific Questionnaire
EPC: Evidence-based Practice Center
FDA: Food and Drug Administration
g: grams
HbA_1c_: hemoglobin A1c
hrs: hours
JDRF: Juvenile Diabetes Research Foundation
KQ: Key Question
MDI: multiple daily injections
mg: milligram
NA: not applicable
NICU: neonatal intensive care unit
NPH: neutral protamine Hagedorn
NS: not significant
PAID: Problem Areas in Diabetes
PedsQoL: Pediatric Quality of Life Index
QOL: quality of life
RCTs: randomized controlled trials
rt-CGM: real-time continuous glucose monitoring
SAP: sensor-augmented pump
SDS: standard deviation scores
SF: Short Form
SMBG: self-monitoring of blood glucose
U.S.: United States
WHO-5: World Health Organization-5 Well Being Index