# Technical Expert Panel^*^ * Some Key Informants and TEP members declined to have their names listed.

Barbara Burton, M.D.

Director, PKU Program

Professor of Pediatrics

Northwestern University Feinberg School of Medicine

Chicago, IL

Ada Hamosh, M.D., M.P.H.

Professor, Department of Pediatrics and Institute of Genetic Medicine

Johns Hopkins University School of Medicine

Baltimore, MD

Cary Harding, M.D.

Associate Professor, Molecular and Medical Genetics

Oregon Health & Science University

Portland, OR

Christine Mueller, D.O.

Medical Officer, Office of Orphan Products Development

Office of Special Medical Programs/Office of the Commissioner

U.S. Food and Drug Administration

Silver Spring, MD

Rani Singh, Ph.D.

Director, Division of Medical Genetics

Emory University

Decatur, GA

Desiree White, Ph.D.

Associate Professor of Psychology

Washington University

St. Louis, MO