# References

1 Webster D, Wildgoose J. Tyrosine supplementation for phenylketonuria. Cochrane Database of Systematic Reviews. 2010;(8). Language: English. Entry Date: 20080314. Revision Date: 20101029.
2 Neonatal screening. Emery and Rimoin's principles and practice of medical genetics. New York. Churchill Livingstone. 2002:826-41.
3 Wilcox WR, Cederbaum; SD. Amino acid metabolism. Rimoin DL, Connor JM, Pyeritz RE, editors. Emery and Rimoin's principles and practice of medical genetics. 4th ed. New York. Churchill Livingstone. 2002:2405-40.
4 Fisch RO, Stassart JP. Normal infant by a gestational carrier for a phenylketonuria mother: alternative therapy. Mol Genet Metab. May. 2004;82(1):83-6. [pmid: 15110327].
5 Feillet F, MacDonald A, Hartung D, et al. Outcomes beyond phenylalanine: an international perspective. Mol Genet Metab. 2009;99(Suppl):S79-85. [pmid: 20123476].
6 Brumm VL, Bilder D, Waisbren SE. Psychiatric symptoms and disorders in phenylketonuria. Mol Genet Metab. Suppl 1. 2010;99:S59-63. [pmid: 20123472].
7 Hegge KA, Horning KK, Peitz GJ, et al. Sapropterin: a new therapeutic agent for phenylketonuria. Ann Pharmacother. Sep. 2009;43(9):1466-73. [pmid: 19654333].
8 National Institutes of Health Consensus Development Conference Statement: phenylketonuria: screening and management. October 16-18, 2000. Pediatrics. Oct. 2001;108(4):972-82. [pmid: 11581453].
9 Mabry-Hernandez I, Wolff T, Green K. Screening for phenylketonuria (PKU): a literature update for the US Preventive Services Task Force. Agency for Healthcare Research and Quality. Rockville. March. 2008.
10 Giovannini M, Verduci E, Salvatici E, et al. Phenylketonuria: Dietary and therapeutic challenges. J Inherit Metab Dis. Apr. 2007;30(2):145-52. [pmid: 17347911].
11 van Spronsen FJ, Enns GM. Future treatment strategies in phenylketonuria. Molecular Genetics and Metabolism. 2009;99(SUPPL):S90-S5. [pmid: 20123478].
12 Koch R, Burton B, Hoganson G, et al. Phenylketonuria in adulthood: a collaborative study. J Inherit Metab Dis. Sep. 2002;25(5):333-46. [pmid: 12408183].
13 Guttler F, Guldberg P. The influence of mutations of enzyme activity and phenylalanine tolerance in phenylalanine hydroxylase deficiency. Eur J Pediatr. Jul. Suppl 1. 1996;155:S6-10. [pmid: 8828600].
14 Somaraju UR, Merrin M. Sapropterin dihydrochloride for phenylketonuria. Cochrane Database of Systematic Reviews. 2010;(6). Language: English.
15 Sarkissian CN, Gámez A, Scriver CR. What we know that could influence future treatment of phenylketonuria. J Inherit Metab Dis. Feb. 2009;32(1):3-9. [pmid: 18668342].
16 Matalon R, Michals-Matalon K, Bhatia G, et al. Large neutral amino acids in the treatment of phenylketonuria (PKU). J Inherit Metab Dis. Dec. 2006;29(6):732-8. [pmid: 16988900].
17 Rocha JC, Martel F. Large neutral amino acids supplementation in phenylketonuric patients. J Inherit Metab Dis. Aug. 2009;32(4):472-80. [pmid: 19437129].
18 Koch R, Trefz F, Waisbren S. Psychosocial issues and outcomes in maternal PKU. Mol Genet Metab. Suppl 1. 2010;99:S68-74. [pmid: 20123474].
19 Levy HL, Waisbren SE, Guttler F, et al. Pregnancy experiences in the woman with mild hyperphenylalaninemia. Pediatrics. Dec. 2003;112(6 Pt 2):1548-52. [pmid: 14654663].
20 Lenke RR, Levy HL. Maternal phenylketonuria and hyperphenylalaninemia. An international survey of the outcome of untreated and treated pregnancies. N Engl J Med. Nov. 20. 1980;303(21):1202-8. [pmid: 7421947].
21 Koch R, Levy HL, Matalon R, et al. The international collaborative study of maternal phenylketonuria: status report 1994. Acta Paediatr Suppl. Dec. 1994;407:111-9. [pmid: 7766945].
22 Lee PJ, Ridout D, Walter JH, et al. Maternal phenylketonuria: report from the United Kingdom Registry 1978-97. Arch Dis Child. Feb. 2005;90(2):143-6. [pmid: 15665165].
23 Lenke RR, Levy HL. Maternal phenylketonuria--results of dietary therapy. Am J Obstet Gynecol. Mar. 1. 1982;142(5):548-53. [pmid: 7058857].
24 Levy HL, Waisbren SE. Effects of untreated maternal phenylketonuria and hyperphenylalaninemia on the fetus. New England Journal of Medicine. Nov. 24. 1983. 1983;309(21):1269-74. ill , charts. [pmid: 6633585].
25 Koch R, Wenz E, Bauman C, et al. Treatment outcome of maternal phenylketonuria. Acta Paediatr Jpn. Aug. 1988;30(4):410-6. [pmid: 3150229].
26 Naughten E, Saul IP. Maternal phenylketonuria--the Irish experience. J Inherit Metab Dis. 1990;13(4):658-64. [pmid: 2122129].
27 Levy HL, Waisbren SE, Lobbregt D, et al. Maternal non-phenylketonuric mild hyperphenylalaninemia. Eur J Pediatr. Jul. Suppl 1. 1996;155:S20-5. [pmid: 8828603].
28 Levy HL, Waisbren SE, Lobbregt D, et al. Maternal mild hyperphenylalaninaemia: an international survey of offspring outcome. Lancet. Dec. 10. 1994;344(8937):1589-94. [pmid: 7983992].
29 Whitehead H, Holmes J, Roberts R, et al. Maternal phenylketonuria 1987 to 1993, pregnancy outcome and early infant development: The Northern Ireland experience. British Journal of Obstetrics and Gynaecology. 1996;103(10):1041-4. [pmid: 8863706].
30 Rohr F, Munier A, Sullivan D, et al. The Resource Mothers Study of Maternal Phenylketonuria: preliminary findings. J Inherit Metab Dis. 2004;27(2):145-55. [pmid: 15159645].
31 Maillot F, Lilburn M, Baudin J, et al. Factors influencing outcomes in the offspring of mothers with phenylketonuria during pregnancy: the importance of variation in maternal blood phenylalanine. Am J Clin Nutr. Sep. 2008;88(3):700-5. [pmid: 18779286].
32 Lee PJ, Lilburn M, Baudin J. Maternal phenylketonuria: experiences from the United Kingdom. Pediatrics. Dec. 2003;112(6 Pt 2):1553-6. [pmid: 14654664].
33 Widaman KF, Azen C. Relation of prenatal phenylalanine exposure to infant and childhood cognitive outcomes: results from the International Maternal PKU Collaborative Study. Pediatrics. Dec. 2003;112(6 Pt 2):1537-43. [pmid: 14654661].
34 Gambol PJ. Maternal phenylketonuria syndrome and case management implications. J Pediatr Nurs. Apr. 2007;22(2):129-38. [pmid: 17382850].
35 BioMarin Pharmaceutical Inc. Kuvan (sapropterin dihydrochloride) tablets: prescribing information. Novatoa, CA. BioMarin Pharmaceutical Inc. 2007.
36 Chou R, Aronson N, Atkins D, et al. AHRQ series paper 4: assessing harms when comparing medical interventions: AHRQ and the effective health-care program. J Clin Epidemiol. May. 2010;63(5):502-12. [pmid: 18823754].
37 Poustie VJ, Wildgoose J. Dietary interventions for phenylketonuria. Cochrane Database of Systematic Reviews. 2010;(1). Language: English. Entry Date: 20080314. Revision Date: 20100514. Publication Type: journal article.
38 Campistol J, Gassió R, Artuch R, et al. Neurocognitive function in mild hyperphenylalaninemia. Developmental Medicine & Child Neurology. May. 2011;53(5):405-8. [pmid: 21418193].
39 Guldberg P, Rey F, Zschocke J, et al. A European multicenter study of phenylalanine hydroxylase deficiency: Classification of 105 mutations and a general system for genotype-based prediction of metabolic phenotype. American Journal of Human Genetics. Jul. 1998;63(1):71-9. [pmid: 9634518].
40 Singh RH, Quirk ME, Douglas TD, et al. BH(4) therapy impacts the nutrition status and intake in children with phenylketonuria: 2-year follow-up. J Inherit Metab Dis. Dec. 2010;33(6):689-95. [pmid: 20941642].
41 Guttler F. Hyperphenylalaninemia: diagnosis and classification of the various types of phenylalanine hydroxylase deficiency in childhood. Acta Paediatr Scand Suppl. 1980;280:1-80. [pmid: 7006308].
42 Hanley WB. Non-PKU mild hyperphenylalaninemia (MHP)--the dilemma. Mol Genet Metab. Sep-Oct. 2011;104(1-2):23-6. [pmid: 21632269].
43 Christ SE, Huijbregts SCJ, de Sonneville LMJ, et al. Executive function in early-treated phenylketonuria: Profile and underlying mechanisms. Molecular Genetics and Metabolism. 2009;99(SUPPL):S22-S32. [pmid: 20123466].
44 McMaster Quality Assessment Scale of Harms (McHarm) for primary studies. Hamilton ON McMaster University. 2008.
45 Owens DK, Lohr KN, Atkins D, et al. AHRQ series paper 5: grading the strength of a body of evidence when comparing medical interventions--agency for healthcare research and quality and the effective health-care program. J Clin Epidemiol. May. 2010;63(5):513-23. [pmid: 19595577].
46 Bayesian Data Analysis. 2nd ed. Chapman & Hall. 2003.
47 Smith TC, Spiegelhalter DJ, Thomas A. Bayesian approaches to random-effects meta-analysis: a comparative study. Stat Med. Dec. 30. 1995;14(24):2685-99. [pmid: 8619108].
48 Afilalo J, Duque G, Steele R, et al. Statins for secondary prevention in elderly patients: a hierarchical bayesian meta-analysis. J Am Coll Cardiol. Jan. 1. 2008;51(1):37-45. [pmid: 18174034].
49 Babapulle MN, Joseph L, Belisle P, et al. A hierarchical Bayesian meta-analysis of randomised clinical trials of drug-eluting stents. Lancet. Aug. 14-20. 2004;364(9434):583-91. [pmid: 15313358].
50 Baldwin D, Woods R, Lawson R, et al. Efficacy of drug treatments for generalised anxiety disorder: systematic review and meta-analysis. BMJ. 2011;342:d1199. [pmid: 21398351].
51 Brophy JM, Belisle P, Joseph L. Evidence for use of coronary stents. A hierarchical bayesian meta-analysis. Ann Intern Med. May. 20. 2003;138(10):777-86. [pmid: 12755549].
52 Brophy JM, Joseph L, Rouleau JL. Beta-blockers in congestive heart failure. A Bayesian meta-analysis. Ann Intern Med. Apr. 3. 2001;134(7):550-60. [pmid: 11281737].
53 Kaizar EE, Greenhouse JB, Seltman H, et al. Do antidepressants cause suicidality in children? A Bayesian meta-analysis. Clin Trials. 2006;3(2):73-90. discussion 1-8. [pmid: 16773951].
54 Sutton AJ, Abrams KR. Bayesian methods in meta-analysis and evidence synthesis. Stat Methods Med Res. Aug. 2001;10(4):277-303. [pmid: 11491414].
55 Tweedie RL, Scott DJ, Biggerstaff BJ, et al. Bayesian meta-analysis, with application to studies of ETS and lung cancer. Lung Cancer. Mar. Suppl 1. 1996;14:S171-94. [pmid: 8785662].
56 Brooks S, Gelman A, Jones G, et al., editors. Handbook of Markov Chain Monte Carlo. Methods and Applications. Chapman & Hall/CRC. 2010.
57 Gelman A. Prior distributions for variance parameters in hierarchical models. Bayesian Analysis. 2006;1(3):515-33.
58 Fonnesbeck C, et al. PyMC: Bayesian Stochastic Modelling in Python. J Stat Softw. Jan. 2010;35(4):1-80. [pmid: 21603108].
59 Waisbren SE, Noel K, Fahrbach K, et al. Phenylalanine blood levels and clinical outcomes in phenylketonuria: a systematic literature review and meta-analysis. Mol Genet Metab. Sep-Oct. 2007;92(1-2):63-70. [pmid: 17591452].
60 Anastasoaie V, Kurzius L, Forbes P, et al. Stability of blood phenylalanine levels and IQ in children with phenylketonuria. Mol Genet Metab. Sep-Oct. 2008;95(1-2):17-20. [pmid: 18703366].
61 Azadi B, Seddigh A, Tehrani-Doost M, et al. Executive dysfunction in treated phenylketonuric patients. Eur Child Adolesc Psychiatry. Jun. 2009;18(6):360-8. [pmid: 19221856].
62 Cerone R, Schiaffino MC, Di Stefano S, et al. Phenylketonuria: diet for life or not?. Acta Paediatr. Jun. 1999;88(6):664-6. [pmid: 10419254].
63 Griffiths PV, Demellweek C, Fay N, et al. Wechsler subscale IQ and subtest profile in early treated phenylketonuria. Arch Dis Child. Mar. 2000;82(3):209-15. [pmid: 10685922].
64 Jones SJ, Turano G, Kriss A, et al. Visual evoked potentials in phenylketonuria: association with brain MRI, dietary state, and IQ. J Neurol Neurosurg Psychiatry. Sep. 1995;59(3):260-5. [pmid: 7673953].
65 Leuzzi V, Rinalduzzi S, Chiarotti F, et al. Subclinical visual impairment in phenylketonuria. A neurophysiological study (VEP-P) with clinical, biochemical, and neuroradiological (MRI) correlations. J Inherit Metab Dis. Jun. 1998;21(4):351-64. [pmid: 9700592].
66 Pfaendner NH, Reuner G, Pietz J, et al. MR imaging-based volumetry in patients with early-treated phenylketonuria. Am J Neuroradiol. Aug. 2005;26(7):1681-5. [pmid: 16091513].
67 Ris MD, Weber AM, Hunt MM, et al. Adult psychosocial outcome in early-treated phenylketonuria. J Inherit Metab Dis. Aug. 1997;20(4):499-508. [pmid: 9266385].
68 Ris MD, Williams SE, Hunt MM, et al. Early-treated phenylketonuria: adult neuropsychologic outcome. J Pediatr. Mar. 1994;124(3):388-92. [pmid: 8120707].
69 Rupp A, Kreis R, Zschocke J, et al. Variability of blood-brain ratios of phenylalanine in typical patients with phenylketonuria. J Cereb Blood Flow Metab. Mar. 2001;21(3):276-84. [pmid: 11295882].
70 Schmidt E, Rupp A, Burgard P, et al. Sustained attention in adult phenylketonuria: the influence of the concurrent phenylalanine-blood-level. J Clin Exp Neuropsychol. Oct. 1994;16(5):681-8. [pmid: 7836491].
71 Seashore MR, Friedman E, Novelly RA, et al. Loss of intellectual function in children with phenylketonuria after relaxation of dietary phenylalanine restriction. Pediatrics. Feb. 1985;75(2):226-32. [pmid: 3969322].
72 Wasserstein MP, Snyderman SE, Sansaricq C, et al. Cerebral glucose metabolism in adults with early treated classic phenylketonuria. Mol Genet Metab. Mar. 2006;87(3):272-7. [pmid: 16343970].
73 Weglage J, Wiedermann D, Denecke J, et al. Individual blood-brain barrier phenylalanine transport determines clinical outcome in phenylketonuria. Ann Neurol. Oct. 2001;50(4):463-7. [pmid: 11601498].
74 Weglage J, Grenzebach M, Pietsch M, et al. Behavioural and emotional problems in early-treated adolescents with phenylketonuria in comparison with diabetic patients and healthy controls. J Inherit Metab Dis. Jul. 2000;23(5):487-96. [pmid: 10947203].
75 Weglage J, Pietsch M, Denecke J, et al. Regression of neuropsychological deficits in early-treated phenylketonurics during adolescence. J Inherit Metab Dis. Aug. 1999;22(6):693-705. [pmid: 10472530].
76 Weglage J, Pietsch M, Funders B, et al. Deficits in selective and sustained attention processes in early treated children with phenylketonuria--result of impaired frontal lobe functions?. Eur J Pediatr. Mar. 1996;155(3):200-4. [pmid: 8929728].
77 Weglage J, Pietsch M, Funders B, et al. Neurological findings in early treated phenylketonuria. Acta Paediatr. Apr. 1995;84(4):411-5. [pmid: 7795351].
78 Welsh MC, Pennington BF, Ozonoff S, et al. Neuropsychology of early-treated phenylketonuria: specific executive function deficits. Child Dev. Dec. 1990;61(6):1697-713. [pmid: 2083493].
79 Weglage J, Funders B, Wilken B, et al. School performance and intellectual outcome in adolescents with phenylketonuria. Acta Paediatr. Jun-Jul. 1993;82(6-7):582-6. [pmid: 8338995].
80 Berry HK, Sutherland BS, Hunt MM, et al. Treatment of children with phenylketonuria using a phenylalanine-free protein hydrolysate (Albumaid XP). Am J Clin Nutr. Apr. 1976;29(4):351-7. [pmid: 1266784].
81 Viau KS, Wengreen HJ, Ernst SL, et al. Correlation of age-specific phenylalanine levels with intellectual outcome in patients with phenylketonuria. J Inherit Metab Dis. Aug. 2011;34(4):963-71. [pmid: 21556836].
82 Emery AE, Farquhar JW, Timson J. Amniotic fluid amino acids in maternal phenylketonuria. Clin Chim Acta. Mar. 1972;37:544-6. [pmid: 5022122].
83 Sharman R, Sullivan K, Young R, et al. Biochemical markers associated with executive function in adolescents with early and continuously treated phenylketonuria. Clin Genet. Feb. 2009;75(2):169-74. [pmid: 19215250].
84 Anderson PJ, Wood SJ, Francis DE, et al. Are neuropsychological impairments in children with early-treated phenylketonuria (PKU) related to white matter abnormalities or elevated phenylalanine levels?. Dev Neuropsychol. 2007;32(2):645-68. [pmid: 17931123].
85 Anderson PJ, Wood SJ, Francis DE, et al. Neuropsychological functioning in children with early-treated phenylketonuria: impact of white matter abnormalities. Dev Med Child Neurol. Apr. 2004;46(4):230-8. [pmid: 15077700].
86 Channon S, Goodman G, Zlotowitz S, et al. Effects of dietary management of phenylketonuria on long-term cognitive outcome. Arch Dis Child. Mar. 2007;92(3):213-8. [pmid: 17068073].
87 Channon S, Mockler C, Lee P. Executive functioning and speed of processing in phenylketonuria. Neuropsychology. Sep. 2005;19(5):679-86. [pmid: 16187886].
88 Channon S, German E, Cassina C, et al. Executive functioning, memory, and learning in phenylketonuria. Neuropsychology. Oct. 2004;18(4):613-20. [pmid: 15506828].
89 Moyle JJ, Fox AM, Bynevelt M, et al. A neuropsychological profile of off-diet adults with phenylketonuria. J Clin Exp Neuropsychol. May. 2007;29(4):436-41. [pmid: 17497567].
90 Christ SE, Steiner RD, Grange DK, et al. Inhibitory control in children with phenylketonuria. Dev Neuropsychol. 2006;30(3):845-64. [pmid: 17083296].
91 Gassio R, Artuch R, Vilaseca MA, et al. Cognitive functions in classic phenylketonuria and mild hyperphenylalaninaemia: experience in a paediatric population. Dev Med Child Neurol. Jul. 2005;47(7):443-8. [pmid: 15991863].
92 Antshel KM, Waisbren SE. Developmental timing of exposure to elevated levels of phenylalanine is associated with ADHD symptom expression. J Abnorm Child Psychol. Dec. 2003;31(6):565-74. [pmid: 14658738].
93 Antshel KM, Waisbren SE. Timing is everything: Executive functions in children exposed to elevated levels of phenylalanine. Neuropsychology. Jul. 2003;17(3):458-68. [pmid: 12959512].
94 Huijbregts SC, de Sonneville LM, Licht R, et al. Sustained attention and inhibition of cognitive interference in treated phenylketonuria: associations with concurrent and lifetime phenylalanine concentrations. Neuropsychologia. 2002;40(1):7-15. [pmid: 11595258].
95 Griffiths P, Campbell R, Robinson P. Executive function in treated phenylketonuria as measured by the one-back and two-back versions of the continuous performance test. J Inherit Metab Dis. Apr. 1998;21(2):125-35. [pmid: 9584263].
96 Pietz J, Dunckelmann R, Rupp A, et al. Neurological outcome in adult patients with early-treated phenylketonuria. Eur J Pediatr. Oct. 1998;157(10):824-30. [pmid: 9809823].
97 Stemerdink BA, van der Meere JJ, van der Molen MW, et al. Information processing in patients with early and continuously-treated phenylketonuria. Eur J Pediatr. Sep. 1995;154(9):739-46. [pmid: 8582426].
98 de Sonneville LM, Schmidt E, Michel U, et al. Preliminary neuropsychological test results. Eur J Pediatr. Suppl 1. 1990;149:S39-44. [pmid: 2091930].
99 Luciana M, Sullivan J, Nelson CA. Associations between phenylalanine-to-tyrosine ratios and performance on tests of neuropsychological function in adolescents treated early and continuously for phenylketonuria. Child Dev. Nov-Dec. 2001;72(6):1637-52. [pmid: 11768137].
100 Waisbren SE, Azen C. Cognitive and behavioral development in maternal phenylketonuria offspring. Pediatrics. Dec. 2003;112(6 Pt 2):1544-7. [pmid: 14654662].
101 Waisbren SE, Hanley W, Levy HL, et al. Outcome at age 4 years in offspring of women with maternal phenylketonuria: the Maternal PKU Collaborative Study. JAMA. Feb. 9. 2000;283(6):756-62. [pmid: 10683054].
102 Hanley WB, Koch R, Levy HL, et al. The North American Maternal Phenylketonuria Collaborative Study, developmental assessment of the offspring: preliminary report. Eur J Pediatr. Jul. Suppl 1. 1996;155:S169-72. [pmid: 8828638].
103 Waisbren SE, Chang P, Levy HL, et al. Neonatal neurological assessment of offspring in maternal phenylketonuria. J Inherit Metab Dis. 1998;21(1):39-48. [pmid: 9501268].
104 Koch R, Hanley W, Levy H, et al. The Maternal Phenylketonuria International Study: 1984-2002. Pediatrics. Dec. 2003;112(6 Pt 2):1523-9. [pmid: 14654658].
105 Cipcic-Schmidt S, Trefz FK, Funders B, et al. German Maternal Phenylketonuria Study. Eur J Pediatr. Jul. Suppl 1. 1996;155:S173-6. [pmid: 8828639].
106 Koch R, Levy HL, Matalon R, et al. The North American Collaborative Study of Maternal Phenylketonuria. Status report 1993. Am J Dis Child. Nov. 1993;147(11):1224-30. [pmid: 8237918].
107 Platt LD, Koch R, Hanley WB, et al. The international study of pregnancy outcome in women with maternal phenylketonuria: report of a 12-year study. Am J Obstet Gynecol. Feb. 2000;182(2):326-33. [pmid: 10694332].
108 Koch R, Friedman E, Azen C, et al. The International Collaborative Study of Maternal Phenylketonuria: status report 1998. Eur J Pediatr. Oct. Suppl 2. 2000;159:S156-60. [pmid: 11043164].
109 Guttler F, Azen C, Guldberg P, et al. Impact of the phenylalanine hydroxylase gene on maternal phenylketonuria outcome. Pediatrics. Dec. 2003;112(6 Pt 2):1530-3. [pmid: 14654659].
110 Rouse B, Azen C. Effect of high maternal blood phenylalanine on offspring congenital anomalies and developmental outcome at ages 4 and 6 years: the importance of strict dietary control preconception and throughout pregnancy. J Pediatr. Feb. 2004;144(2):235-9. [pmid: 14760268].
111 The Maternal Phenylketonuria Collaborative Study: a status report. Nutr Rev. Nov. 1994;52(11):390-3. [pmid: 7854653].
112 Burton BK, Nowacka M, Hennermann JB, et al. Safety of extended treatment with sapropterin dihydrochloride in patients with phenylketonuria: Results of a phase 3b study. Mol Genet Metab. Aug. 2011;103(4):315-22. [pmid: 21646032].
113 Levy HL, Milanowski A, Chakrapani A, et al. Efficacy of sapropterin dihydrochloride (tetrahydrobiopterin, 6R-BH4) for reduction of phenylalanine concentration in patients with phenylketonuria: a phase III randomised placebo-controlled study. Lancet. Aug. 11. 2007;370(9586):504-10. [pmid: 17693179].
114 Lee P, Treacy EP, Crombez E, et al. Safety and efficacy of 22 weeks of treatment with sapropterin dihydrochloride in patients with phenylketonuria. Am J Med Genet A. Nov. 15. 2008;146A(22):2851-9. [pmid: 18932221].
115 Trefz FK, Burton BK, Longo N, et al. Efficacy of sapropterin dihydrochloride in increasing phenylalanine tolerance in children with phenylketonuria: a phase III, randomized, double-blind, placebo-controlled study. J Pediatr. May. 2009;154(5):700-7. [pmid: 19261295].
116 Vernon HJ, Koerner CB, Johnson MR, et al. Introduction of sapropterin dihydrochloride as standard of care in patients with phenylketonuria. Mol Genet Metab. Jul. 2010;100(3):229-33. [pmid: 20418136].
117 Burlina A, Blau N. Effect of BH(4) supplementation on phenylalanine tolerance. J Inherit Metab Dis. Feb. 2009;32(1):40-5. [pmid: 19067227].
118 Lambruschini N, Perez-Duenas B, Vilaseca MA, et al. Clinical and nutritional evaluation of phenylketonuric patients on tetrahydrobiopterin monotherapy. Mol Genet Metab. Dec. Suppl 1. 2005;86:S54-60. [pmid: 16040265].
119 Burton BK, Bausell H, Katz R, et al. Sapropterin therapy increases stability of blood phenylalanine levels in patients with BH4-responsive phenylketonuria (PKU). Mol Genet Metab. Oct-Nov. 2010;101(2-3):110-4. [pmid: 20638313].
120 Trefz FK, Scheible D, Frauendienst-Egger G. Long-term follow-up of patients with phenylketonuria receiving tetrahydrobiopterin treatment. J Inherit Metab Dis. 2010. Mar. 9. [pmid: 20217238].
121 Humphrey M, Nation J, Francis I, et al. Effect of tetrahydrobiopterin on Phe/Tyr ratios and variation in Phe levels in tetrahydrobiopterin responsive PKU patients. Mol Genet Metab. Sep-Oct. 2011;104(1-2):89-92. [pmid: 21624843].
122 Muntau AC, Roschinger W, Habich M, et al. Tetrahydrobiopterin as an alternative treatment for mild phenylketonuria. N Engl J Med. Dec. 26. 2002;347(26):2122-32. [pmid: 12501224].
123 Burton BK, Grange DK, Milanowski A, et al. The response of patients with phenylketonuria and elevated serum phenylalanine to treatment with oral sapropterin dihydrochloride (6R-tetrahydrobiopterin): a phase II, multicentre, open-label, screening study. J Inherit Metab Dis. Oct. 2007;30(5):700-7. [pmid: 17846916].
124 Schindeler S, Ghosh-Jerath S, Thompson S, et al. The effects of large neutral amino acid supplements in PKU: an MRS and neuropsychological study. Mol Genet Metab. May. 2007;91(1):48-54. [pmid: 17368065].
125 Matalon R, Michals-Matalon K, Bhatia G, et al. Double blind placebo control trial of large neutral amino acids in treatment of PKU: effect on blood phenylalanine. J Inherit Metab Dis. Apr. 2007;30(2):153-8. [pmid: 17334706].
126 Kirkham JJ, Dwan KM, Altman DG, et al. The impact of outcome reporting bias in randomised controlled trials on a cohort of systematic reviews. BMJ. 2010;340:c365. [pmid: 20156912].
127 Mathieu S, Boutron I, Moher D, et al. Comparison of registered and published primary outcomes in randomized controlled trials. JAMA. Sep. 2. 2009;302(9):977-84. [pmid: 19724045].