# Peer Reviewers

Phyllis Acosta, Ph.D., R.D.

Metabolic Diseases, Ross Products Division

Abbott Laboratories

Columbus, OH

Rochelle Fu, Ph.D.

Associate Professor of Biostatistics

Oregon Health and Science University

Portland, OR

Thomas Morgan, M.D.

Assistant Professor of Pediatric Medical Genetics

Monroe Carell Jr. Children's Hospital at Vanderbilt University

Nashville, TN

Anne Pariser, M.D.

Associate Director for Rare Disease Program

Office of New Drugs

U.S. Food and Drug Administration

Silver Spring, MD

Gerard Vockley, M.D., Ph.D.

Professor of Human Genetics/Pediatrics

University of Pittsburgh Medical School

Pittsburgh, PA

Susan Waisbren, Ph.D.

Associate Professor of Psychology

Harvard Medical School

Boston, MA