# Methods

## Topic Development and Refinement

The topic for this report was nominated in a public process. We drafted the initial Key Questions and analytic framework and refined them with input from key informants. These included individuals, such as geneticists, psychologists, metabolic dieticians, and nurse practitioners, who are the primary clinicians caring for individuals with phenylketonuria (PKU), as well as researchers in academia and the federal government. After review from the Agency for Healthcare Research and Quality (AHRQ), the questions and framework were posted to a public website. The public was invited to comment on these questions. After reviewing the public commentary, we drafted final Key Questions and submitted them to AHRQ for review. We identified clinical and research experts on the topic of PKU in the fields of genetics, nutrition, and psychology to provide assistance during the project. The Technical Expert Panel (TEP) contributed to the AHRQ's broader goals of (1) creating and maintaining science partnerships as well as public-private partnerships and (2) meeting the needs of an array of potential customers and users of its products. Thus, the TEP was both an additional resource and a sounding board during the project. The TEP included eight members serving as technical or clinical experts. To ensure robust, scientifically relevant work, we called on the TEP to provide reactions to work in progress. TEP members participated in conference calls and discussions through e-mail to:

- Refine the analytic framework and Key Questions at the beginning of the project;
- Discuss the preliminary assessment of the literature, including inclusion/exclusion criteria.

As noted, this report focuses on the use of adjuvant treatments for PKU and does not address dietary restriction alone. The effectiveness of dietary restriction has been demonstrated in previous studies,12, 37 and it is well established as the cornerstone of PKU therapy.8

## Role of the AHRQ Task Order Officer

The Task Order Officer (TOO) was responsible for overseeing all aspects of this project. The TOO helped to develop a common understanding among all parties involved in the project, resolved questions and ambiguities, and addressed our queries regarding the scope and processes of the project. The TOO reviewed the report for consistency, clarity, and to ensure that it conforms to AHRQ standards.

## Analytic Framework

We developed the analytic framework (Figure 1) based on clinical expertise and refined it with input from our key informants and TEP members. The framework summarizes the process by which treatment is chosen and modified for infants, children, adolescents, adults, or pregnant women with PKU. The treatment choice that is the basis of this review is whether to add adjuvant treatment in the form of sapropterin (BH4) or large neutral amino acids (LNAAs) to dietary therapy. The primary target health outcome is maintenance of cognition, with secondary outcomes including increasing quality of life. Monitoring blood phenylalanine (Phe) levels provides an intermediate marker of treatment success because these levels are used to adjust the dietary intake of Phe in an effort to mitigate the cognitive decline that can occur from elevated blood Phe levels.

Figure 1 Analytic framework for treatment questions

BH4 = sapropterin dihydrochloride; LNAAs = large neutral amino acids; Phe = phenylalanine; PKU = phenylketonuria

* Encompasses a full range of specific negative effects, including the narrower definition of adverse events. Can include costs, medical side effects, poor quality of life, etc.

Note: Numbers in circles indicate the positioning of Key Questions in the treatment process.

The analytic framework illustrates the relationship between infants, children, adolescents, and adults with PKU and females with PKU who become pregnant, treatment choices for PKU, monitoring, outcomes, and harms. Patients may choose a Phe-restricted diet alone or a Phe-restricted diet in conjunction with treatment with sapropterin dihydrochloride or large neutral amino acids, followed by monitoring of Phe levels. Depending upon the Phe level the treatment may be altered. Therapies may lead to intermediate and long-term outcomes and harms. Intermediate treatment outcomes include decreased Phe levels in the blood and improved Phe tolerance. Therapies may also lead to long term outcomes, including changes in quality of life, normal growth, nutritional outcomes, and cognitive development. Outcomes in infants of mothers with PKU include the prevention of neurologic impairment and cardiac defects and normal growth.

In maternal PKU, treatment is intended to prevent neurologic impairment and cardiac defects in the infant (who typically does not have PKU) caused by the teratogenic effects of excessively high Phe levels in the maternal bloodstream. The Phe level of the mother is monitored throughout the pregnancy to guide modifications to the diet or other treatment approaches.

## Literature Search Strategy

### Databases

We employed systematic search strategies (Appendix A) to retrieve research on the treatment of PKU. Our primary literature search employed five databases: MEDLINE® via the PubMed interface, PsycINFO (CSA Illumina interface; psychology and psychiatry literature), Embase, the Cumulative Index of Nursing and Allied Health Literature (CINAHL) database, and the National Agricultural Library (AGRICOLA) database. Our search strategies used a combination of subject heading terms appropriate for each database and key words relevant to PKU (e.g., phenylketonuria, pharmaceutical preparations, phenylalanine). We limited searches to the English language but did not set a date limit.

We also manually searched the reference lists of included studies and of recent narrative and systematic reviews and meta-analyses addressing PKU. We also invited TEP members to provide citations.

### Search Terms

Controlled vocabulary terms served as the foundation of our search in each database, complemented by additional keyword phrases. We also employed indexing terms when possible within each of the databases to exclude undesired publication types (e.g., reviews, case reports, news), items from non-peer-reviewed journals, and items published in languages other than English.

Our searches for primary literature were executed between August 2010 and August 2011. Because we identified no literature on the pharmacologic treatment of pregnant women in our initial searches, we conducted an additional search to identify any case reports of pharmacologic management in pregnancy on February 4, 2011. Appendix A provides our search terms and the yield from each database.

### Grey Literature

#### Grey Literature Search

We searched Internet resources to identify current research and regulatory information using topically relevant keywords (e.g., kuvan, sapropterin, phenylketonuria). All search results were limited to English language. Resources included the Web sites of regulatory agencies (U.S. Food and Drug Administration, Health Canada, European Medicines Agency, Japan's Pharmaceutical and Medical Devices Agency), and clinical trials registries (clinicaltrials.gov, International Clinical Trials Registry Platform, Current Controlled Trials, European Union Clinical Trials Register). We also searched compilations of abstracts presented at major scientific meetings addressing PKU (annual meetings of the National PKU Alliance, American College of Human Genetics, Society for Inherited Metabolic Disorders American Society of Medical Genetics, and the Society for the Study of Inborn Errors of Metabolism) for treatment-related presentations given from 2006 (where possible) to 2011. Abstracts for each conference for each year were not available electronically.

Additionally, we searched commercial databases such as LexisNexis and a number of PKU-related websites specifically for any legal procedures related to the drug that might be a source of additional data. Searches were executed between January and June 2011. Finally, per Evidence based Practice Center (EPC) protocol, the maker of Kuvan, Biomarin, as well as manufacturers of LNAAs (Applied Nutrition Corporation, Solace Nutrition, Nutricia North America), were invited to provide Scientific Information Packets, but none did so.

## Review of Reviews

We searched for relevant systematic reviews that might provide information for this review. In particular, we found a body of review literature focused on the relationship between blood Phe and outcomes listed in the Key Questions. We assessed this literature systematically to determine whether it was specifically relevant to our research questions and of high quality.

We assessed relevance of the reviews by determining if the review (1) included studies of individuals with PKU, (2) assessed the relationship of Phe level and cognition, (3) included studies with at least 10 participants, (4) included studies in English only, and (5) was conducted systematically. If a review met these criteria, then we assessed the quality of the review by considering elements assessing the rigor of a review's design and completeness of reporting.

## Process for Individual Study Selection

For this review, the relevant populations for Key Question 2 and Key Question 4 were infants (<2 years), children (2 to 12 years), adolescents (13 to 21 years), and adults (≥21years) with PKU. The relevant population for Key Question 3 and Key Question 5 was pregnant women with PKU. All subgroups were relevant to Key Question 1, Key Question 6, and Key Question 7.

### Inclusion and Exclusion Criteria

We developed criteria for inclusion and exclusion based on the patient populations, interventions, outcome measures, and types of evidence specified in the Key Questions and in consultation with the TEP. Table 1 summarizes criteria.

Table 1 Inclusion and exclusion criteria

Category | Criteria
Population | Humans only:; - Infants with PKU* <2 years of age; - Children with PKU* 2-12 years of age; - Adolescents with PKU* 13-21 years of age; - Pregnant women with PKU*; - Adults with PKU* >21 years of age; * As operationalized by study authors.
Interventions | BH4 LNAAs
Comparators | Dietary therapy alone (Phe-restricted diet and medical foods) or in conjunction with other intervention Placebo
Outcomes | [underlined: Key Questions 1a, 1b] Changes in cognition including executive function and IQ [underlined: Key Questions 2-7] Intermediate Outcomes; - Phe level; - Phe tolerance; - Phe variability; - Harms; Long term Outcomes; - Cognitive outcomes; - Liberalization of diet; - Nutritional outcomes; - Quality of life; - Harms
Time period | All years
Publication languages | English only
Admissible evidence (study design and other criteria) | [underlined: Admissible designs]; - Randomized controlled trials, uncontrolled open label trials, prospective and retrospective cohort studies with comparison groups, case series with no comparators, case control studies, and cross-sectional studies; [underlined: Sample size]; - N ≥ 10 individuals with PKU; [underlined: Other criteria]; - Original research studies that provide sufficient detail regarding methods and results to enable use and adjustment of the data and results; - Studies must include extractable data on relevant outcomes

BH4 = sapropterin dihydrochloride; LNAAs = large neutral amino acids; N = number; PKU = phenylketonuria

#### Study Population

Studies needed to provide adequate information to ensure that participants were in the target study population. We only included studies with human participants who had any form of PKU or hyperphenylalaninemia. We did not include studies with participants who had primary BH4 deficiency. We recognize that classification of the severity of PKU varies across countries and clinics.8, 38-42 Therefore, we did not impose a specific classification of PKU types (e.g. classic versus moderate of mild); rather, we allowed the definitions of PKU as they were operationalized by study authors.

#### Language

We included only English language studies. Our technical experts concurred that very few studies on PKU are published in other languages, and those studies that are published in other languages are also typically published in English.

#### Time Period

No time limits were set in this review.

#### Sample Size

As an inclusion criterion, we set the cutoff level at a minimum of 10 participants. PKU is a rare condition; therefore, recruitment into larger research studies is slow and challenging. Most studies enroll fewer than 20 participants. We anticipated being unable to combine treatment studies analytically; thus it would not have been appropriate to include even smaller studies that would be unable to independently demonstrate effect. For the first Key Question on Phe and cognition, we intended to combine studies quantitatively; for those questions, using a minimum sample size of 10 provided ample data for analysis.

#### Study Design

We included randomized controlled trials (RCTs) and uncontrolled open label trials, prospective and retrospective cohort studies, and case series and case control studies addressing the effectiveness of pharmacological treatment approaches (Key Questions 2 to 7). In addition to these designs, we included cross-sectional studies to address the question about identifying target blood Phe levels to optimize outcomes (Key Question 1).

#### Outcomes

Key Question 1 seeks to identify “specific Phe levels that are optimal for minimizing or avoiding cognitive impairment in individuals with PKU.” We defined cognitive impairment as deficits in IQ or executive function. For measures of executive function, we sought outcomes in the following categories: working memory, attention, cognitive flexibility, planning, and inhibitory control. The specific measures for each of these outcomes used in studies meeting our criteria are presented in Table 2.

Table 2 Measures of executive function reported in studies assessed for this review

Domain | Measures
Attention | - Amsterdam Neuropsychological Tasks-Sustained Attention (Tempo, Bias); - California Verbal Learning Test-Auditory Attention Diagnostic Method; - California Verbal Learning Test-Children's version; - Color Word Interference Task; - Continuous Performance Test-Omission Errors; - Continuous Performance Test-Successfully recognized matches; - D2-Aufmerksamkeits-Belastungs-Test; - Sonneville Visual Attention Tasks-Calculation Exercise; - Sonneville Visual Attention Tasks-Dot Pattern Exercise; - Test of Everyday Attention for Children (Sky Search, Ode Transmission, Digital Distraction, Telephone Search, Sky Search Dual Task); - Videotracking; - Wechsler Adult Intelligence Scale-Revised Digit Span Forward
Cognitive flexibility | - Contingency Naming Test; - Delis-Kaplan Executive Functioning System Trail Making; - Intradimensional/Extradimensional Set-Shifting Task; - Trail Making Test A & B; - Wisconsin Card Sorting Test (Categories, Perseverative Errors, Perseverative Responses); - Zahlen-Verbindungs-Test (Trail Making Test)
Inhibitory control | - Antisaccade; - Behavior Rating Inventory of Executive Function Inhibit Scale; - Continuous Performance Test-Commission Errors; - Day-Night Stroop-like Test; - Flanker/Eriksen and Schultz; - Go/No Go; - Stroop Color and Word; - Stroop Word Reading Task
Planning | - Tower of Hanoi; - Tower of London
Working memory | - Digit Span; - Memory Search Task; - n-Back; - Self-Ordered Pointing; - Spatial Working Memory; - Wechsler Adult Intelligence Scale Third Edition-Working Memory Index; - Wechsler Adult Intelligence Scale-Revised Digit Span Back; - Wechsler Intelligence Scale for Children-III Digit Span; - Working Memory Scale Third Edition

For treatment-related questions (Key Questions 2 to 7), we sought outcomes that included liberalization of diet, nutritional outcomes, quality of life, and changes in cognition, including executive function and IQ. We also report on intermediate outcomes (Phe level, Phe tolerance, and Phe variability).

### Additional Criteria for Key Question 1

#### Phe Levels and IQ

Because the purpose of Key Question 1 was to identify a “specific” Phe level at which outcomes were observed, we required appropriate quantitative data to conduct the analysis for this question for both IQ and executive function. Papers needed to include either individual-level data on both Phe and the outcome or a mean/median and some measure of variance (usually standard deviation) for both.

For the purpose of the analysis of IQ in Key Question 1, while intellectual disability is defined as IQ score lower than 70 (i.e., two standard deviations below the population mean) and impairment in activities of daily living, IQ scores within the normal range could be considered impairment if they are lower than the expected value for the general population. Though necessarily subjective, we believe that a reasonable candidate for impairment is a threshold of one standard deviation below the population mean, or an IQ score of 85. It is expected that subjects below this threshold would exhibit at least some symptoms of cognitive impairment, such as poor language development, problem solving deficiencies, and memory deficits.

#### Phe Levels and Measures of Executive Function

To estimate a range of blood Phe levels associated with poor executive function outcomes, we sought to conduct a meta-analysis of papers that could provide data on this relationship. As such, we required that studies provide either individual data on blood Phe level and executive function measures or average Phe and executive function measures along with variance and correlation information. Studies also needed an appropriate control population (i.e., healthy individuals without PKU) for normative data.

Using input from clinical experts and published classifications of measures of executive function,43 we grouped the measures employed in the studies meeting our criteria under core domains of executive function. These domains included working memory, cognitive flexibility, inhibitory control, attention, and planning (Table 2).

We then assessed whether the studies within each domain were suitable for meta-analysis by examining the number of studies using a given test. We required that a test be used in at least three studies to be considered for meta-analysis.

## Screening of Studies

Once we identified articles through the electronic database searches, review articles, and bibliographies (discussed above), we examined abstracts of articles to determine whether studies met our criteria. Two reviewers separately evaluated each abstract for inclusion or exclusion, using an Abstract Review Form (Appendix B). If at least one reviewer concluded that the article could be eligible for the review based on the abstract, we retained it for full text assessment.

Two reviewers independently assessed the full text of each included study using a standardized form (Appendix B) that included questions stemming from our inclusion/exclusion criteria. Disagreements between reviewers were resolved by a third-party adjudicator. The group of abstract and full text reviewers included expert clinicians (TR, ML) and health services researchers (MM, SK, JF).

## Data Extraction and Data Management

Evidence tables were used as data extraction tools and were jointly developed and tested by the team. All data were extracted by one team member and checked by a second. For Key Question 1, the data extraction process captured information on cognitive outcomes, as well as aspects of dietary treatment important to measuring Phe levels for Key Question 1. These included type of Phe measurement (lifetime, historical, concurrent, recent), treatment status (early, continuously), and disease type/classification. Evidence tables for the treatment questions collected this information as well as treatment details, key study design and comparator data. When possible to identify, analyses resulting from the same study were grouped into a single evidence table. The final evidence tables are presented in their entirety in Appendix C.

## Individual Study Quality Assessment

We assessed quality using a domain-based approach, with separate tools as appropriate by study design. The detailed tools used to assess quality are in Appendix D. Studies for Key Question 1 were primarily cross-sectional, while treatment studies were largely RCTs or uncontrolled open label trials thus necessitating separate approaches. In addition, we used the McMaster harms tool44 to assess harms in treatment studies.

Two reviewers independently assessed quality for each study, with final decisions made by third party adjudication and consensus of the team as needed. We describe the individual quality components below and report individual quality assessments for each study in Appendix E.

### Determining Quality Levels

We used targeted sets of questions to assess randomized trials, case series, cohort, and case-control studies. Appendix D includes the individual questions used to assess each study type, and Appendix E lists scores for each question for each study. For all but the uncontrolled open label trials, we required that studies receive a positive score on all of the questions used to assess quality to receive a rating of “good.” For uncontrolled open label trials, we scored studies with one negative score as fair quality and those with more than one negative score as poor quality.

### Grading the Body of Evidence for Each Key Question

We evaluated the overall strength of the evidence for the primary outcomes. We used the approach to determining strength of evidence as described in the EPCs' Methods Guide for Effectiveness and Comparative Effectiveness Reviews.45 We assessed the strength of evidence for key outcomes identified by the clinical investigators to be most clinically important: cognitive outcomes including IQ and executive function, nutritional outcomes, quality of life, and liberalization of diet. Secondary outcomes included changes in blood Phe levels, Phe variability, and Phe tolerance.

We examined the following four major domains: risk of bias (low, medium, high), consistency (inconsistency not present, inconsistency present, unknown or not applicable), directness (direct, indirect), and precision (precise, imprecise). We assigned each key outcome for each comparison of interest an overall evidence grade based on the ratings for the individual domains.

The overall strength of evidence could be graded as “high” (indicating high confidence that the evidence reflects the true effect and further research is very unlikely to change our confidence in the estimate of effect); “moderate” (indicating moderate confidence that the evidence reflects the true effect and further research may change our confidence in the estimate of effect and may change the estimate); “low” (indicating low confidence that the evidence reflects the true effect and further research is likely to change our confidence in the estimate of effect and is likely to change the estimate); or “insufficient” (indicating that evidence is either unavailable or does not permit estimation of an effect). When no studies were available for an outcome or comparison of interest, we assessed the evidence as insufficient. Two reviewers independently graded the body of evidence; disagreements were resolved through discussion or a third reviewer adjudication.

## Data Synthesis

We used both qualitative and quantitative approaches to synthesizing the data. When possible in Key Question 1, we used meta-analytic approaches to identify threshold Phe levels.

### Meta-analytic Methods

We provide a detailed description of the meta-analysis in Appendix F and summarize the methods here. We required that studies eligible for the meta-analysis include data in one of two forms:

- Individual level data: Measurements of both blood Phe and IQ for each non-control individual in the study (control individuals did not generally have Phe measurements taken), or
- Summarized data: Means/medians and standard deviations of Phe and IQ if individual level data were not available, provided that the study reported a correlation coefficient (Pearson's or Spearman's r) for these two measures, and data to allow for an associated measure of uncertainty for r to be computed.

We defined measurements of blood Phe reported in studies as concurrent (taken <6 weeks) with IQ testing, historical (taken more than one year prior), or both. No included studies reported Phe measurements taken more than 6 weeks but less than one year prior to IQ testing (“recent”). We also considered measurements taken before age 6 to comprise the critical period from the standpoint of cognitive development. To avoid pooling these disparate types of measurements, we estimated two models, one for concurrent Phe measurements and a second for historical Phe measurements. The model structure described below was replicated identically for concurrent and historical measurements of Phe to obtain separate estimates of their effects.

We meta-analyzed the association of blood Phe levels with IQ using a Bayesian hierarchical mixed effects model.46 The advantages of using a Bayesian approach to meta-analysis were recognized over a decade ago,47 and they have been applied extensively ever since.48-55 It allows for straightforward probabilistic inference across studies, and can accommodate both fixed and random effects. In contrast to the more indirect measures of inference afforded by classical methods, all inference from Bayesian models is in the form of probability statements that describe the uncertainty in the unknown quantities of interest (θ), given the information at hand (y):

Pr ( θ ∣ y ) ∝ Pr ( y ∣ θ ) Pr ( θ )

The left side of this equation is the posterior distribution of all unknown parameters in the model, while the right side shows that this posterior quantity is the product of a data likelihood and the prior distribution (i.e., before data are observed) of the model. While in principle the use of priors allows for the incorporation of extant information into the analysis, we used uninformative priors on all parameters, allowing the results from the included studies to completely inform the analysis.

Using random effects for meta-analysis permits us to abandon the tenuous assumption that the effects across studies are independent and identically distributed. Rather, we view them as exchangeable samples from a “population” of PKU studies. This conditional independence (i.e., conditional on population parameters) assumption avoids either having to combine studies in a single estimate (which assumes they are identical) or keeping them entirely separate (which assumes they are completely different), but rather, allows for some mixture of the two extremes. In contrast, fixed effects models force one of these unlikely extremes.

We specified random effects for the intercept and slope parameters of a linear relationship between blood Phe level and IQ. Importantly, this allowed each study to have its own parameters, each sampled from a notional population of parameters. Those with smaller sample sizes were automatically shrunk towards the population means for each parameter, with larger studies influencing the estimate of the population mean more than being influenced by it. In turn, the magnitude of the effect (i.e., slope) was specified partly as a function of a fixed effect for whether measurements of Phe were carried out during the critical period. Hence, the overall model was a hierarchical mixed effects model. Bayesian hierarchical models are very easily estimated using Markov chain Monte Carlo (MCMC) methods.56

As noted, all stochastic parameters were specified using diffuse prior distributions. For all linear model coefficients, a normal distribution with mean zero and precision (inverse-variance) 0.01 was used. For precision parameters, the standard deviation was modeled uniformly on the interval (0, 1000) and then transformed to inverse variance; this provides a better non-informative prior than modeling the precision directly.57

In order to evaluate the association of particular levels of Phe with the likelihood of cognitive impairment, we chose a threshold value of IQ to define impairment. For a standardized measure like IQ, a boundary of one standard deviation below the mean (IQ=85) is an appropriate choice. We used this threshold value to define indicator variables that were set to one if the value of the predicted IQ was below 85 during the current iteration of the MCMC sampler, and zero otherwise. Hence, for each combination of Phe level and critical period indicator, the total number of ones divided by the number of MCMC iterations represents a probability of observing IQ<85. To estimate the sensitivity of this probability to Phe, this probability was calculated for a range of blood Phe levels from 200 to 3000 μmol/L, in increments of 200. This was done for critical period and non-critical period Phe measurement, under both the historical and concurrent measurement models.

We coded the model in PyMC version 2.1^58^ which implements several MCMC algorithms for fitting Bayesian hierarchical models. The model was run for one million iterations, with the first 900000 discarded as a burn-in interval. The remaining sample was thinned by a factor of ten to account for autocorrelation, yielding 10000 samples for inference. Posterior predictive checks46 were performed, which compare data simulated from the posterior distribution with the observed data. This exercise showed no substantial lack of fit for any of the studies included in the dataset.