# Key Informants^*^ * Some Key Informants and TEP members declined to have their names listed.

Jeffrey Botkin, M.D., M.P.H.

Professor of Pediatrics

University of Utah School of Medicine

Salt Lake City, UT

Cary Harding, M.D.

Associate Professor, Molecular and Medical Genetics

Oregon Health & Science University

Portland, OR

Celide Koerner, R.N., M.S.R.D.

Senior Research Nurse, Institute of Genetic Medicine

Johns Hopkins University

Baltimore, MD

Rani Singh, Ph.D.

Director, Division of Medical Genetics

Emory University

Decatur, GA

Robert Steiner, M.D.

Attending Physician, Doernbecher Children's Hospital

Oregon Health & Science University

Portland, OR

Stephanie Stremer

President, PKU and Allied Disorders of Wisconsin

Waunakee, WI

Desiree White, Ph.D.

Associate Professor of Psychology

Washington University

St. Louis, MO