# Recent Conference Abstracts Addressing Adjuvant Treatment

Table K-1 Recent conference abstracts addressing adjuvant treatment

## References

1 Shintaku H, Ohwada M, Aoki K, et al. Diagnosis of tetrahydrobiopterin (BH4) responsive mild phenylketonuria in Japan over the past 10 years. Ann Acad Med Singapore. Dec. 2008;37(12 Suppl):77-2. [pmid: 19904458].
2 Burton BK, Bausell H, Katz R, et al. Sapropterin therapy increases stability of blood phenylalanine levels in patients with BH4-responsive phenylketonuria (PKU). Mol Genet Metab. Oct-Nov. 2010;101(2-3):110-4. [pmid: 20638313].
3 Burton BK, Nowacka M, Hennermann JB, et al. Safety of extended treatment with sapropterin dihydrochloride in patients with phenylketonuria: Results of a phase 3b study. Mol Genet Metab. Aug. 2011;103(4):315-22. [pmid: 21646032].
4 Koch R, Moseley K, Guttler F. Tetrahydrobiopterin and maternal PKU. Mol Genet Metab. Dec. Suppl 1. 2005;86:S139-41. [pmid: 16338627].
5 Burton BK, Grange DK, Milanowski A, et al. The response of patients with phenylketonuria and elevated serum phenylalanine to treatment with oral sapropterin dihydrochloride (6R-tetrahydrobiopterin): a phase II, multicentre, open-label, screening study. J Inherit Metab Dis. Oct. 2007;30(5):700-7. [pmid: 17846916].
6 Lee P, Treacy EP, Crombez E, et al. Safety and efficacy of 22 weeks of treatment with sapropterin dihydrochloride in patients with phenylketonuria. Am J Med Genet A. Nov. 15. 2008;146A(22):2851-9. [pmid: 18932221].
7 Levy HL, Milanowski A, Chakrapani A, et al. Efficacy of sapropterin dihydrochloride (tetrahydrobiopterin, 6R-BH4) for reduction of phenylalanine concentration in patients with phenylketonuria: a phase III randomised placebo-controlled study. Lancet. Aug. 11. 2007;370(9586):504-10. [pmid: 17693179].