# Summary of New Drug Application Studies of Sapropterin

Table J-1 Summary of New Drug Application studies