# Studies Addressing Maternal PKU

Table I-1 Overview of Maternal PKU Collaborative Study (MPKUCS) papers

Table I-2 Overview of additional Maternal PKU studies

Table I-3 Summary of maternal PKU studies reporting cognitive outcomes

## References

1 Rouse B, Azen C. Effect of high maternal blood phenylalanine on offspring congenital anomalies and developmental outcome at ages 4 and 6 years: the importance of strict dietary control preconception and throughout pregnancy. J Pediatr. Feb. 2004;144(2):235-9. [pmid: 14760268].
2 Guttler F, Azen C, Guldberg P, et al. Impact of the phenylalanine hydroxylase gene on maternal phenylketonuria outcome. Pediatrics. Dec. 2003;112(6 Pt 2):1530-3. [pmid: 14654659].
3 Levy HL, Waisbren SE, Guttler F, et al. Pregnancy experiences in the woman with mild hyperphenylalaninemia. Pediatrics. Dec. 2003;112(6 Pt 2):1548-52. [pmid: 14654663].
4 Waisbren SE, Azen C. Cognitive and behavioral development in maternal phenylketonuria offspring. Pediatrics. Dec. 2003;112(6 Pt 2):1544-7. [pmid: 14654662].
5 Koch R, Hanley W, Levy H, et al. The Maternal Phenylketonuria International Study: 1984-2002. Pediatrics. Dec. 2003;112(6 Pt 2):1523-9. [pmid: 14654658].
6 Widaman KF, Azen C. Relation of prenatal phenylalanine exposure to infant and childhood cognitive outcomes: results from the International Maternal PKU Collaborative Study. Pediatrics. Dec. 2003;112(6 Pt 2):1537-43. [pmid: 14654661].
7 Antshel KM, Waisbren SE. Developmental timing of exposure to elevated levels of phenylalanine is associated with ADHD symptom expression. Journal of Abnormal Child Psychology: An official publication of the International Society for Research in Child and Adolescent Psychopathology. Dec. 2003;31(6):565-74.
8 Antshel KM, Waisbren SE. Timing is everything: Executive functions in children exposed to elevated levels of phenylalanine. Neuropsychology. Jul. 2003;17(3):458-68. [pmid: 12959512].
9 Platt LD, Koch R, Hanley WB, et al. The international study of pregnancy outcome in women with maternal phenylketonuria: report of a 12-year study. Am J Obstet Gynecol. Feb. 2000;182(2):326-33. [pmid: 10694332].
10 Koch R, Friedman E, Azen C, et al. The International Collaborative Study of Maternal Phenylketonuria: status report 1998. Eur J Pediatr. Oct. Suppl 2. 2000;159:S156-60. [pmid: 11043164].
11 Waisbren SE, Hanley W, Levy HL, et al. Outcome at age 4 years in offspring of women with maternal phenylketonuria: the Maternal PKU Collaborative Study. JAMA. Feb. 9. 2000;283(6):756-62. [pmid: 10683054].
12 Waisbren SE, Chang P, Levy HL, et al. Neonatal neurological assessment of offspring in maternal phenylketonuria. Journal of Inherited Metabolic Disease. 1998;21(1):39-48. [pmid: 9501268].
13 Hanley WB, Koch R, Levy HL, et al. The North American Maternal Phenylketonuria Collaborative Study, developmental assessment of the offspring: preliminary report. Eur J Pediatr. Jul. Suppl 1. 1996;155:S169-72. [pmid: 8828638].
14 Cipcic-Schmidt S, Trefz FK, Funders B, et al. German Maternal Phenylketonuria Study. Eur J Pediatr. Jul. Suppl 1. 1996;155:S173-6. [pmid: 8828639].
15 Koch R, Levy HL, Matalon R, et al. The international collaborative study of maternal phenylketonuria: status report 1994. Acta Paediatr Suppl. Dec. 1994;407:111-9. [pmid: 7766945].
16 Koch R, Levy HL, Matalon R, et al. The North American Collaborative Study of Maternal Phenylketonuria. Status report 1993. Am J Dis Child. Nov. 1993;147(11):1224-30. [pmid: 8237918].
17 Maillot F, Lilburn M, Baudin J, et al. Factors influencing outcomes in the offspring of mothers with phenylketonuria during pregnancy: the importance of variation in maternal blood phenylalanine. Am J Clin Nutr. Sep. 2008;88(3):700-5. [pmid: 18779286].
18 Lee PJ, Lilburn M, Baudin J. Maternal phenylketonuria: experiences from the United Kingdom. Pediatrics. Dec. 2003;112(6 Pt 2):1553-6. [pmid: 14654664].
19 Levy HL, Waisbren SE. Effects of untreated maternal phenylketonuria and hyperphenylalaninemia on the fetus. New England Journal of Medicine. Nov. 24. 1983. 1983;309(21):1269-74. ill , charts. [pmid: 6633585].
20 Levy HL, Mitchell ML. The current status of newborn screening. Hosp Pract (Off Ed). Jul. 1982;17(7):89-97. [pmid: 6809575].
21 Hanley WB, Azen C, Koch R, et al. Maternal phenylketonuria collaborative study (MPKUCS) - The ‘outliers’. Journal of Inherited Metabolic Disease. 2004;27(6):711-23. [pmid: 15505376].